# Chapter 3 Results

## Literature Search

We identified 6,288 unique records and assessed 1,086 full-text articles for eligibility (Figure 2). We excluded 985 studies for various reasons, detailed in Appendix C, and included 86 studies reported in 101 articles. Of these, 26 studies (reported in 31 articles) and 2 companion articles to previously included studies are new and were not included in the previous USPSTF review on this topic. Details of quality assessments of included studies are in Appendix D Tables 1–7.

Figure 2 Summary of Evidence Search and Selection

Note: The sum of the number of studies per KQ exceeds the total number of studies because some studies were applicable to multiple KQs.

Abbreviation: KQ=key question.

Figure 2 is a flow diagram that documents the search and selection of evidence. Records were identified by searching PubMed (n=2,262), Cochrane Library (n=35), Embase (n=2,986), and ClinicalTrials.gov (n=866). In addition, records were identified from the 2017 Screening for Obstructive Sleep Apnea in Adults Evidence Review for the U.S. Preventive Services Task Force (n=127) and through handsearching (n=12). In total, 6,288 unique titles and abstracts were screened for potential inclusion. Of these, 1,086 were deemed appropriate for full-text review to determine eligibility. After full-text review, 985 were excluded: 15 for non-English; 80 for ineligible population; 66 for ineligible screening; 49 for ineligible treatment; 177 for ineligible comparison; 211 for ineligible outcome; 11 for ineligible setting; 217 for ineligible study design; 45 for intermediate outcome only; 33 for ineligible country; 1 for non-English screener; 68 for being abstracts only; 6 for poor quality; 2 for being irretrievable; and 4 for being irrelevant systematic reviews. Eighty-six studies represented in 101 articles met inclusion criteria. No study was included for Key Question 1. Seven studies were included for Key Question 2. No study was included for Key Question 3. Four studies were included for Key Question 4. Seventy-three studies represented in 87 articles were included for Key Question 5. Nineteen studies represented in 24 articles were included for Key Question 6.

## Results by KQ

### KQ 1 Does Screening for OSA in Adults Improve Health Outcomes, Including for Specific Subgroups of Interest?

We found no eligible study that addressed this question.

### KQ 2 What Is the Accuracy of Screening Questionnaires, Clinical Prediction Tools, and Multistep Screening Approaches (e.g., Using a Questionnaire Followed by Home-Based Oximetry/Testing) in Identifying Persons in the General Population Who Are More or Less Likely to Have OSA, Including for Specific Subgroups of Interest?

We included seven fair-quality studies^112–118^ assessing clinical prediction tools or screening questionnaires compared with facility-based PSG, four of which were new to this review (Table 1).^115–118^ Two evaluated the BQ,^112,^ ^115^ four evaluated the STOP-BANG Questionnaire^115–118^ and two evaluated the Multivariable Apnea Prediction (MVAP) score—alone and when followed by an unattended HST.^113,^ ^114^ We found no eligible studies of good or fair quality evaluating other clinical prediction tools or screening questionnaires, such as the ESS.

Table 1 Characteristics of Included Studies Assessing the Accuracy of Clinical Prediction Tools or Screening Questionnaires (KQ 2)

First Author, Year; Country | N | Study Design | Study Quality | Participants | Name of Questionnaire(s)/Tool(s) | Mean Age (SD) | % F | % Race/Ethnicity | Mean BMI (SD) | Mean AHI (SD) | % With HTN | % With OSA
Hrubos-Strom, 2011^112^; Norway | 518^*^ | Cross-sectional | Fair | Randomly drawn from Norwegian National Population Register | BQ (Norwegian translation) | 48 (11.2) | 45 | NR | 28 (4.8) | Median 6.4 (NR^†^) | 27 | NR
Morales, 2012^113^; United States | 452 | Cross-sectional | Fair | Medicare recipients from greater Philadelphia metro region, most with some daytime sleepiness^‡^ | MVAP score; MVAP score + AHI from unattended HST | 71 (5.4) | 70 | African American: 61; Caucasian: 36 | 30 (6.2) | NR | NR | Any OSA: NR; Any OSAS (AHI ≥5 and ESS >10): 27^§^
Gurubhagav-atula, 2013^114^; United States | 250 | Cross-sectional | Fair | U.S. adults with HTN^ǁ^ from internal medicine practices and an HTN clinic | MVAP score; MVAP score + AHI from unattended HST | 53 (7.7) | 20 | African American: 59; Caucasian: 40 | 32 (7.4) | 22.5 (22.9) | 100 | Of the 79% who had in-lab PSG:; Any OSA: 80^¶^; OSAS: 25^#^
Edmonds, 2019^115^; United States | 43 | Cross-sectional | Fair | U.S. adults with DM2 from a general internal medicine clinic | STOP-BANG, BQ | NR | 53 | NR | 38 (7.7) | 31.2 (28.1) | NR | Mild (AHI 5–14): 28; Mod (AHI 15–29): 26; Severe (AHI ≥30): 37
Jorge, 2019^116^; Spain | 91 | Cross-sectional | Fair | Spanish adults with a recent diagnosis of mild to mod AD | Modified STOP-BANG^**^ | Median (IQR); 76 (73–80) | 64 | NR | Median (IQR); 28 (25.2 to 30.2) | 20.7 (10.6 to 40.3) | 57 | Mild (AHI: 5–14): 26.4; Mod (AHI 15–30): 25.3; Severe (AHI >30): 37.4
Shin, 2021^117^ | 1,033^††^ | Cross-sectional | Fair | Korean adults enrolled in a population-based cohort study | Modified STOP-BANG^‡‡^ | 59 (7.9) | 48 | Asian: 100 | 25 (3.0) | 7.3 (8, 9) | 38 | Mild (AHI 5–14): 32.4; Mod (AHI 15–29): 10.1; Severe (AHI ≥30): 3.1
Selvanathan, 2021^118,§§^ | 202/199^ǁǁ^ | Cross-sectional | Fair | Adults on opioids for chronic pain | STOP-BANG; STOP-BANG + resting daytime SpO_2_ | 53 (12.8) | 58 | NR | 29 (6.4) | Median (IQR); 6.5 (2.3 to 19.4) | 33 | NR

* The data in this row describe the 518 participants who underwent PSG. The 518 were a subset of the larger study population of 16,302 who completed the BQ. The mean age of the larger study population was 48 years, 53% were female, the mean BMI (SD) was 26 (4.3), and 14% had HTN.

† SD was not reported, but 25th and 75th percentiles were 1.7 and 18.3, respectively.

‡ From personal communication with Indira Gurubhagavatula (July 2015), 74% met their definition of daytime sleepiness (frequency of sleepiness, based on whether they had a problem staying awake, of every day or several [≥3] days per week); 32% had ESS >10.

§ Mild (AHI 5–15 and ESS >10): 9%; at least mod (AHI ≥15 and ESS >10): 17%; mod (AHI 15–30 and ESS >10): 8%; severe (AHI ≥30 and ESS >10): 8%.

ǁ Required to have BP ≥140/90 or to be on antihypertensive medications.

¶ Mild: 34%; mod: 22%; severe: 25%.

# At least mild (AHI ≥5 and ESS >10): 25%; severe (AHI ≥30 and ESS >10): 7.6%.

** Modified STOP-BANG (age older than 70 years, BMI >26 kg/m^2^; neck circumference >26.5 cm).

†† Validation sample only.

‡‡ Modified STOP-BANG (age 5–64 years 1 point, age ≥65 years 2 points; and waist circumference >85, snoring; observed apnea; high blood pressure; BMI >25 kg/m^2^, each 1 point).

§§ Although this is a 2-stage study, we only report the findings from the first stage in which all patients are included.

ǁǁ The n of 202 represents those who received the STOP-BANG and PSG; the n of 199 includes those who received the STOP-BANG, PSG, and resting daytime (SpO_2_).

Abbreviations: AD=Alzheimer’s disease; AHI=apnea-hypopnea index; BMI=body mass index; BP=blood pressure; BQ=Berlin Questionnaire; DM2=type 2 diabetes; ESS=Epworth Sleepiness Scale; F=female; HST=home sleep testing; HTN=hypertension; IQR=interquartile range; KQ=key question; mod=moderate; MVAP=Multivariable Apnea Prediction; N=sample size; NR=not reported; OSA=obstructive sleep apnea; OSAS=obstructive sleep apnea syndrome; PSG=polysomnography; SD=standard deviation; STOP-BANG=Snoring, Tiredness, Observed apnea, blood Pressure, Body mass index, Age, Neck circumference, Gender; U.S.=United States.

#### BQ

The BQ classifies risk of OSA as high or low by using three categories related to snoring, tiredness, and BP (at least two positive categories constitute high risk).^90^ In addition to the 10 questions, it also gathers information on age, sex, height, and weight. One of the two included studies evaluating the BQ randomly sampled Norwegians from the National Population Register to complete the Norwegian translation of the BQ (55% response rate).^112^ Of those completing the questionnaire, 24 percent were classified as high risk and 518 had received in-hospital PSG. Of the 518 included in the analysis, the mean age was 48 years, 45 percent were female, the mean BMI was 28 kg/m^2^, and the median AHI was 6.4. Although the group receiving PSG oversampled high-risk participants (70% were high risk), the authors’ analyses adjusted for bias in the sampling procedure to report estimated screening properties for the general population. In contrast, the second study^115^ included a small (n=43) but unselected sample of adults with DM2 recruited from a U.S. general internal medicine clinic. A majority (53%) were female, the mean BMI was 38.3 kg/m^2^, and the mean AHI was 31.2; the mean age of participants was not reported. All participants received PSG in laboratory. Neither study assessing the BQ described the race or ethnicity of enrolled participants.

The study enrolling Norwegians found suboptimal screening accuracy, as follows:^112^ for AHI ≥5: sensitivity was 37 percent and specificity was 84 percent; for AHI ≥15, sensitivity and specificity were 43 and 80 percent, respectively (Table 2). Of note, because it has implications for the validity of studies that oversample high-risk groups (and illustrates the impact of spectrum bias), the studies’ unadjusted analyses (reported only in online appendixes) show much higher sensitivity but lower specificity (for AHI ≥5: 79% and 41%, respectively; for AHI ≥15: 83% and 35%, respectively). The study enrolling participants with DM2 from a U.S. general medicine clinic assessed accuracy for mild (AHI 5–14), moderate (AHI 15-29), and severe OSA (AHI ≥30).^115^ Specificity of the BQ was suboptimal for all categories of OSA (mild: 0%; moderate: 31%; severe: 26%). Sensitivity was higher for moderate OSA (89%) and for severe OSA (93%) but was lower for mild OSA (80%). Positive likelihood ratios (PLRs) ranged from minimal to small in both studies (PLRs: 0.83 to 2.5), indicating that an abnormal result on the BQ—at best—minimally increased the likelihood of OSA. The negative likelihood ratios (NLRs) also ranged from minimal to small, indicating that a normal BQ only minimally decreased the likelihood of OSA (NLRs: 0.24 to 0.8).

Table 2 Results of Included Studies Assessing the Accuracy of Clinical Prediction Tools or Screening Questionnaires (KQ 2)

First Author, Year | Cutoff Value of Screening Questionnaire(s)/Tool(s) | Reference Standard Definition of OSA Diagnosis | Sensitivity (95% CI) | Specificity (95% CI) | AUROC (95% CI) | Calibration | Other Accuracy Measures (95% CI)
Hrubos-Strom, 2011^112^ | BQ ≥2 positive categories | AHI ≥5^*^ | 37.2 (36.0 to 38.4) | 84.0 (83.2 to 84.7) | NR | NR | PPV=61.3 (59.7 to 62.9); NPV=66.2 (65.3 to 67.1); PLR=2.3 (2.2 to 2.5); NLR=0.8 (0.7 to 0.8)
Hrubos-Strom, 2011^112^ | BQ ≥2 positive categories | AHI ≥15^*^ | 43.0 (41.2 to 44.8) | 79.7 (79.0 to 80.5) | NR | NR | PPV=33.5 (32.0 to 35.0); NPV=85.5 (84.8 to 86.1); PLR=2.1 (2.0 to 2.3); NLR=0.7 (0.7 to 0.7)
Morales, 2012^113^ | MVAP=0.49 | Severe OSAS (AHI ≥30 and ESS >10) | 90.0 (NR) | 64.4 (NR) | 0.78 (0.71 to 0.85) | NR | NLR=0.141 (NR); NPTP=1.1% (NR)
Morales, 2012^113^ | MVAP+HST^†^=uAHI 15 | Severe OSAS (AHI ≥30 and ESS >10) | 90.9 (NR) | 75.7 (NR) | 0.83 (0.77 to 0.90) | NR | NLR=0.120 (NR); NPTP=1.0% (NR)
Gurubhagavatula, 2013^114^ | MVAP=0.483 | Severe OSAS (AHI ≥30 and ESS >10) | 91.5 (NR) | 43.9 (NR) | 0.68 (0.67 to 0.70) | NR | NLR=0.190 (NR); NPTP=0.015 (NR)
Gurubhagavatula, 2013^114^ | MVAP=0.559 | Any OSAS (AHI ≥5 and ESS >10) | 69.4 (NR) | 56.5 (NR) | 0.61 (NR) | NR | NLR=0.524 (NR); NPTP=0.148 (NR)
Gurubhagavatula, 2013^114^ | MVAP+HST^†^=uAHI 18 | Severe OSAS (AHI ≥30 and ESS >10) | 88.2 (NR) | 71.6 (NR) | 0.80 (0.78 to 0.82) | NR | NLR=0.162 (NR); NPTP=0.015 (NR)
Gurubhagavatula, 2013^114^ | MVAP+HST^†^=uAHI 13.5 | Any OSAS (AHI ≥5 and ESS >10) | 80.5 (NR) | 54.0 (NR) | 0.67 (NR) | NR | NLR=0.349 (NR); NPTP=0.104 (NR)
Edmonds, 2019^115^ | STOP-BANG ≥3 | Mild (AHI 5–14) | 87.2 (NR) | 0 | NR | NR | PPV=89.5 (NR); NPV=0 (NR)
Edmonds, 2019^115^ | STOP-BANG ≥3 | Mod (AHI 15–29) | 92.6 (NR) | 18.8 (NR) | NR | NR | PPV=65.8 (NR); NPV=60 (NR)
Edmonds, 2019^115^ | STOP-BANG ≥3 | Severe (AHI ≥30) | 93.8 (NR) | 14.8 (NR) | NR | NR | PPV=39.5 (NR); NPV=80 (NR)
Edmonds, 2019^115^ | BQ ≥2 positive categories | Mild (AHI 5–14) | 79.5 (NR) | 0 (NR) | NR | NR | PPV=88.6 (NR); NPV=0 (NR)
Edmonds, 2019^115^ | BQ ≥2 positive categories | Mod (AHI 15–29) | 88.9 (NR) | 31.3 (NR) | NR | NR | PPV=68.6 (NR); NPV=62.5 (NR)
Edmonds, 2019^115^ | BQ ≥2 positive categories | Severe (AHI ≥30) | 93.8 (NR) | 25.9 (NR) | NR | NR | PPV=42.9 (NR); NPV=87.5 (NR)
Jorge, 2019^116^ | Modified STOP-BANG (age older than 70 years; BMI >26 kg/m^2^; neck circumference >26.5 cm) ≥2 positive categories | Severe (AHI >30) | 61 (47 to 74) | 76 (59 to 89) | 0.72 (0.61 to 0.83) | NR | PPV=81 (66 to 91); NPV=54 (39 to 69)
Shin, 2021^117^ | Modified STOP-BANG ≥3 (snoring; observed apnea; high blood pressure; BMI >25 kg/m^2^; age 5–64 years 1 point, ≥65 years 2 points; waist circumference >85 cm; diabetes; male) | All (AHI ≥5) | 62.3 (60.5 to 64.2) | 64.5 (62.9 to 66) | 0.73 (0.70 to 0.76) | NR | PPV=64 (63.4 to 64.4); NPV=71.8 (71.1 to 72.5)
Shin, 2021^117^ | Modified STOP-BANG ≥3 (snoring; observed apnea; high blood pressure; BMI >25 kg/m; age 5–64 years 1 point, ≥65 years 2 points; waist circumference >85 cm; diabetes; male) | Mild to moderate (5 < AHI <30) | 62.0 (60.1 to 63.9) | 63.8 (62.2 to 65.4) | 0.72 (0.69 to 0.75) | NR | PPV=61.6 (61.0 to 62.3); NPV=72.6 (71.9 to 73.3)
Shin, 2021^117^ | Modified STOP-BANG ≥3 (snoring; observed apnea; high blood pressure; BMI >25 kg/m^2^; age 5–64 years 1 point, ≥65 years 2 points; waist circumference >85 cm; diabetes; male) | Severe (AHI ≥30) | 79.1 (77.3 to 80.9) | 53.3 (51.6 to 54.9) | 0.78 (0.72 to 0.84) | NR | PPV=6.03 (6.89 to 6.17); NPV=99.2 (99.1 to 99.2)
Selvanathan, 2021^118^ | STOP-BANG ≥3^ǂ^ | Moderate to Severe (AHI ≥15) | 89.2 (80.1 to 95.0) | 38.0 (33.6 to 40.7) | NR | NR | NR
Selvanathan, 2021^118^ | STOP-BANG ≥3 or resting daytime SpO_2_ ≤95%^ǂ^ | All (AHI ≥5) | 92.9 (87.8 to 96.0) | 31.6 (24.5 to 37.0) | NR | NR | PPV=67.3 (63.9 to 69.8); NPV=73.5 (57.0 to 86.0); PLR=1.4 (1.2 to 1.5); NLR=0.2 (0.1 to 0.5)
Selvanathan, 2021^118^ | STOP-BANG ≥3 or resting daytime SpO_2_ ≤95%^ǂ^ | Moderate to severe (AHI ≥15) | 95.4 (87.7 to 98.8) | 23.1 (19.4 to 24.8) | NR | NR | PPV=37.6 (34.6 to 38.9); NPV=91.2 (76.5 to 97.7); PLR=1.24 (1.0 to 1.3); NLR=0.2 (0.05 to 0.6)
Selvanathan, 2021^118^ | STOP-BANG ≥3 or resting daytime SpO_2_ ≤95%^ǂ^ | Severe (AHI ≥30) | 100 (89.4 to 100) | 21.0 (18.6 to 21.0) | NR | NR | PPV=22.4 (20.0 to 22.4); NPV=100 (88.4 to 100); PLR=1.3 (1.1 to 1.3); NLR=infinity

* Estimates were based on a simulated model that adjusted for oversampling of BQ high-risk participants (not just based on findings for the 518 in the clinical sample).

† 2-stage process using MVAP for everyone, and then unattended HST to estimate AHI for those with an intermediate MVAP score.

ǂ Although this is a two-stage study, we only report the findings from the first stage in which all patients were included.

Abbreviations: AHI=apnea-hypopnea index; AUROC=area under the receiver operating characteristic curve; BMI=body mass index; BQ=Berlin Questionnaire; CI=confidence interval; ESS=Epworth Sleepiness Scale; HST=home sleep testing; KQ=key question; mod=moderate; MVAP=Multivariable Apnea Prediction; NLR=negative likelihood ratio; NPTP=negative post-test probability; NPV=negative predictive value; NR=not reported; OSA=obstructive sleep apnea; OSAS=obstructive sleep apnea syndrome; PLR=positive likelihood ratio; PPV=positive predictive value; STOP-BANG=Snoring, Tiredness, Observed apnea, blood Pressure, Body mass index, Age, Neck circumference, Gender; uAHI=unattended AHI from home sleep test; vs.=versus.

#### STOP-BANG Questionnaire

The STOP-BANG Questionnaire includes the following eight dichotomous items: snoring, tiredness, observed apnea, high BP, BMI, age, neck circumference, and gender (male).^88,^ ^119^ A score of less than 3 is considered low risk for OSA; a score of 3 or more represents moderate to high risk for OSA. Four studies assessed the accuracy of the STOP-BANG among diverse populations and used different scoring criteria as well as additional variables to determine a positive screen (Table 1).^115–118^

One study enrolled a small sample of adults (n=43) with DM2 recruited from a U.S. general internal medicine clinic.^115^ A majority (53%) were female, the mean BMI was 38 kg/m^2^, and the mean AHI was 31. All participants received PSG in a laboratory. This study used the established cut point for a positive test (3 or greater). A second study (n=91) enrolled participants with a recent diagnosis of mild to moderate Alzheimer’s disease (AD) who were enrolled in a Spanish cohort study comparing cognitive progression among participants with OSA with those without OSA.^116^ The median age was 76 years, 64 percent were female, the median BMI was 28 kg/m^2^, the mean AHI was 21, and 57 percent had high BP. This study optimized the cutoffs for each item in the STOP-BANG and revised the criteria for a positive item for age (older than 70 years vs. older than 50 years), for BMI (>26 kg/m^2^ vs. >35 kg/m^2^), and for neck circumference (>26.5 cm vs. >40 cm), resulting in a modified STOP-BANG score.^116^ A third study included Korean adults (n=1,033) who were part of a large, multiyear population-based cohort study. The mean age was 59 years, 48 percent were female, the mean BMI was 25 kg/m^2^, and the mean AHI was 7.^117^ In this study, the STOP-BANG was modified; sleepiness and neck circumference were eliminated, waist circumference and diabetes were included, and age had three cut points. The investigators developed the modified score based on an exploratory sample (n=1,032) and examined accuracy in a validated sample of 1,033. A fourth study (n=199) included adults on opioids for chronic pain in a two-stage study.^118^ Participants in the first stage of the study had a mean age of 52 years, were 58 percent female, had a mean BMI of 29 kg/m^2^, and a median AHI of 6. In the first stage, the threshold for risk of OSA was either a STOP-BANG score greater than 3 or a resting daytime oxyhemoglobin saturation (SpO_2_) of [underlined: less than] 95 percent. In the second stage, the 159 participants who met the threshold for risk received overnight oximetry at home, and those whose oxygen desaturation index was 5 or more were classified as at risk. No demographic data were provided for this subsample of 159 individuals. Because only a portion of the sample was included for the second stage, we did not include these accuracy data.

The study enrolling U.S. adults with DM2 found good sensitivity for detecting mild, moderate, and severe OSA (87%, 93%, and 94%, respectively), but very low specificity for the same subgroups (0%, 19%, and 15%, respectively) (Table 2).^115^ In contrast, the study enrolling Spanish adults with AD found modest sensitivity and somewhat better specificity for severe OSA (61% and 76%, respectively).^116^ PLRs and NLRs were minimal to small in both studies, indicating neither that a positive score on the STOP-BANG increased the risk of OSA nor that a normal score on the STOP-BANG decreased the risk of OSA. The study from Korea that included a general population of adults found moderate sensitivity and specificity for detecting all mild to moderate and severe OSA.^117^ The study that included adults receiving opioids for chronic pain provided accuracy data for the STOP-BANG alone as well as accuracy for the STOP-BANG plus resting daytime SpO_2_ (first stage). Sensitivity for the STOP-BANG to detect moderate to severe OSA was very good, but specificity was limited. Similarly, accuracy findings for the combination STOP-BANG plus resting daytime SpO_2_ indicated excellent sensitivity but low specificity for all OSA as well as for moderate to severe and severe OSA. The NLRs for detecting all degrees of OSA and moderate to severe OSA were moderate (NLRs: 0.2), indicating that a normal screening modestly decreased the likelihood of any or moderate to severe OSA (NLRs: 0.2); the NLR for detecting severe OSA was large (NLR: infinity), indicating that a normal first-stage screening greatly decreased the likelihood of severe OSA.

#### MVAP Score

The MVAP score combines symptoms of snoring, choking, and witnessed apnea events with BMI, age, and sex.^120^ It rates apnea risk between 0 and 1, with 0 representing the lowest risk and 1 representing the highest risk. Both included studies assessing the MVAP were conducted by the same research group from Philadelphia.^113,^ ^114^ One study evaluated Medicare recipients (n=452) from the city’s greater metropolitan area, most of whom (74%) had daytime sleepiness.^113^ The percentage with OSA was not reported, but 27 percent had OSA syndrome (OSAS), defined as the presence of OSA and excessive daytime sleepiness (AHI ≥5 and ESS >10). The second study evaluated patients with HTN from internal medicine practices at a Veterans Affairs Medical Center and a university-based HTN clinic (n=250).^114^ Eighty percent of participants had OSA (AHI ≥5); of those, 22 percent had moderate OSA and 25 percent had severe OSA. Twenty-five percent of all participants had OSAS. The mean ages of participants were 71^113^ and 53 years,^114^ 60 to 64 percent were non-White, and the mean BMIs were 30 to 32 kg/m^2^. The study of Medicare recipients included 70 percent women;^113^ the other study included 20 percent women.^114^ Key quality limitations included concern for attrition bias^114^ and moderate concern for selection bias or spectrum bias (with high prevalence of OSA, OSAS, and/or sleepiness among those receiving PSG; Appendix D).^113,^ ^114^

Both studies reported operating characteristics of MVAP to predict severe OSAS (AHI ≥30 and ESS >10) using MVAP cutoff scores of 0.48 to 0.49 (Table 2). Sensitivity was 90^113^ and 92 percent,^114^ with specificity of 64 and 44 percent, respectively (95% CIs not reported). The study of Medicare recipients reported reasonable discrimination (area under the curve [AUC], 0.78 [95% CI, 0.71 to 0.85]), whereas the other study found inadequate discrimination (AUC, 0.68 [95% CI, 0.67 to 0.70]). An AUC of less than 0.70 is thought to indicate inadequate discrimination.^121,^ ^122^ Calibration, which is often assessed by plotting the predicted risk versus the observed rate,^121^ was not reported.

The study of patients with HTN also reported operating characteristics of MVAP to predict any OSAS (AHI ≥5 and ESS >10) using an MVAP cutoff score of 0.559. This study reported a sensitivity of 69.4 percent, a specificity of 56.5 percent, and an AUC of 0.614.^114^

#### MVAP Score Followed by HST

The same two studies described in the previous section also reported measures of discrimination for the MVAP score followed by unattended HST compared with in-laboratory PSG (Table 1).^113,^ ^114^ Both reported characteristics to predict severe OSAS (AHI ≥30 and ESS >10) using different HST AHI cutoffs: one used 15^113^ and the other used 18.^114^ Both studies found better operating characteristics with MVAP followed by an HST than with MVAP alone (sensitivity, 88% to 91%; specificity, 72% to 76%; AUC, 0.799 to 0.833).

The study of patients with HTN also reported operating characteristics of MVAP to predict any OSAS (AHI ≥5 and ESS >10) using an HST AHI cutoff of 13.5. It reported a sensitivity of 81 percent, a specificity of 54 percent, and an AUC of 0.672.

### KQ 3 What Are the Harms Associated With Screening or Subsequent Diagnostic Testing for OSA, Including for Specific Subgroups of Interest?

We found no eligible study that addressed this question.

### KQ 4 How Effective Is Treatment With PAP or MADs for Improving Intermediate Outcomes (i.e., AHI or Blood Pressure) in Persons With OSA, Including for Specific Subgroups of Interest?

We included four SRs of good quality comparing the intermediate outcomes of treatment with PAP or MAD (e.g., AHI, BP) versus those of control (Appendix E Table 1).^123–126^ One limited inclusion to studies with oral appliances compared with an inactive control for improving BP outcomes and included 11 RCTs (based on searches of studies conducted through 2016); across all studies, follow-up duration ranged from 2 weeks to 4.65 years.^123^ Two SRs limited to studies comparing PAP with an inactive control that reported on AHI and BP outcomes.^125,^ ^126^ One limited inclusion to RCTs enrolling participants diagnosed with minimally symptomatic, asymptomatic, or nonsleepy OSA only and included fewer trials reporting on BP outcomes (k=7; 1,541 participants) than the second review, which had no limits on population criteria related to OSA severity and symptoms (k=23; 4,905 participants). One review was limited to populations with OSA and resistant hypertension (k=8; 606 participants).^124^ Characteristics of studies included in each review (age, gender, BMI, and proportion of participants treated for HTN) are shown in Appendix E Table 1. Some reviews included a broader range of outcomes and trials and did not report characteristics separately for the subgroup of studies reporting on AHI or BP. All provided pooled estimates of AHI or BP outcomes, and all noted a high level of heterogeneity across trials in terms of duration, sample size, and population characteristics.

#### BP

##### MAD

One review found benefits associated with MAD compared to inactive control for improving BP; however, differences between groups were imprecise and not statistically significant.^123^ Pooled estimates of mean change from baseline daytime systolic BP (SBP) among MAD versus control was −1.55 (95% CI, −4.65 to 4.25; 5 trials, 469 participants; I^2^=0%), and −1.14 (95% CI, −2.78 to 3.38; 5 trials, 469 participants; I^2^=0%) for daytime diastolic BP (DBP). Estimates for 24-hour BP were similar (Appendix E Table 1).

##### PAP

In the review limited to minimally symptomatic, asymptomatic, or nonsleepy populations, pooled data from five studies (1,541 participants) comparing CPAP to control demonstrated a small reduction in daytime DBP (−0.92 mm Hg [95% CI, −1.39 to −0.46]; I^2^=0) and no significant difference between groups in daytime SBP (−0.51 mm Hg [95% CI, −3.39 to 2.38]; I^2^=84%).^126^ The second review of PAP included trials of any OSA severity and symptoms, and was conducted to support the AASM practice guidelines.^125^ The scope of the review was broader than that of the outcomes related to AHI and BP. The task force for this review developed a clinical significance threshold between 1 and 2 mm Hg for BP change based on other commonly used thresholds in the literature, consensus after accounting for literature review, and clinical judgment.^125^ Pooled analyses showed that PAP was associated with a reduction in a mean 24-hour BP of −2.63 mm Hg (95% CI, −3.86 to −1.39; 8 trials, 994 participants; I^2^=0%). Pooled estimates for change in daytime SBP and DBP between groups were also significantly lower among PAP versus among control groups, ranging from −2.76 mm Hg to −1.98 mm Hg, respectively (Appendix E Table 1).

Two reviews focused on the effect of PAP in populations with hypertension and OSA. One review of PAP was limited to studies enrolling participants with resistant hypertension (k=23; 4,905 participants) as defined by the American Heart Association: uncontrolled range of BP despite the use of three antihypertensive medications, including a diuretic drug at the optimal dose, or controlled BP despite the use of four or more antihypertensive medications. Pooled analysis showed a reduction in mean 24-hour systolic BP (−5.06 mm Hg [95% CI −7.98 to 2.13]; I^2^=84%) and mean 24-hour diastolic BP (−4.21 mm Hg [95% CI −6.50 to −1.93]; I^2^=81%). PAP was also associated with reductions in mean nighttime systolic and diastolic BP but not daytime systolic and diastolic BP (Appendix E Table 1).^124^ The review for the AASM also reported on estimates among groups based on hypertensive status and severity; however, fewer studies were included in pooled estimates than the review described above. Estimates were similar in magnitude for participants with treatment-resistant HTN and for those who had received treatment for HTN (Appendix E Table 1). Pooled estimates from four trials (409 participants) with treatment-resistant HTN, defined as requiring three or more antihypertensive medications, demonstrated that PAP was associated with a reduction in a mean 24-hour BP of −2.06 mm Hg (95% CI, −4.12 to −0.00 mm Hg). Similarly, pooled estimates from four trials (627 participants) with treated HTN demonstrated a reduction in mean 24-hour BP of −2.16 mm Hg (95% CI, −3.59 to −0.72 mm Hg).^125^

#### AHI

Two reviews reported on the difference between groups in change from baseline AHI, and both reviews focused on PAP.^125,^ ^126^ The 2016 review to support the AASM practice guidelines found a greater reduction in AHI associated with PAP than with controls (pooled mean difference: −23.41 events per hour [95% CI, −28.51 to −18.30]; 11 trials, 832 participants).^125^ The second review—which limited inclusion to studies of asymptomatic adults with OSA or those of minimally symptomatic, nonsleepy adults—included fewer studies (3 trials, 1,541 participants) and found a pooled mean difference of −15.57 events per hour (95% CI, −29.32 to −1.82).^126^ Despite a difference in scope and in the number of included trials, the pooled estimates in AHI reduction favoring PAP were generally consistent. Both estimates were associated with heterogeneity (Appendix E Table 1). The review limited to asymptomatic, nonsleepy populations attributed heterogeneity to the results of a single study.^126,^ ^127^

### KQ 5 How Effective Is Treatment With PAP or MADs for Improving Health Outcomes in Persons With OSA, Including for Specific Subgroups of Interest?

We included 73 good- or fair-quality RCTs (reported in 87 articles) that reported at least one eligible health outcome. Characteristics and results are summarized in this section and are organized by treatment type.

#### PAP

Sixty-three RCTs (reported in 74 articles) comparing PAP with sham PAP (29 RCTs, 33 articles)^127–159^ or another inactive control (34 RCTs, 41 articles)^160–200^ reported at least one eligible health outcome. Most trials identified participants from sleep clinics or referrals, and none focused on persons who were screen detected in primary care settings. The majority of trials were conducted in a single country, including the United States (k=13),^130,^ ^131,^ ^135,^ ^141,^ ^144,^ ^145,^ ^149,^ ^150,^ ^173,^ ^178,^ ^189,^ ^194,^ ^196^ Spain (k=16),^127–129,^ ^133,^ ^134,^ ^148,^ ^160,^ ^162,^ ^163,^ ^165,^ ^167,^ ^180–182,^ ^188,^ ^192^ the United Kingdom (k=15),^132,^ ^138,^ ^140,^ ^151,^ ^154–156,^ ^158,^ ^168–172,^ ^183,^ ^184,^ ^195^ Australia (k=5),^136,^ ^147,^ ^153,^ ^164,^ ^175^ Hong Kong (k=4),^137,^ ^177,^ ^179,^ ^197^ and one each in Canada,^190^ Denmark,^161^ Norway,^199^ and New Zealand.^146^ Three trials enrolled participants from multiple country settings: one from Australia and North America,^193^ one from the United Kingdom and Canada,^166^ and one from the United States and Canada.^157^

Most trials (k=53) followed participants for 12 weeks or less; 10 trials followed participants over a longer duration, including 16 to 24 weeks (k=5)^141,^ ^166,^ ^175,^ ^193,^ ^199^ 52 weeks (k=3);^162,^ ^184,^ ^196^ one did so for a median of 4 years;^163^ and one for a median of 4.7 years.^185^ The mean age of enrolled populations ranged from 44 to 78 years, and most trials enrolled populations with a mean age of 40 to 59 years; seven enrolled populations with a mean age of 65 years or older.^131,^ ^149,^ ^167,^ ^181,^ ^184,^ ^185,^ ^188^ The vast majority of participants in most trials were males, with females comprising up to one-third of the enrolled population in 38 trials; one trial limited enrollment to females,^165^ and three enrolled a majority of females.^192,^ ^197,^ ^201^ Most trials did not describe race or ethnicity of enrolled populations, and those that did (k=14) used heterogeneous categories and varying levels of detail (Appendix E Tables 2 and 3). Five trials reported only on the proportion who were non-Caucasian, non-White, or non-European American (range: 5% to 40%).^131,^ ^141,^ ^150,^ ^189,^ ^195^ One trial enrolled a majority of participants who were Black or biracial (52%),^130^ seven trials enrolled fewer Black or African American participants (range: 5% to 20%),^135,^ ^144,^ ^157,^ ^173,^ ^193,^ ^194,^ ^196^ and five trials enrolled some Asian participants (range: 2% to 8%).^135,^ ^173,^ ^184,^ ^193,^ ^194^ Few trials reported on other categories of race or ethnicity. The mean BMI was 30 to 36 kg/m^2^ in most trials (range: 25–47 kg/m^2^). Two trials that enrolled participants with a mean BMI greater than 40 both limited participation to populations with OSA and obesity.^182,^ ^192^ The mean or median baseline AHI (or similar measure) was in the severe OSA range (AHI ≥30) for most trials; 13 trials reported mean baseline AHI in the moderate OSA range (AHI 16 to 30),^131,^ ^146,^ ^149,^ ^154,^ ^164,^ ^168,^ ^177,^ ^184,^ ^185,^ ^193,^ ^196,^ ^197,^ ^199^ and six reported mean baseline AHI in the mild OSA range (AH1 5 to 15).^157,^ ^166,^ ^169,^ ^171,^ ^189,^ ^195^ The severity of OSA for participants enrolled in trials most frequently ranged from moderate to severe (k=29) or from mild to severe (k=16). Seventeen trials limited participants to more narrow ranges: mild only,^171,^ ^195^ mild to moderate or moderate only,^146,^ ^157,^ ^164,^ ^185,^ ^188,^ ^189,^ ^193^ or severe only.^127,^ ^147,^ ^167,^ ^179–182,^ ^192^ One trial did not report sufficient data to determine the range of OSA severity of participants.^166^ Mean or median baseline ESS was 10 or greater in most trials, indicating EDS. Eighteen trials reported a mean baseline ESS of less than 10,^127,^ ^131,^ ^134,^ ^154,^ ^161–163,^ ^166,^ ^167,^ ^173,^ ^175,^ ^180,^ ^185,^ ^188,^ ^192,^ ^196,^ ^197,^ ^199^ and six trials did not report a baseline ESS.

##### Mortality

Thirty-one RCTs reported on mortality (Appendix E Table 4). The vast majority (28 RCTs) reported mortality rates at 12 weeks or less, and most of these (25 RCTs) reported no death in any study group;^127,^ ^128,^ ^133,^ ^135,^ ^138,^ ^144,^ ^146,^ ^148–150,^ ^154–157,^ ^160,^ ^164,^ ^168–173,^ ^177,^ ^189,^ ^190^ three trials (536 total participants) reported one death, either in the PAP^166^ or sham PAP group^134,^ ^161^ at 12 weeks. Three RCTs assessed mortality over a longer duration, and none found a statistically significant difference between groups. One (n=1,105) reported two deaths in each study arm over 24 weeks.^141^ Two reported on mortality over a median duration of 4 to 5 years; one (n=723) reported eight deaths in the PAP group and three in the control group (incidence density ratio, 2.6 [95% CI, 0.70 to 11.8]; p=0.16),^163^ and the second (n=364) found a similar number of deaths among the PAP and control groups (8% vs. 7%, respectively).^185^

##### General Health-Related QOL

Twenty-eight RCTs reported one or more measures of general health–related QOL. Twenty measured QOL using the Medical Outcome Short-Form (36-Item) Health Survey (SF-36).^127,^ ^134,^ ^138,^ ^147,^ ^148,^ ^155–157,^ ^164,^ ^166,^ ^171,^ ^174,^ ^177,^ ^182,^ ^184,^ ^193,^ ^195,^ ^196,^ ^199,^ ^200^ Most trials reported changes on the SF-36 physical component summary score (PCS) and the mental component summary score (MCS). Pooled analyzes in change from baseline SF-36 MCS found a statistically significantly greater improvement among the PAP group than among the control group (2.20 [95% CI, 0.95 to 3.44]; 15 trials, 2,345 participants).^127,^ ^134,^ ^138,^ ^148,^ ^155–157,^ ^166,^ ^174,^ ^182,^ ^193,^ ^195,^ ^196,^ ^199,^ ^200^ Similarly, pooled analyses for change in SF-36 PCS from baseline found significantly greater improvement among the PAP group than among the control group (1.53 [95% CI, 0.29 to 2.77]; 13 trials, 2,031 participants) (Table 3 and Appendix F Figure 1).^127,^ ^134,^ ^138,^ ^148,^ ^155–157,^ ^174,^ ^182,^ ^195,^ ^196,^ ^199,^ ^200^ The pooled estimates for change from baseline SF-36 MCS and SF-36 PCS associated with PAP were smaller than the range considered a minimal clinically important difference (MCID), which is 4 to 7 for both SF-36 component summary scores.^202,^ ^203^ Two RCTs reporting on changes in total SF-36 scores at 12 weeks found inconsistent results; one (n=61) reported no difference between groups (but did not provide numerical data),^147^ and one (n=179) found significantly greater improvement among the PAP group than among the control groups (mean change from baseline, 4.7 vs. 2.0; p<0.05).^164^

Table 3 Summary of Pooled Findings from PAP Treatment Studies

Outcome Measure | Number of Trials | Number of Participants | Effect Size (95% CI) | I^2^ | Estimated MCID
ESS | 47 | 7,024 | MD: −2.33 (−2.75 to −1.90) | 88 | −2 to −3^204,^ ^205^
SF-36 PCS | 13 | 2,031 | MD: 1.53 (0.29 to 2.77) | 59 | 4 to 7^202,^ ^203^
SF-36 MCS | 15 | 2,345 | MD: 2.20 (0.95 to 3.44) | 64 | 4 to 7
Sleep-related QOL: all measures | 17 | 3,083 | SMD: 0.30 (0.19 to 0.42) | 55 | NA^*^
Sleep-related QOL: FOSQ only | 10 | 1,425 | MD: 0.55 (0.05 to 1.06) | 70 | 1.8 to 2.2^252^
Sleep-related QOL: SAQLI only | 6 | 1,725 | MD: 0.40 (0.17 to 0.62) | 81 | 1 to 2^253^

* A SMD between 0.2 and 0.4 is considered a small effect size.

Abbreviations: ESS: Epworth Sleepiness Scale; MCID: minimal clinically important difference; MCS=mental component summary score; mod=moderate; MD: mean difference; MVA=motor vehicle accident; PAP=positive airway pressure; PCS=physical component summary score; QOL=quality of life; SAQLI=Sleep Apnea Quality of Life Index; SF-36=Medical Outcome Short-Form (36-Item) Health Survey; SMD=standardized mean difference.

Eight RCTs measured general QOL using another tool, including the Nottingham Health Profile (k=4),^168–171^ the EuroQol (k=3),^133,^ ^166,^ ^195^ and the SF-12 (k=1)^165^ (Appendix E Table 4). Overall, results were mixed. For the Nottingham Health Profile, three trials found no difference between groups in the change from baseline overall scores,^169–171^ and one reported greater improvement in the PAP group compared with the control groups (4.9 vs. 7.9 [lower scores indicate greater improvement]; p=0.002).^168^ In the three trials reporting on the EuroQol, two found no difference between groups in change from baseline score over 12 to 24 weeks,^166,^ ^195^ and one (n=340) only reported within-group changes; the PAP group improved at 12 weeks compared with baseline (p<0.001; effect size [standard deviation units], 0.38), but no improvement was seen in the control group.^133^ Finally, one trial (n=307) reporting on changes in SF-12 at 12 weeks found a significantly greater improvement on the PCS among the PAP group versus the control group, but no difference on the MCS score.^165^

##### Sleep-Related QOL

Seventeen RCTs assessed sleep-related QOL—6 using the Sleep Apnea Quality of Life Index (SAQLI),^142,^ ^155,^ ^158,^ ^166,^ ^177,^ ^184^ 10 using the Functional Outcomes of Sleep Questionnaire (FOSQ),^127,^ ^146,^ ^148,^ ^153,^ ^157,^ ^164,^ ^172,^ ^182,^ ^195,^ ^199^ and 1 using the Quebec Sleep Questionnaire.^167^ Our meta-analysis (combining all measures) found that PAP was associated with a small but statistically significant improvement in sleep-related QOL compared with controls (SMD, 0.30 [95% CI, 0.19 to 0.42]; 17 trials, 3,083 participants) (Appendix F Figure 2). Our subgroup analysis by mean baseline ESS found a similar but slightly larger effect size in trials with a mean ESS of 10 or greater (SMD, 0.35 [95% CI, 0.22 to 0.49]; 11 trials, 2,228 participants); in studies with a mean baseline ESS less than 10, the effect size was smaller and the pooled estimate was not statistically significant (Appendix F Figure 4). Results shown as a mean difference in scores for each sleep-related QOL measure are provided in Appendix F Figure 3 and summarized in Table 3. For both measures, the pooled mean difference falls below the range considered an MCID.

##### Cognitive Impairment

Fourteen RCTs reported one or more measures of cognitive function.^127,^ ^141,^ ^144,^ ^146,^ ^164,^ ^167–171,^ ^178,^ ^181,^ ^184,^ ^188^ No study reported on a global measure of cognition. Common measures included neurocognitive measures of verbal learning and memory, alertness, and reaction time. In general, studies assessed cognitive function using heterogeneous outcome measures and reported inconsistent results (Appendix E Table 4).

##### Motor Vehicle Accidents

Three RCTs reported on the incidence of motor vehicle accidents (MVAs), and none found a statistically significant difference between groups (Appendix E Table 4).^141,^ ^173,^ ^184^ One trial (n=212) found no MVA at 12 weeks,^173^ and two found similar rates among PAP and comparator groups at 24 weeks (10 vs. 11 MVAs out of 1,105 participants)^141^ and 1 year (2 vs. 1 MVAs out of 278 participants).^184^

##### CV Events

Ten RCTs reported on the incidence of one or more CV events (Appendix E Table 4).^134,^ ^141,^ ^146,^ ^158,^ ^163,^ ^166,^ ^173,^ ^184,^ ^185,^ ^199^ Trials reported on heterogeneous categories of CV outcomes. Six trials (1,773 total participants) reported on the incidence of myocardial infarction (MI). In four of the six trials, a total of one MI occurred (combined) in either group (the control group) over 3 weeks to 1 year.^146,^ ^166,^ ^173,^ ^184^ Two trials reported on outcomes over a median of 4 to 5 years; one (n=723) reported two MIs in the PAP group and eight in the control group,^163^ and the second (n=244) found a similar number of MIs in the PAP and control groups (9% vs. 7%, respectively).^185^

Five RCTs reported on the incidence of various other CV events (angina, unstable angina, and atrial fibrillation, pacemaker implantation due to syncope and prolonged pauses); trial durations were 12 weeks,^134,^ ^173^ 24 weeks,^166,^ ^199^ and 1 year.^184^ Overall, too few events occurred to draw conclusions. Across four trials reporting on angina or unstable angina (570 total participants), four versus nine angina events occurred among the PAP versus comparator groups, respectively.^134,^ ^166,^ ^173,^ ^184^ For atrial fibrillation (k=3), one trial (n=212) reported a single case of incident atrial fibrillation at 12 weeks (randomized to the control group);^173^ and in two trials assessing outcomes at 6 months and 1 year (669 total participants), there was no difference in the incidence of atrial fibrillation between the PAP and control groups (12 vs. 19 events).^166,^ ^184^ One trial limited to participants with atrial fibrillation (n=104) reported two cases of pacemaker implantation due to syncope or prolonged pauses among participants randomized to PAP over 24 weeks.^199^

One RCT reported one event in either group for each of the following events (Appendix E Table 4): incident heart failure,^163^ unspecified tachyarrhythmia requiring hospitalization,^173^ percutaneous coronary intervention for worsening angina,^173^ and emergent cardiac surgery.^158^

One trial reported only an overall number of CV events (as adverse events) without describing how outcomes were measured or defined (31 vs. 29 events in PAP and control arms, respectively).^141^ One trial reported hospitalizations for unstable angina or arrhythmia (17 vs. 11 in the PAP and control arms, respectively; 723 total participants).^163^

##### Cerebrovascular Events

Eight trials reported on the incidence of transient ischemic attacks^163,^ ^166,^ ^184^ and/or strokes.^163,^ ^166,^ ^173,^ ^184,^ ^185,^ ^195,^ ^196,^ ^199^ Overall, too few events were observed to draw conclusions. In four studies measuring outcomes at 1 year or less, three found zero or one event in each group for transient ischemic attacks and strokes,^166,^ ^173,^ ^184,^ ^195^ and one reported two events in each arm^196^ (Appendix E Table 4). Two trials measured outcomes over a median of 4 to 5 years.^163,^ ^185^ Both reported fewer events in the PAP group versus the control group; however, overall event rates were low and differences between groups was less than three events per group and were not statistically significant.

##### Headaches

In one RCT (n=37), three participants in the control group developed headaches at 4 weeks compared with none in the PAP group.^171^

##### ESS

Forty-seven RCTs reported sufficient ESS data to include in meta-analyses. Most were 12 weeks or less in duration; seven followed participants for 24 weeks,^141,^ ^193,^ ^199^ 48 to 52 weeks,^162,^ ^184,^ ^196^ or longer.^163^ Our meta-analyses found that PAP reduced mean ESS scores more than controls (pooled mean difference: −2.33 [95% CI, −2.75 to −1.90]; 47 trials, 7,024 participants) (Figure 3). The pooled mean difference is within the range considered an MCID for the ESS (−2 to −3).^204,^ ^205^ Our analyses found substantial statistical heterogeneity that may be due to variation in PAP devices, participant characteristics (e.g., baseline ESS), treatment adherence, study duration, or chance; however, we were unable to find a clear explanation. As shown in Figure 3, heterogeneity is lower in subgroups defined by narrow ranges of OSA severity (severe only and mild or mild-moderate, vs. mild-severe) (Figure 3). However, the meta-analyses by OSA severity subgroup (4 categories: mild to severe, mild only and mild to moderate, moderate only and moderate to severe, and severe only) did not find a clear difference by OSA severity. Differences in mean score change were −2.61, −1.91, −2.21, and −3.08, respectively, and CIs overlapped; the analysis still found considerable statistical heterogeneity within the mild to severe, and moderate or moderate to severe groups (Figure 3). Four studies reporting on ESS did not provide sufficient data to be included in meta-analyses; however, results were consistent with the pooled estimates above.^131,^ ^183,^ ^194,^ ^198^

Figure 3 Comparison of PAP vs. Inactive Control for Change in ESS

Abbreviations: BL=baseline; CI=confidence interval; Diff=difference; ESS=Epworth Sleepiness Score; N=sample size; PAP=positive airway pressure; REML=restricted maximum likelihood; vs.=versus.

Figure 3 displays the weighted mean differences in ESS, comparing PAP vs. inactive control. The figure displays estimates stratified by OSA severity and provides an overall pooled estimate. Twelve trials of mild to severe OSA yielded a weighted mean difference of -2.61 (95% CI, -3.57 to -1.66; I2 = 89.90). Six trials of mild only, or mild to moderate OSA yielded a weighted mean difference of -1.91 (95% CI, -2.61 to -1.20); I2 = 39.10). Twenty-three trials of moderate only, or moderate to severe OSA yielded a pooled weighted mean difference of -2.21 (95% CI, -2.92 to -1.51); I2 = 87.22). Six trials of severe OSA yielded a pooled weighted mean difference of -3.08 (95% CI, -3.71 to -2.45); I2 = 2.73). Overall, PAP was associated with a reduction in ESS (pooled WMD, -2.33 [95% CI, -2.75 to -1.90]; I2 = 88.37; 47 trials) when compared to inactive controls.

##### Subpopulations

The Apnea Positive Pressure Long-term Efficacy Study found no significant overall difference in improvement of QOL between PAP and sham PAP after 6 months.^141,^ ^142^ However, analyses stratified by OSA severity found that greater improvement in QOL may occur for those with severe OSA treated with PAP who used it more than 4 hours per night (compared with those treated with sham PAP; between-group difference on SAQLI, 0.2; p<0.05).^141,^ ^142^ We found no other study that reported the difference between the effect on health outcomes of PAP versus sham PAP for populations defined by age, sex, BMI, or severity of OSA.

#### MADs

We included 12 RCTs (reported in 15 articles) assessing the effect of MADs on health outcomes, including mortality, QOL, cognitive impairment, CV events, headaches, and ESS (Appendix E Table 5).^164,^ ^177,^ ^206–218^ Four studies compared MADs with sham devices that did not advance the mandible,^206,^ ^207,^ ^216–218^ one compared an MAD with a placebo tablet,^164^ two compared MADs with no treatment,^209,^ ^215^ and one compared an MAD with conservative management of OSA with weight loss.^177^ All studies recruited participants with known or suspected OSA from specialty clinics, such as sleep medicine or otolaryngology. Nine studies were conducted in Europe, two in Australia,^164,^ ^211^ and one in Hong Kong.^177^ Treatment durations ranged from 4 to 12 weeks for most studies; however, one lasted for only 1 week^209^ and one for 24 weeks.^206^ The mean age of enrolled participants ranged from 46 to 58 years. The vast majority of participants were men, with women comprising 14 to 32 percent in the 11 trials reporting sex. No study reported the percentage of minority participants. Almost all studies included participants with mild to moderate OSA, and six studies also included participants with severe OSA.^177,^ ^208,^ ^209,^ ^211,^ ^214,^ ^218^ One study included participants with only severe OSA.^216^

##### Mortality

Among the four trials that reported on mortality over 1 to 12 weeks,^164,^ ^209,^ ^215,^ ^218^ three reported no participant deaths. The other trial reported one death in the no-treatment group.^218^

##### QOL

Six included trials reported at least one QOL measure.^164,^ ^177,^ ^206,^ ^207,^ ^215,^ ^217,^ ^218^ All six used the SF-36, two of the six also used the SAQLI^177,^ ^215^ and three of the six also used the FOSQ.^164,^ ^215,^ ^217^ Because of heterogeneity in the reporting of SF-36 outcomes, the results could not be pooled in a meta-analysis. Overall, results were mixed, with some studies finding no significant improvement in QOL from using MADs,^177,^ ^206,^ ^207,^ ^217^ some reporting possible benefits for some measures or subscales but not for others,^164,^ ^218^ and some reporting benefits for some overall QOL scores.^215^ Further details and specific data are provided in Appendix E. Because of inconsistency, imprecision, and heterogeneity of reporting, findings are insufficient to make conclusions about the potential benefits of using MADs for improving QOL.

##### SF-36

The two trials (n=39 and n=91) that compared an MAD with a sham device found no significant difference in multiple SF-36 subscores.^206,^ ^207,^ ^217^ A four-arm crossover trial (n=90) of three types of MADs compared with no treatment found significant improvement in the SF-36 PCS for a SleepPro2 (MEDiTAS, Milton Keynes, UK) MAD only, and the SF-36 MCS for a custom MAD only.^215^ A trial (n=67) that compared an MAD with conservative management found no significant difference in SF-36 Physical Function, Mental Health, and General Health subscores.^177^ Another trial (n=93) that compared an MAD with a sham device or no treatment found no significant benefit for SF-36 PCS but reported some improvement for SF-36 MCS scores (although it was unclear if the improvement was significantly greater than that with controls because of how the findings were reported).^218^ A trial (n=197) that compared 12 weeks of an MAD with placebo tablet found a significant improvement in overall SF-36 score from baseline but not compared with placebo tablet.^164^

##### Sleep-Related QOL

The trial that compared an MAD with conservative management for 10 weeks found significant improvements in the Emotional and Symptoms subscores but not in the total SAQLI score.^177^ The four-arm crossover trial that compared three types of MADs (each for 6 weeks) found significant improvement in the total SAQLI score for all devices and in nearly all subscores for all devices.^215^ The trial that compared an MAD with a placebo tablet reported significant improvement in mean FOSQ score at 12 weeks but not in subscores other than Social Outcomes.^164^

##### ESS

Ten trials included in our meta-analysis reported on change in ESS among groups randomized to MAD or to an inactive control.^164,^ ^177,^ ^208–211,^ ^214–216,^ ^218^ Our meta-analyses found that MADs improved ESS scores more than controls (−1.67 [95% CI, −2.09 to −1.25]; 10 trials, 1,540 participants; I^2^=36%) (Appendix F Figure 5). The pool mean difference, however, falls below the range considered an MCID for the ESS.^204,^ ^205^ One trial that did not provide sufficient data to be included in the meta-analysis found consistent results.^217^

##### Other Health Outcomes

We included one trial assessing each of the following outcomes for participants using MADs over 6 to 12 weeks: cognitive impairment,^164^ MVAs,^215^ CV events,^215^ and headaches.^217^ Specific data are provided in Appendix E Table 6. Because of unknown consistency, imprecision, and very small numbers of events, findings are insufficient to make conclusions about the potential benefits of MADs for these outcomes.

##### Subpopulations

We found no studies that assessed whether the effect of MADs on health outcomes differs for groups defined by age, sex, BMI, or severity of OSA.

### KQ 6 What Are the Harms Associated With Treatment of OSA Using PAP or MADs, Including for Specific Subgroups of Interest?

Reporting of harms in the included studies was sparse. Most did not report information about harms. Nineteen RCTs (reported in 24 articles) reported on harms associated with treatment of OSA, including 9 trials of PAP,^137,^ ^141,^ ^142,^ ^156,^ ^157,^ ^171,^ ^177,^ ^189,^ ^193,^ ^201,^ ^219,^ ^220^ 9 of MADs,^177,^ ^206,^ ^207,^ ^209–218^ and 1 of PAP and MAD.^177^ Characteristics and detailed results of all 19 studies reporting harms are provided in Appendix E Tables 2, 3, 5, 7, and 8.

#### PAP

Of the 10 included RCTs of PAP, six compared PAP with a sham device,^137,^ ^141,^ ^142,^ ^156,^ ^157,^ ^201,^ ^219,^ ^220^ and four compared PAP with another control (e.g., oral placebo, usual care).^171,^ ^177,^ ^189,^ ^193^ Most studies enrolled fewer than 100 persons; one study^189^ enrolled 111 participants, another study^157^ enrolled 281 participants, a third study^193^ enrolled 298 participants, and the Apnea Positive Pressure Long-term Efficacy Study^141,^ ^142^ enrolled more than 1,000 participants. The majority of enrollees were male, the mean age ranged from 42 to 62 years, and most participants were overweight or obese (mean BMI, 27–39 kg/m^2^). Most of the studies followed patients for 8 to 12 weeks, and two lasted 24 weeks.^141,^ ^142,^ ^193^ In general, harms related to PAP treatment were likely short-lived and could be alleviated by discontinuing treatment with PAP or by supplementing PAP with additional interventions. Overall, 1 to 47 percent of participants in trials of PAP reporting any harms had specific adverse events while using PAP, including claustrophobia, oral or nasal dryness, eye or skin irritation, rash, nosebleeds, and pain.

Across four studies,^177,^ ^189,^ ^201,^ ^219,^ ^220^ 11 percent of patients receiving therapeutic PAP reported irritation compared with 1 percent of patients in the control group. In one study,^141,^ ^142^ rash was reported by significantly more patients receiving therapeutic PAP than by participants receiving sham PAP (18% vs. 11%; p=0.001). Claustrophobia was reported in one trial by a single patient (2%) receiving sham PAP, but by none receiving therapeutic PAP.^201,^ ^220^ One study reported three nosebleeds—one in the PAP group (2%) and two in the control group (4%)^189^—and another study reported one (0.7%) nosebleed in the PAP group and none in the control group.^193^ In two studies, 12 percent of patients reported oral dryness, and 47 percent of patients reported nasal dryness in the therapeutic PAP group compared with 0 percent in the usual care arm.^171,^ ^177^ Three trials reported on pain in the PAP group;^171,^ ^193,^ ^201,^ ^220^ a fourth trial reported on temporomandibular joint pain,^177^ but no patient reported an event. One study contained one report each (2%) of ear pain and noncardiac chest pain in the therapeutic PAP arm; no patient in the control arm reported pain.^201,^ ^220^ In the second RCT, no patient in the active PAP arm reported pain compared with one patient (3%) in the control arm who reported chest pain and arm pain.^171^ The third study reported two cases of pain: one in the PAP group (0.7%) and one in the control group (0.7%).^193^ A single trial reported on both excess salivation and dental issues, such as tooth damage or loosening, but no patient reported either event.^177^ No study reported the need for additional sleep medication as a consequence of the intervention.

#### MADs

Ten RCTs reported harms related to MAD use.^177,^ ^206,^ ^207,^ ^209–218^ Most RCTs (k=6) lasted 4 to 8 weeks, one lasted a single week,^209^ one lasted 10 weeks,^177^ one lasted 12 weeks,^210^ and one lasted 24 weeks.^206,^ ^207^ Across three studies that reported any discontinuation of treatment because of adverse events, 7 percent of patients in the active MAD group discontinued MAD use due to harms compared with 1 percent of patients in the control group.^177,^ ^215,^ ^218^ No study reported rash, claustrophobia, nosebleed, or the need for additional sleep medication.

In four studies, rates of oral dryness ranged from 5 to 33 percent in the active MAD group compared with 0 to 3 percent in the control group.^177,^ ^206,^ ^207,^ ^210,^ ^215^ Six studies reported rates of excess salivation.^177,^ ^206,^ ^207,^ ^210–213,^ ^215,^ ^217^ Three of these reported rates of excessive salivation from 23 to 68 percent in the active treatment arms compared with 0 to 3 percent in the sham group or no-treatment group.^177,^ ^206,^ ^207,^ ^215^ One of the six studies reported a higher rate of excessive salivation in the sham MAD arm than in the active treatment arm (58% and 36%, respectively).^210^ Another reported a significantly higher rate of hypersalivation but did not report the number of patients who experienced this outcome.^217^ The remaining study reported no significant difference in excess salivation between the MAD and sham groups but also did not report the respective numbers of patients.^211–213^

All 10 RCTs reporting harms included some report of oral mucosal, dental, or jaw symptoms, including mucosal or dental pain, discomfort or tenderness, mucosal erosions, jaw or temporomandibular joint pain or discomfort that occurred either upon waking or persistently, jaw occlusal changes, and jaw muscle discomfort. In seven studies, adverse oral mucosal, dental, or jaw symptoms ranged from 17 to 74 percent in MAD groups compared with 0 to 17 percent in the sham group, no-treatment group, or conservative management group. Two studies reported that there was a statistically significant difference only in the percentage who experienced jaw discomfort and tooth tenderness in the MAD group compared with that in the sham group.^211–213,^ ^217^ One trial (n=150) measured common harms on one scale by asking participants to rate presence and severity (0, absent; 1, mild; 2, moderate; 3, severe) of the following: jaw pain, tooth pain, muscle stiffness, dry mouth, hypersalivation, and occlusal changes.^216^ There was no significant difference between MAD and sham groups on mean scores at 8 weeks (2 vs. 2; p=0.14).