# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope of work and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Six KQs were developed for this review:

1. Does screening for obstructive sleep apnea (OSA) in adults improve health outcomes, including for specific subgroups of interest?
2. What is the accuracy of screening questionnaires, clinical prediction tools, and multistep screening approaches (e.g., using a questionnaire followed by home-based oximetry/testing) in identifying persons in the general population who are more or less likely to have OSA, including for specific subgroups of interest?
3. What are the harms associated with screening or subsequent diagnostic testing for OSA, including for specific subgroups of interest?
4. How effective is treatment with positive airway pressure (PAP) or mandibular advancement devices (MADs) for improving intermediate outcomes (i.e., the apnea-hypopnea index [AHI] or blood pressure) in persons with OSA, including for specific subgroups of interest?
5. How effective is treatment with PAP or MADs for improving health outcomes in persons with OSA, including for specific subgroups of interest?
6. What are the harms associated with treatment of OSA using PAP or MADs, including for specific subgroups of interest?

Figure 1 Analytic Framework

Abbreviations: AHI=apnea-hypopnea index; OSA=obstructive sleep apnea.

Figure 1 depicts the key questions within the context of the eligible populations, screenings, interventions, comparisons, outcomes, settings, and study designs. On the left, the population of interest is asymptomatic adults. Moving from left to right, the figure illustrates the overarching question: Does screening for obstructive sleep apnea (OSA) in asymptomatic adults improve health outcomes (KQ 1). The figure depicts the question: What is the accuracy of screening questionnaires, clinical prediction tools, and multistep screening approaches in identifying persons in the general population who are more or less likely to have OSA (KQ 2). Screening may result in harms (KQ 3). After detection of OSA, the figure illustrates the following questions: How effective is treatment with positive airway pressure or mandibular advancement devices for improving intermediate outcomes (i.e., apnea-hypopnea index, blood pressure) (KQ 4) and for improving health outcomes (KQ 5). Treatment with positive airway pressure or mandibular advancement devices may result in harms (KQ 6).

In addition to addressing the KQs, this review also looked for evidence related to two contextual questions (CQs) that focused on (1) barriers to undergoing diagnostic testing for OSA and (2) the association between AHI and health outcomes. These CQs were not a part of this systematic review but are intended to provide additional background information. Literature addressing the CQs is summarized in Appendix A.

## Data Sources and Searches

PubMed/MEDLINE, the Cochrane Library, and Embase were searched for English-language articles published through August 23, 2021. Medical Subject Headings were used as search terms when available and keywords when appropriate, the search focused on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are listed in Appendix B. Targeted searches for unpublished literature were conducted via ClinicalTrials.gov. To supplement electronic searches, the reference lists of pertinent review articles and studies that met the inclusion criteria were reviewed. Studies suggested by peer reviewers or public comment respondents were reviewed and, if appropriate, incorporated into the final review. Since August 23, 2021, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on September 23, 2022, and no additional studies meeting eligibility criteria were identified. All literature search results were managed using EndNote^TM^ version 9.2 (Thomson Reuters, New York, NY).

## Study Selection

Inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs were developed with input from the USPSTF (Appendix B). We included English-language studies of adults ages 18 years or older conducted in countries categorized as “very high” on the Human Development Index.^104^ We excluded studies of children, adolescents, pregnant women, and adults with central sleep apnea or acute stroke or other acute conditions that can trigger onset of OSA. We also excluded studies focused on the screening, diagnosis, or treatment of OSA among persons with rare conditions (e.g., acromegaly) for whom testing (rather than screening and primary prevention) for OSA is considered part of standard disease management. Studies focused on screening in occupational settings (e.g., during a workplace fitness-for-duty evaluation) were also excluded.

For KQs 1 and 3 (direct evidence of benefits and harms of screening, respectively), and KQ 2 (accuracy of clinical prediction tools or screening questionnaires), we included studies that enrolled asymptomatic adults with OSA or persons with unrecognized symptoms of OSA; those that enrolled referral populations were not eligible. For KQ 1, RCTs comparing screened with nonscreened groups reporting on health outcomes were eligible. For KQ 2, prospective cohort studies and cross-sectional studies that evaluated the accuracy of screening questionnaires or clinical prediction tools (alone or followed by an unattended HST) compared with overnight PSG conducted in a sleep laboratory were eligible. Studies assessing single patient characteristics or risk factors were not eligible; clinical prediction tools were required to include multiple factors. For KQ 2, we excluded studies limited to persons who were referred to sleep laboratories for suspected OSA and excluded studies where only a subgroup (usually the highest risk group) had PSG because of concern for verification bias. For KQ 3 (harms of screening), we included studies eligible for KQ 1 or KQ 2 that reported harms of screening or diagnostic tests, such as false-positive results leading to unnecessary treatment, anxiety, condition-specific distress, or stigma.

For KQs 4 through 6 (benefits and harms of treatment), we included studies evaluating PAP or MADs compared to an inactive control; other interventions were not eligible (e.g., oropharyngeal exercises, weight loss interventions). For KQ 4 (benefit of treatment for improving intermediate outcomes), we limited inclusion to good-quality, recent (within 5 years) SRs comparing PAP or MADs with an inactive control that reported on changes in BP outcomes or in AHI. For KQs on the benefit of treatment for improving health outcomes (KQ 5) and harms of treatment (KQ 6), RCTs of asymptomatic adults with OSA and/or symptomatic adults with a confirmed diagnosis of OSA were eligible.

Titles and abstracts were independently reviewed by two investigators; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

Two investigators independently assessed the quality of the included studies by using criteria defined by the USPSTF adapted for this topic and supplemented it with criteria from the Quality Assessment of Diagnostic Accuracy 2 (QUADAS-2)^105^ for diagnostic accuracy studies and from A Measurement Tool to Assess Systematic Reviews (AMSTAR) for SRs^106^ (Appendix B). Each study was assigned a final quality rating of good, fair, or poor; disagreements were resolved by discussion and consensus. Only studies rated as having good or fair quality were included.

For each included study, one investigator extracted pertinent information about the methods, enrolled populations, interventions, comparators, eligible outcomes, timing, settings, and study designs. All data extractions were checked by a second investigator for completeness and accuracy.

## Data Synthesis and Analysis

We qualitatively synthesized the findings for each KQ by summarizing the characteristics and results of included studies in tabular and narrative format. Summary tables and figures of study characteristics, population characteristics, intervention characteristics, and outcomes were used to assess the consistency, precision, and relationship of effect size with key potential modifiers. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies following established guidance.^107^ We had a sufficient number of similar trials to conduct a meta-analysis of studies examining the benefits of PAP and MAD. We ran random-effects restricted maximum likelihood models on continuous measures of sleepiness, general health–related QOL and sleep-related QOL when at least three similar studies were available. We calculated pooled estimates of the difference in mean change from the baseline score between the intervention and control groups; when studies reported on similar outcomes using multiple scales, we used the standardized mean difference (SMD) in change from the baseline score in pooled estimates. The meta command in Stata version 16 were used to conduct all quantitative analyses.^108^ For our meta-analyses of PAP and MAD treatments, we stratified analyses by comparison groups, providing pooled estimates for studies using sham controls (e.g., a sham PAP device) separately from those not using sham controls. We combined parallel trials and crossover trials but conducted subgroup analyses to explore whether findings differed by this study design feature and by other factors when possible, including OSA severity and baseline sleepiness (ESS score).

For all quantitative analyses, the I^2^ statistic was calculated to assess the statistical heterogeneity in effects between studies.^109,^ ^110^ An I^2^ from 0 to 40 percent may not be important, an I^2^ from 30 to 60 percent may represent moderate heterogeneity, an I^2^ from 50 to 90 percent may represent substantial heterogeneity, and an I^2^ of 75 percent or greater represents considerable heterogeneity.^111^

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from December 17, 2020, to January 20, 2021. In response to public comments, the treatment eligibility criteria were revised to clarify the variations of PAP that were eligible and that studies focused on screening specific occupational groups in the context of an occupational health examination for fitness for duty are excluded. The USPSTF made no substantive change that altered the scope of the review. The final version of the research plan was posted on the USPSTF website on March 4, 2021. The draft evidence review was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and addressed in revisions of this evidence review where appropriate. Revisions included clarifying in the Introduction and Methods that combined screening approaches for OSA were eligible (e.g., screening questionnaire followed by home-based oximetry testing for persons who score above a defined threshold on the questionnaire) and elaborating on the limitations of the current body of evidence in the Discussion. The draft evidence review was posted for public comment from March 29, 2022, through April 25, 2022. Revisions included clarifying current AASM clinical practice guidelines relevant to OSA in the Introduction and clarifying in the Introduction and Methods that the scope of the review does not include screening for OSA in occupational settings.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs and to resolve issues related to the scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.