# Chapter 1 Introduction

## Scope and Purpose

The United States Preventive Services Task Force (USPSTF) will use this review to update its recommendation on screening for obstructive sleep apnea (OSA) in adults. In 2017, the USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms of screening for OSA in asymptomatic adults (I statement).^1^

## Condition Definition

OSA is a sleep disorder characterized by episodes of narrowing and obstruction of the pharyngeal airway during sleep resulting in reductions or cessations in breathing.^2^ By definition, OSA consists of more than five events per hour of partial or total upper airway obstruction despite efforts to breathe.^3^ Total airway obstruction (>90%) for more than 10 seconds is defined as apnea, whereas hypopnea is a partial airway obstruction (>30%) with at least a 3 percent reduction in oxyhemoglobin saturation or sleep arousals.^4^ The apnea-hypopnea index (AHI) is used to define the severity of OSA. The AHI categorization cutoffs vary slightly depending on the source but are similar to cutoffs proposed by Veasey and Rosen:^4^ mild OSA—5 to 15 events per hour; moderate OSA—16 to 30 events per hour; and severe OSA—more than 30 events per hour. Common clinical signs and symptoms of OSA include excessive daytime sleepiness (EDS), unrefreshing sleep despite length of sleep, loud or irregular snoring, and choking or gasping at night.^5^ The International Classification of Sleep Disorders, Third Edition includes both physiological measurements and clinical signs and symptoms in its OSA definition: a respiratory disturbance index (RDI) of five or more events per hour as determined by polysomnography (PSG) in addition to the common clinical symptoms of OSA or an RDI of 15 or more events per hour with or without clinical symptoms.^6^ The RDI includes the number of respiratory effort–related arousals per hour in addition to the number of apnea and hypopnea events.^7^

## Etiology and Natural History

OSA is caused by a narrowing of the upper airway leading to either a reduction or cessation of airflow during sleep. Although anatomical abnormalities are implicated in OSA, evidence suggests there are multifactorial causes.^2,^ ^8^ A common cause for the restriction in the upper airway is obesity, which may include adipose tissue in areas around the airway, increased lingual fat, and abdominal fat leading to reduced lung volume.^9^ Other causes leading to a narrow pharyngeal airway are enlarged tonsils;^10^ an anatomically long upper airway, particularly in men;^9^ and a small craniofacial structure, especially in Asian populations.^11,^ ^12^ The conclusions of one systematic review (SR) and meta-analysis^8^ that compared craniofacial and upper airway morphology of patients with OSA with those of controls indicated that patients with OSA displayed a reduced pharyngeal airway space, a greater total anterior facial height, and an inferior position of the hyoid bone. Nonanatomic contributions included reduced upper airway dilator muscle control and functions that are responsible for neural control, reduced muscle responsiveness, and reduced muscle effectiveness; an unstable or overly sensitive respiratory control system; and a low respiratory arousal threshold that leads persons to wake up too easily when airways narrow which possibly reduces pharyngeal muscle activity.^2,^ ^9^ In recent years, research has focused on metabolic disease as a contributing factor to OSA, specifically insulin resistance and leptin deficiency and possibly glycemic control;^13^ however, further research may be warranted to identify the mechanisms involved and the direction of the association between OSA and metabolic disease.

Left untreated, OSA is associated with multiple adverse health outcomes. However, the natural history of OSA progression rates (from mild to severe) is unclear. For example, the extent to which mild, asymptomatic OSA progresses in severity independent of other factors such as weight gain is unclear and not well described in the current literature. Some researchers have examined multiple complications of OSA and have hypothesized comprehensive models that have accounted for the relationships between OSA and adverse health outcomes. For instance, some researchers suggested that metabolic factors both influence the development of OSA and are products of OSA, in which visceral obesity is the common etiological factor.^13,^ ^14^

## Risk Factors

Risk factors for OSA include male sex (odds ratio [OR], 3.1 [95% confidence interval {CI}, 2.5 to 3.8]), increasing age (40 to 70 years), higher body mass index (BMI), craniofacial and upper airway abnormalities (e.g., children with retrognathia or micrognathia), and postmenopausal status (OR, 3.5 to 4.3 for AHI ≥15).^15–31^

Persons with OSA (especially moderate to severe OSA) have an increased incidence of hypertension (HTN), which may be a risk factor for OSA as well as an adverse health consequence of untreated OSA. However, the presence of HTN alone is not useful in detecting persons at increased risk of OSA.^21^ Smoking, alcohol use, sedative use, and nasal obstruction (e.g., due to nasal congestion) have been suspected of increasing OSA risk, but these factors are supported by sparse or mixed evidence.^21,^ ^32–39^

## Prevalence and Burden

### Prevalence

The prevalence of OSA in the literature varies, in part, by the definition of hypopnea used for the study.^40^ Older studies set higher AHI thresholds compared with more recent studies, making comparisons challenging.^21^ Further, estimates may vary because of sampling biases, year of publication, or a combination of factors.^41^ As noted in this section, the estimated prevalence of OSA in the U.S. population has increased in the past few decades, which primarily is attributed to the increased prevalence of obesity.^42^ In addition, between 1999 and 2010, diagnoses of OSA in the National Ambulatory Medical Care Survey rose by 442 percent.^43^

Based on data from the Wisconsin Sleep Cohort Study (WSCS) and the 2012 National Health and Nutrition Examination Survey, estimated prevalence of any OSA (AHI ≥ 5) was 26 percent, and prevalence of moderate to severe OSA (AHI ≥ 15) was 10 percent.^42^ A recent modeling study conducted in 2019 indicates that this is an underestimate of the prevalence that would be expected when using the most recent (2012) American Academy of Sleep Medicine scoring criteria to identify OSA; standardized prevalence using 2012 scoring criteria in the U.S. estimates were 33.2 percent for any OSA (AHI ≥5) and 14.5 percent for moderate to severe OSA (AHI ≥15).^44^ Evidence about the prevalence of severe OSA (AHI ≥30) is scant, although clearly this prevalence would be lower than the combined prevalence of moderate to severe OSA.

#### Subpopulations

The prevalence of OSA appears to increase with age through the sixth to seventh decades and then plateaus.^16,^ ^17,^ ^31^ OSA is approximately 2 to 3 times more common in men than in women, although the gap narrows at the age of menopause in women.^16,^ ^17,^ ^28,^ ^45^ Based on data extrapolated from the WSCS and the 2012 National Health and Nutrition Examination Survey, the prevalence of moderate to severe OSA (AHI ≥15) among adults ages 30 to 70 years was 13 percent for men and 6 percent for women.^42^ Using a standard definition of daytime sleepiness and an AHI of 5 or greater to define OSA, prevalence was 14 percent among men and 5 percent among women.^42^

A higher BMI is associated with an increased prevalence of sleep-disordered breathing, and the prevalence of OSA appears to be rising with the obesity rates in the United States.^23,^ ^42^ For instance, in men ages 30 to 49 years the prevalence of moderate to severe sleep-disordered breathing (AHI ≥15) was 55.0 percent in those with a BMI greater than or equal to 40, 16.6 percent with a BMI of 30 to 39.9, and 3.8 percent with a BMI of 25 to 29.9. In women ages 30 to 49 years, the prevalence of moderate to severe sleep-disordered breathing was 18.6 percent in those with a BMI greater than or equal to 40, 3.6 percent with a BMI of 30 to 39.9, and 0.73 percent with a BMI of 25 to 29.9.^42^

African American, Native American, and Hispanic populations have a higher prevalence of OSA compared with Whites; however, some evidence suggests that differences are partially explained by higher rates of obesity, asthma, and tobacco use among certain ethnic groups.^46^

### Burden of Disease

Many adverse health outcomes have been associated with OSA in observational studies, primarily attributed to chronic disturbances in gas exchange (e.g., hypercapnia and hypoxemia), sympathetic nervous system arousal (e.g., oxidative stress caused by intermittent hypoxemia leading to sympathetic activation, cortical arousal independent of oxygen), and fragmented sleep. Untreated, severe OSA (AHI ≥30) is associated with increased all-cause mortality.^47,^ ^48^ However, there is controversy in the literature regarding the extent to which OSA independently contributes to various adverse outcomes (i.e., without the contributions of age, BMI, and other potential confounders). For example, OSA is associated with several cardiovascular (CV) risk factors, making it more difficult to establish an independent association between OSA and CV disease (CVD).

Specific adverse health outcomes associated with untreated OSA include increased higher rates of motor vehicle and other accidents,^48–55^ cognitive impairment,^29,^ ^56–58^ lost work days,^59^ work disability,^60^ impaired work performance,^61^ and decreased quality of life (QOL).^62^ In addition, bidirectional associations between OSA and the following outcomes have been reported: CV events,^63,^ ^64^ coronary heart disease (CHD) and heart failure,^65–70^ angina,^71,^ ^72^ atrial fibrillation,^73^ stroke,^65,^ ^74,^ ^75^ HTN,^23,^ ^24,^ ^76–80^ and type 2 diabetes (DM2) and metabolic syndrome.^14,^ ^81–84^

#### Subpopulations

Despite a lower prevalence of OSA, women may present with more OSA comorbidities, including insomnia, mood disorders, anxiety, and morning headache.^85^

Some evidence suggests that morbidity associated with OSA varies by symptom subtypes, particularly those experiencing EDS. For example, a 2019 cohort study (n=1,207 participants with at least moderate OSA) found a higher risk of incident heart failure, CHD, and CVD among those reporting excessive sleepiness compared with other subtypes (disturbed sleep, minimally symptomatic, and moderately sleepy).^86^ A qualitative analysis (n=42) of U.S. patients with OSA and EDS concluded that EDS adversely affected multiple health-related QOL domains in the majority of participants, including physical health and functioning, cognition, relationships, emotions, and work productivity.^87^

## Rationale for Screening and Screening Strategies

In theory, screening to identify unrecognized OSA followed by appropriate treatment could improve sleep quality, eliminate apneas and hypopneas, and normalize oxygen saturation levels to reduce risk of future adverse health outcomes. Potential screening strategies include formal screening questionnaires and clinical prediction tools in addition to combined screening approaches, which may use a questionnaire or clinical prediction tool followed by home-based oximetry testing for persons who score above a defined threshold on the questionnaire or clinical prediction tool. For persons who screen positive, a diagnostic test would be used to determine whether they have OSA (i.e., formal PSG in a sleep facility or unattended home sleep testing [HST] with a portable monitor [PM]).

The available screening questionnaires and clinical prediction tools attempt to identify persons at higher risk of OSA. Many of them combine questions about objective findings (e.g., BMI, neck circumference) with questions about symptoms associated with OSA. Screening questionnaires that could be considered for use in primary care include the STOP (Snoring, Tiredness, Observed apnea, blood Pressure) Questionnaire,^88^ STOP-BANG Questionnaire (STOP Questionnaire plus BMI, Age, Neck circumference, and Gender),^89^ the Berlin Questionnaire (BQ),^90^ the Wisconsin Sleep Questionnaire,^28^ and the Epworth Sleepiness Scale (ESS).^91^ Previous reviews found that most tools were validated in referral settings (using populations with a higher prevalence of OSA) and not in the general population or were limited by risk of spectrum bias, and also found that the accuracy and reliability in general primary care settings were unclear and may have been substantially overestimated.^21,^ ^92^

The traditional confirmatory diagnostic test for OSA is a technologist-attended PSG conducted in a sleep laboratory facility. The use of PSG for diagnosis requires measurement of the following: electroencephalogram (EEG), electrooculogram, chin electromyelogram, airflow, oxygen saturation, respiratory effort, and electrocardiogram or heart rate.^93^ Additional recommended measurements include body position and leg movements.^93^ The frequency of events is typically reported as an AHI. In-laboratory PSG is costly and potentially inconvenient for patients. In-home PMs have been proposed as an alternative.^94^ Sleep study monitors are generally classified into one of four types based on the signals recorded (Appendix A Table 1): type I is a facility-based PSG; the other types are PMs. The American Academy of Sleep Medicine (AASM) recommends using PSG or a home sleep apnea test with a technically adequate device to diagnosis OSA in uncomplicated adults presenting with signs and symptoms that indicate an increased risk of moderate to severe OSA.^6^ If the home testing result is negative, inconclusive, or technically inadequate, then PSG is recommended to ascertain diagnosis.^6^ For patients with significant cardiorespiratory disease, potential respiratory muscle weakness, awake hypoventilation or suspicion of sleep-related hypoventilation, chronic opioid use, history of stroke, or severe insomnia, the AASM recommends using PSG rather than home testing for diagnosis.^6^

## Treatment Approaches

Positive airway pressure (PAP) is the main treatment for OSA.^95,^ ^96^ PAP devices deliver compressed air into the airway and aim to maintain an open airway. These devices can deliver continuous PAP (CPAP), auto-adjusting PAP (APAP), or bilevel PAP (BPAP).^95^ OSA treatment guidelines are summarized in Appendix A Table 2. The American College of Physicians recommends (1) to encourage all patients who are overweight or obese with OSA to lose weight (strong recommendation, low-quality evidence), (2) PAP as initial therapy for patients diagnosed with OSA (strong recommendation, moderate-quality evidence), and (3) mandibular advancement devices (MADs) as an alternative therapy to PAP for patients with OSA who prefer them or for those with adverse effects associated with PAP (weak recommendation, low-quality evidence).^96^ In 2019, the AASM recommended that clinicians and patients discuss using CPAP or APAP (over BPAP) to treat OSA in adults with EDS, impaired sleep–related QOL, or comorbid HTN.^95^ The AASM also recommends that PAP therapy be initiated using either APAP at home or in-laboratory PAP titration in adults with OSA and no significant comorbidity, noting that the choice of treatment delivery at home versus in a laboratory should be based on access, cost-effectiveness, patient preference, clinician judgment, and other factors.^95^ This recommendation is qualified as being for persons with no significant comorbidities because it was based on studies that excluded patients with, for example, congestive heart failure, chronic opiate use, significant lung disease, neuromuscular disease, or history of uvulopalatopharyngoplasty (UPPP).^95^ For patients who do not accept PAP treatment, AASM guidelines suggest that providers discuss alternative treatment options with patients, such as weight loss, positional therapy, oral appliance therapy, or surgical interventions. Other relevant AASM treatment guidelines are outlined in Appendix A Table 2.

Surgical interventions for OSA are available, but they generally are not considered first-line treatment options. PAP is by far the most commonly used treatment, and surveys of practice patterns indicate that surgical treatments are rarely used.^97,^ ^98^ For example, the recently published AASM clinical practice guideline recommends that clinicians discuss referral to a sleep surgeon with adults with OSA and a BMI less than 40 kg/m^2^ who are intolerant of PAP.^99^ Types of surgical procedures that have been studied or used for OSA include the following: nasal and nasopharyngeal, oral and oropharyngeal, hypopharyngeal and laryngeal, global airway, upper airway bypass procedures, and implantable hypoglossal nerve stimulator. Specific procedures include UPPP, in which tissue is removed from the throat and from the rear of the mouth; maxillomandibular advancement, in which the jaw is surgically moved forward; soft palate implants; nasal polyp removal; tonsillectomy; and tracheostomy.

## Clinical Practice in the United States and Recommendations of Other Organizations

The current frequency of routine screening for OSA in primary care and use of questionnaires to assess risk for OSA among those presenting with sleep-related symptoms is unclear. However, one 2011 practice-based research network study of 44 randomly selected practices found that only 20 percent of patients (who regularly visit primary care clinicians) with sleep-related symptoms spontaneously reported their symptoms to their primary care clinicians.^100^ Currently, most primary care clinicians refer patients with suspected OSA to a specialist to determine the appropriate diagnostic test and treatment, likely due to the complexity associated with diagnosis and with treatment selection.^101^ Clinical practice guidelines related to screening and diagnosis of OSA are summarized in Appendix A Table 3. Most groups do not recommend routine screening in primary care settings among populations without signs or symptoms of OSA. One group (the AASM) recommends routine screening using a standardized questionnaire in groups considered high-risk for OSA, including those who are preoperative for bariatric surgery or who have any of the following conditions: obesity (BMI ≥30 kg/m^2^), congestive heart failure, atrial fibrillation, treatment-resistant hypertension, impaired glucose tolerance or DM2, nocturnal dysrhythmias, stroke, pulmonary hypertension, and coronary artery disease.^102^ Recent (2019) U.S. Department of Veterans Affairs (VA) guidelines suggest using the STOP Questionnaire to stratify the risk of OSA among patients who report sleep complaints (graded as a weak recommendation by the VA guideline work group) and also suggest assessing for sleep-disordered breathing in patients with a history of CV or cerebrovascular events, congestive heart failure, and chronic opioid use^103^ (graded as a weak recommendation by the VA guideline work group).