# Appendix F Additional Figures

Appendix F Figure 1 Comparison of PAP vs. Inactive Control for Change in Short Form (36) Health Survey Mental Component Summary (SF-36 MCS) and Physical Component Summary (SF-36 PCS)

Abbreviations: BL=baseline; CI=confidence interval; Diff=difference; ESS=Epworth Sleepiness Scale; H^2^=H^2^ statistic; I^2^=I^2^ statistic; MCS=mental component summary; mil=mild; mod=moderate; N=number; OSA=obstructive sleep apnea; PAP=positive airway pressure; PCS=physical component summary; REML=restricted maximum-likelihood estimation; sev=severe; SF-36=Medical Outcome Short-Form (36-Item) Health Survey; T^2^=T^2^ statistic; vs.=versus.

Appendix F Figure 1 displays the weighted mean differences in the Short Form (36) Health Survey Mental Component Summary (SF-36 MCS) and the Physical Component Summary (SF-36 PCS), comparing PAP vs. inactive control. For the SF-36 PCS, 13 trials yielded a weighted mean difference of 1.53 (95% CI, 0.29 to 2.77; I2 = 58.60). For the SF-36 MCS, 15 trials yielded a weighted mean difference of 2.20 (95% CI, 0.95 to 3.44); I2 = 64.42).

Appendix F Figure 2 Comparison of PAP vs. Inactive Control for Change in Sleep-Related Quality of Life, Pooled Standardized Mean Difference

Abbreviations: BL=baseline; CI=confidence interval; Diff=difference; ESS=Epworth Sleepiness Scale; FOSQ=Functional Outcomes of Sleep Questionnaire; H^2^=H^2^ statistic; I^2^=I^2^ statistic; N=number; PAP=positive airway pressure; QSQ=Quebec Sleep Questionnaire; REML=restricted maximum-likelihood estimation; SAQLI=Sleep Apnea Quality of Life Index; T^2^=T^2^ statistic; vs.=versus.

Appendix F Figure 2 displays the standardized mean differences in Sleep-Related Quality of Life (as measured by the FOSQ, QSQ, or SAQLI), comparing PAP vs. inactive control. The figure displays estimates stratified by sleep-related quality of life measure and provides an overall pooled estimate. Ten trials yielded a pooled standardized mean difference of 0.24 (95% CI, 0.09 to 0.39; I2 = 43.03) on the FOSQ. One trial yielded a standardized mean difference of 0.76 (95% CI, 0.03 to 1.49) on the QSQ. Six trials yielded a pooled standardized mean difference of 0.38 (95% CI, 0.17 to 0.58); I2 = 73.43) on the SAQLI. Overall, PAP was associated with improvements in sleep-related quality of life (pooled SMD, 0.30 [95% CI, 0.19 to 0.42]; I2 = 54.73; 17 trials) when compared to inactive controls.

Appendix F Figure 3 Comparison of PAP vs. Inactive Control for Change in Sleep-Related Quality of Life, Difference in Change From Mean Baseline Scores

Abbreviations: BL=baseline; CI=confidence interval; Diff=difference; ESS=Epworth Sleepiness Scale; FOSQ=Functional Outcomes of Sleep Questionnaire; H^2^=H^2^ statistic; I^2^=I^2^ statistic N=number; PAP=positive airway pressure; QSQ=Quebec Sleep Questionnaire; REML=restricted maximum-likelihood estimation; SAQLI=Sleep Apnea Quality of Life Index; T^2^=T^2^ statistic; vs.=versus.

Appendix F Figure 3 displays the difference in change from mean baseline scores in Sleep-Related Quality of Life (as measured by the FOSQ, QSQ, or SAQLI), comparing PAP vs. inactive control. The figure displays estimates stratified by sleep-related quality of life measure and provides an overall pooled estimate. Ten trials yielded a pooled standardized mean difference of 0.55 (95% CI, 0.05 to 1.06; I2 = 69.61) on the FOSQ. One trial yielded a standardized mean difference of 3.25 (95% CI, 0.26 to 6.24) on the QSQ. Six trials yielded a pooled standardized mean difference of 0.40 (95% CI, 0.17 to 0.62); I2 = 80.54) on the SAQLI. Overall, PAP was associated with improvements in sleep-related quality life (pooled SMD, 0.47 [95% CI, 0.23 to 0.70]; I2 = 88.07; 17 trials) when compared to inactive controls.

Appendix F Figure 4 Comparison of PAP vs. Inactive Control for Change in Sleep-Related Quality of Life, Sensitivity Analysis Limited to Trials With Mean Baseline ESS ≥10

Abbreviations: BL=baseline; CI=confidence interval; Diff=difference; ESS=Epworth Sleepiness Scale; FOSQ=Functional Outcomes of Sleep Questionnaire; H^2^=H^2^ statistic I^2^=I^2^ statistic; N=number; PAP=positive airway pressure; QSQ=Quebec Sleep Questionnaire; REML=restricted maximum-likelihood estimation; SAQLI=Sleep Apnea Quality of Life Index; T^2^=T^2^ statistic; vs.=versus.

Appendix F Figure 4 displays the change in Sleep-Related Quality of Life (as measured by the FOSQ, QSQ, or SAQLI), comparing PAP vs. inactive control. The figure displays pooled estimates stratified by baseline ESS and provides an overall pooled estimate. Five trials with a baseline ESS score of <10 yielded a pooled standardized mean difference of 0.23 (95% CI, -0.04 to 0.51; I2 = 56.07). Twelve trials with a baseline ESS score of ≥10 yielded a pooled standardized mean difference of 0.32 (95% CI, 0.19 to 0.46); I2 = 57.70). Overall, PAP was associated with improvements in sleep-related quality life (pooled SMD, 0.30 [95% CI, 0.19 to 0.42]; I2 = 54.73; 17 trials) when compared to inactive controls.

Appendix F Figure 5 Comparison of MAD vs. Inactive Control for Change in ESS

Abbreviations: BL=baseline; CI=confidence interval; Diff=difference; ESS=Epworth Sleepiness Scale; FOSQ=Functional Outcomes of Sleep Questionnaire; H^2^=H^2^ statistic; I^2^=I^2^ statistic; MAD=mandibular advancement device; mil=mild; mod=moderate; N=number; OSA=obstructive sleep apnea; sev=severe; T^2^=T^2^ statistic; vs.=versus.

Appendix F Figure 5 displays the standardized mean differences in ESS, comparing MAD vs. inactive control. Ten trials yielded a pooled standardized mean difference of -1.67 (95% CI, -2.09 to -1.25; I2 = 35.48).