# Appendix E Additional Tables

Appendix E Table 1 Summary of Included Systematic Reviews and Meta-Analyses on Benefits of Treatment on AHI and Blood Pressure (KQ 4)

Author, Year | Intervention vs. Comparison | N Included Trials (Search Date) | Characteristics of Trials^*^ | Pooled Results; N Trials (Participants); Heterogeneity
de Vries, 2018^123^ | Oral appliance vs. inactive control | 11 (December 31, 2016) | Mean Age: 45.7–58; % Female: 17–22; Race/Ethnicity: NR; Mean BMI: 27.4–30.6; Mean AHI: 13.8–42.3; Mean ESS: NR; OSA Severity: Any^†^; % HTN: 19–89^ǂ^; % HF: NR | Mean Change (95% CI); Daytime SBP: −1.55 (−4.65 to 4.25); 5 (469); I^2^=0%; Daytime DBP: −1.14 (−2.78 to 3.38); 5 (469); I^2^=0%
de Vries, 2018^123^ | Oral appliance vs. inactive control | 11 (December 31, 2016) | Mean Age: 46.4–58; % Female: 17–21; Race/Ethnicity: NR; Mean BMI: 28.4–31; Mean AHI: 21.5–42.3; Mean ESS: NR; OSA Severity: Any^†^; % HTN: 15–89^ǂ^; % HF: NR | Mean Change (95% CI); 24-Hour SBP: −1.38 (−3.41 to 0.64); 4 (427); I^2^=0%; 24-Hour DBP: −1.18 (−2.63 to 0.27); 4 (427); I^2^=0%
Labarca, 2021^124^ | CPAP vs. control in populations (sham CPAP, usual care) | 8 (March 2020) | Mean Age: 57.2–61.2; % Female: 13.5–62.5; Race/Ethnicity: NR; Mean BMI: 28.6–34.3; Mean AHI: 20–59.8; Mean ESS: 6.4–10; OSA Severity: NR; % HTN: 100%; % HF: NR | Mean Difference (95% CI); 24-Hour SBP: −5.06 (−7.98 to −2.13); 8 (606); I^2^=69%; 24-Hour DBP: −4.21 (−6.50 to −1.93); 7 (550); I^2^=81%; Daytime SBP: −2.34 (−6.94 to 2.27); 6 (526); I^2^=84%; Daytime DBP: −2.14 (−4.96 to 0.67); 6 (526); I^2^=78%; Nighttime SBP: −4.15 (−7.01 to −1.29); 6 (526); I^2^=43%; Nighttime DBP: −1.95 (−3.32 to −0.57); 6 (526); I^2^=0%
Patil, 2019^125^ | PAP vs. inactive control (sham, usual care, oral pbo) | 184 (February 2018) | Mean Age: NR; % Female: NR; Race/Ethnicity: NR; Mean BMI: NR; Mean AHI: NR; Mean ESS:NR; OSA Severity: NR; % HTN: NR; % HF: NR | Mean Difference (95% CI); All Participants^§^; AHI, events/hour: −23.41 (−28.51 to −18.30); 11 (832); I^2^=93%; Nighttime SBP: −4.21 (−5.96 to −2.45); 14 (1,272); I^2^=9%; Nighttime DBP: −2.31 (−3.72 to −0.91); 15 (1,451); I^2^=41%; Daytime SBP: −2.76 (−4.31 to −1.20); 12 (1,191); I^2^=5%; Daytime DBP: −1.98 (−3.02 to −0.93); 12 (1,191); I^2^=4%; 24-Hour SBP: −1.47 (−2.28 to −0.66); 23 (4,905); I^2^=0%; 24-Hour DBP: −1.58 (−2.23 to −0.93); 22 (4,595); I^2^=6%; Mean 24-Hour BP: −2.63 (−3.86 to −1.39); 8 (994); I^2^=0%; Resistant Hypertensive^ǁ^; Nighttime SBP: −3.26 (−6.11 to −0.41); 5 (446); I^2^=0%; Nighttime DBP: −2.20 (−4.39 to −0.01); 5 (444); I^2^=0%; Daytime SBP: −1.54 (−4.47 to 1.39); 4 (409); I^2^=0%; Daytime DBP: −1.13 (−3.37 to 1.12); 4 (409); I^2^=0%; 24-Hour SBP: −2.15 (−5.05 to 0.75); 4 (409); I^2^=0%; 24-Hour DBP: −2.06 (−4.12 to −0.00); 4 (409); I^2^=0%; Hypertensive; Nighttime SBP: −3.94 (−6.46 to −1.43); 2 (530); I^2^=0%; Nighttime DBP: −3.03 (−5.28 to −0.79); 2 (530); I^2^=45%; Daytime SBP: −2.70 (−4.92 to −0.47); 2 (530); I^2^=0%; Daytime DBP: −2.40 (−3.88 to −0.92); 2 (530); I^2^=0%; 24-Hour SBP: −2.53 (−4.30 to −0.76); 5 (986); I^2^=0%; 24-Hour DBP: −2.23 (−3.42 to −1.03); 5 (986); I^2^=0%; Mean 24-Hour BP: −2.16 (−3.59 to −0.72); 4 (627); I^2^=0%
Zhang, 2016^126^ | CPAP vs. control; Eligibility limited to trials enrolling populations with minimally symptomatic, asymptomatic, or nonsleepy OSA | 7 (April 1, 2016) | Mean Age: 51.9–66.0; % Female: 9–24; Race/Ethnicity: NR; Mean BMI: 28.5–33.2; Mean AHI: 28.8–55.4; Mean ESS:4.6–7.95; OSA Severity: NR; % HTN: 24.5–77; % HF: NR | Mean Difference (95% CI); SBP: −0.51 (−3.39 to 2.38); 5 (1,541); I^2^=84%; DBP: −0.92 (−1.39 to −0.46); 5 (1,541); I^2^=0.0%; AHI or ODI: −15.57 (−29.32 to −1.82); 3 (1,541); I^2^=87.2%

* Characteristics are for all included studies in the reviews, not limited to the subset that report on AHI or blood pressure outcomes.

† Three studies reporting on BP outcomes enrolled populations with mild-severe OSA, and one each enrolled populations with moderate to severe and mild to moderate.

ǂ Defined as the proportion who were on blood pressure medication.

§ This includes mixed populations of normotensives and hypertensives, many treated with antihypertensive medications.

ǁ Defined as participants treated with ≥3 antihypertensive medications.

Abbreviations: AHI=apnea-hypopnea index; BMI=body mass index; BP=blood pressure; CI=confidence interval; CPAP=continuous positive airway pressure; DBP=diastolic blood pressure; ESS=Epworth Sleepiness Scale; HF=heart failure; HTN=hypertension; KQ=key question; N=number; NR=not reported; ODI=oxygen desaturation index; OSA=obstructive sleep apnea; PAP=positive airway pressure; pbo=placebo; SBP=systolic blood pressure; vs.=versus.

Appendix E Table 2 Characteristics of Included Randomized, Controlled Trials Comparing CPAP and Sham CPAP (KQs 5 and 6)

First Author, Year; Design; Trial Name | G1 (N); G2 (N) | Source of Patients | Screen Detected? | Country | Duration, Weeks | Mean (Range) Age | % F | Race/Ethnicity % | Mean BMI | Mean AHI | Mean ESS | OSA Severity | % HTN;; % HF | Benefits Quality
Arias, 2005^128^; Cross-over | Total (37); nCPAP first (14); Sham nCPAP first (13) | NR | No | Spain | 12 active; 12 sham | 52 | 0 | NR | 31 | 44 | NR | Mild to severe | 0;; 0 | Fair
Barbe, 2001^127^; Parallel | nCPAP (29); Sham CPAP (26) | Sleep clinic | No | Spain | 6 | 53 | 9 | NR | 29 | 54–57 | 7 | Severe only | NR;; 0 | Fair
Campos-Rodriguez, 2006^129^; Parallel | CPAP (36); Sham CPAP (36) | Sleep center | No | Spain | 4 | 57 | 40 | NR | 34–36 | 58–60 | 14–15 | Mild to severe | 100%;; NR^†^ | Fair
Chasens, 2014^130^; Parallel | CPAP (12); Sham CPAP (11) | Community | No | United States | 4 | 56 | 39 | Black/biracial: 52 | 36 | 39 | 11 | Mod to severe | NR;; NR | Fair
Chong, 2006^131^; Parallel | CPAP (19); Sham CPAP (20) | Ads, referrals | No | United States | 3 | 78 | 26 | Non-Caucasian: 5 | 24–25 | RDI 26–31 | 8–9 | Mild to severe | NR;; 0 | Fair
Coughlin, 2007^132^; Cross-over | Total (35); CPAP first (18); Sham first (17) | Sleep center | No | United Kingdom | 6 active; 6 sham | 49 | 0 | NR | 36 | RDI 40 | 14 | Mod to severe | 79;; 0 | Good
Durán-Cantolla, 2010^133^; Parallel | CPAP (169); Sham (171) | Referrals to 11 general hospitals | No | Spain | 12 | 52 | 19 | NR | 32 | 43–45 | 10 | Mod to severe | 100 per GP, but 64 vs. 56 from ABPM;; NR | Good
Egea, 2008^134^; Parallel | Overall^‡^; CPAP (35); Sham CPAP (38) | Referral from cardiology to sleep center | No | Spain | 12 | 63 | 4–9 | NR | 31–32 | 41–43 | 7–8 | Mild to severe | NR;; 100 | Fair
Haensel, 2007^135^; Parallel | CPAP (25); Sham CPAP (25) | Ads, word of mouth, referrals | No | United States | 2 | 49 | 20 | White: 60; Black: 12; Hispanic: 12; Asian: 6; Other: 10 | 33 | 58–64 | NR | Mod to severe | 14;; 0 | Fair
Hoyos, 2012^136^; Parallel | CPAP (34); Sham CPAP (31) | Sleep clinics | No | Australia | 12 | 49 | 0 | NR | 31–32 | 39–42 | 10 | Mod to severe | 34;; NR | Fair
Hui, 2006^137^; Parallel | nCPAP (28); Sham CPAP (28) | Respiratory clinic | No | Hong Kong | 12 | 51 | 23 | NR | 27 | 31 | 11 | Mild to severe | 50;; NR | Fair
Jenkinson, 1999^138^; Hack, 2000^139^; Parallel | nCPAP (54); Sham nCPAP (53) | Referred to sleep clinic | No | United Kingdom | 4 | Median 48–50 (33–71) | 0 | NR | 35 | ODI (>4%): Median 36–38 | Median 16–17 | Mild to severe | 19;; NR | Fair
Jones, 2013^140^; Cross-over | Total (53)^§^; CPAP first (25); Sham CPAP first (27) | Sleep medicine department | No | United Kingdom | 12 CPAP; 12 sham | 46 | 35 | NR | Med-ian 30 | Median 31 | Median 13 | Mod to severe | NR;; NR | Fair
Kushida, 2012^141^; Batool-Anwar, 2016^142^; Parallel; APPLES | CPAP (558); Sham (547) | Sleep clinics (5 hospitals) | No | United States | 24 | 52 | 35 | White: 76; Non-White: 24 | 32 | 40–41 | 10 | Mild to severe | NR;; 0 | Fair
Lam, 2010^143^; Parallel | nCPAP (31); Sham nCPAP (30) | Sleep center | No | Hong Kong | 1 | 46 | 0 | NR | 28 | 40 | 10–11 | Mod to severe | NR;; NR | Fair
Lee, 2011^144^; Parallel | Total (38); CPAP (17); Sham CPAP (21) | Ads and word of mouth | No | United States | 3 | 47 | NR | African American: 8; White: 89; Other: 3 | 28–29 | 29–33 | 7–10 | Mild to severe | 5;; 0 | Fair
Loredo, 2006^145^; Parallel | CPAP (22); Sham (19)^¶^ | Ads and sleep labs | No | United States | 2 | 48 | 17 | NR | 32 | 58–66 | 12 | Mod to severe | NR;; 0 | Fair
Malow, 2008^219^; Parallel | Total (35); CPAP (22); Sham CPAP (13) | Epilepsy clinic | No | United States | 10 | 42 | 43 | NR | 32–35 | 16–19 | NR | Mild to severe | 22%;; NR | Fair
Marshall, 2005^146^; Cross-over | Total (31); CPAP first (15); Sham first (16) | Sleep clinics | No | New Zealand | 3 active; 3 sham | 51 (25–67) | 24 | NR | 32 | 22 | 13 | Mild to mod | NR;; NR | Good
Melehan, 2018^147^; Parallel | CPAP (31); Sham CPAP (30) | NR | No | Australia | 12 | 54 | 0 | NR | 33 | 44–48 | 10 | Severe only | 47–58;; NR | Fair
Montserrat, 2001^148^; Parallel | CPAP (24); Sham CPAP (24) | Sleep clinic | No | Spain | 6 | 54 | NR | NR | 30–34 | 54 | 16–17 | Moderate to severe | NR;; 0 | Fair
Neikrug, 2014^149^; Parallel | CPAP (19); Sham nCPAP (19) | Neurologist^††^ referral and volunteer | No | United States | 3 | 67 | 32 | NR | 27–28 | 22 | NR | Mild to severe | NR;; NR | Fair
Nguyen, 2010^150^; Parallel | nCPAP (10); Sham nCPAP (10) | Sleep clinic | No | United States | 12 | 53 | 10 | Non-Caucasian: 40 | 30 | 32–39 | NR | Mod to severe | 100;; 0 | Fair
Pepperell, 2002^151^; Kohler, 2008^152^; Parallel | CPAP (59); Sham CPAP (59) | Referred by ENTs, GPs, or consultants | No | United Kingdom | 4 | 51 | 0 | NR | 35 | NR | 16 | Mild to severe | 19;; NR | Fair
Phillips, 2011^153^; Cross-over | Total (38); CPAP first (18); Sham CPAP first (19) | Referrals from tertiary clinics | No | Australia | 8 active; 8 sham | 49 | 11 | NR | 32 | 38 | 10 | Mod to severe | 32;; NR | Fair
Robinson, 2006^154^; Cross-over | Total (35); CPAP first (18); Sham first (17) | Sleep center | No | United Kingdom | 4 active; 4 sham | 54 | 11 | NR | 33 | ODI: median 28 | 5 | Mild to severe | 100;; NR | Fair
Siccoli, 2008^155^; Parallel | CPAP (51); Sham CPAP (51) | Sleep center | No | United Kingdom | 4 | 48 | 0 | NR | 35–36 | NR | 15-16 | Mod to severe | NR;; NR | Fair
Smith, 2007^156^; Cross-over | Total (24); CPAP first (11); Sham first (13) | Cardiology clinics | No | United Kingdom | 6 active; 6 sham | 61 | 12 | NR | 31 | 36 | 10 | Mod to severe | 42;; 100 | Fair
Weaver, 2012^157^; Parallel; CATNAP | CPAP (141)^§§^; Sham CPAP (140) | Respiratory Clinics | No | United States and Canada | 8 | 51 | 37–45 | African American: 16–17^‖‖^ | 33–34 | 13 | 15 | Mild to mod | 40;; 2 | Fair
Weinstock, 2012^201,^ ^220^; Cross-over | Total (50); CPAP first (25); Sham CPAP first (25) | Sleep clinics, prior studies and ads | No | United States | 8 active; 8 sham | 54 | 58 | Black: 40 | 38–39 | 32–44 | NR | Mod to severe | NR;; NR | Fair
West, 2007^158^; West, 2009^159^; Parallel | CPAP (21); Sham CPAP (21) | Sleep center | No | United Kingdom | 12 | 56 | 0 | NR | 37 | NR | 14–15 | Mild to severe | NR;; NR | Fair

† Those with NYHA class III-IV HF were excluded.

‡ The overall study included some subjects with CSA. The numbers randomized who had OSA only was NR; the study reported number of completers who had OSA only (CPAP, 20 vs. sham CPAP, 25).

§ One person dropped out before beginning a treatment, but unclear if it was before or after randomization and unclear which group they were in.

‖ Forty-eight randomized but unclear how many to each group; 23 and 18 completed.

¶ The study also had a sham+oxygen (N=22) arm. These Ns and baseline characteristics are for completers.

†† Patients with Parkinson’s disease.

§§ These are the numbers randomized including the post-randomization drop-outs. 42 participants withdrew before exposure to CPAP or sham and were excluded from all analyses. Ns randomized and exposure were as follows: active CPAP=121; sham CPAP=118. All characteristics are for those randomized and exposed.

‖‖ These percentages are based on the sample of randomized and exposed participants, not the original N randomized of 281.

Abbreviations: ABPM=ambulatory blood pressure monitor; AHI=apnea-hypopnea index; APPLES=Apnea Positive Pressure Long-term Efficacy Study; BMI=body mass index; CATNAP=CPAP Apnea Trial North American Program; CPAP=continuous positive airway pressure; CSA=central sleep apnea; dur=duration; ENT=otolaryngologist; ESS=Epworth Sleepiness Scale; F=female; G=group; GP=general practitioner; HF=heart failure; HTN=hypertension; mod=moderate; KQ=key question; N=sample size; nCPAP=nasal continuous positive airway pressure; NR=not reported; NYHA=New York Heart Association; ODI=oxygen desaturation index; OSA=obstructive sleep apnea; pts=patients; RDI=respiratory disturbance index.

Appendix E Table 3 Characteristics of Included Randomized, Controlled Trials Comparing CPAP and Control (KQs 5 and 6)

First Author, Year; Design; Trial Name | G1 (N); G2 (N) | Source of Patients | Screen Detected? | Country | Duration, Weeks | Mean (Range) Age | % F | Race/Ethnicity % | Mean BMI | Mean AHI | Mean ESS | OSA Severity | % HTN;; % HF | Benefits Quality
Ballester, 1999^160^; Parallel | CPAP (68); Usual care (37) | NR | No | Spain | 12 | 53 | 12 | NR | 32 | 56 | 12 | Mod to severe | NR;; NR | Fair
Banghøj, 2021^161^; Parallel | CPAP (36); Control (36) | Hospitals | No | Denmark | 12 | 63 | 22 | NR | 33–36 | 35 | 7 | Mod to severe | NR;; NR | Fair
Barbe, 2010^162^; Parallel | CPAP (178); conservative treatment for HTN (181) | Sleep clinics | No | Spain | 52 | 55–56 | 15–18 | NR | 32–33 | 43–49 | 6 | Mod to severe | 100;; NR | Fair
Barbe, 2012^163^; Parallel | CPAP (357); Control (366) | Teaching hospitals | No | Spain | Median 208^*^ | 52 | 14 | NR | 31 | Median 35–42 | 7 | Mod to severe | 50–53;; NR | Fair
Barnes, 2004^164^; Cross-over | CPAP (97)^†^; Pbo (98) | Referrals | No | Australia | 12 active; 12 pbo | 47 | 20 | NR | 31 | 21 | 11 | Mild to mod | 15;; NR | Fair
Campos-Rodriguez 2016^165^; Parallel | CPAP (151); Control (156) | Sleep centers | No | Spain | 12 | 57 | 100 | NR | 34 | 32 | 10 | Mod to severe | NR;; NR | Fair
Craig, 2012^166^; Parallel; MOSAIC | CPAP (195); Standard care^ǂ^ (196) | Sleep clinics | No | United Kingdom and Canada | 24 | 58 | 22 | NR | 32–33 | ODI >4% dips/hour: Median 9–10 | 8 | NR^§^ | 76–77;; NR | Fair
Dalmases, 2015^167^; Parallel | CPAP (17); Conservative (16) | Hospital | Yes | Spain | 12 | 71 | 30 | NR | 31 | 56 | 6–8 | Severe only | 85;; NR | Fair
Engleman, 1994^168^; Cross-over | Total (35)^¶^; CPAP first (17); Oral pbo first (15) | Referred due to symptoms | No | United Kingdom | 4 active; 4 pbo | 49 | 19 | NR | 33 | 28 | NR | Mild to severe | NR;; NR | Fair
Engleman, 1997^169^; Cross-over | Total (18); CPAP first (10); Oral pbo first (8) | Referral to sleep clinic | No | United Kingdom | 4 active; 4 pbo | 52 | 25 | NR | 30 | 11 | 14 | Mild only | NR;; NR | Fair
Engleman, 1998^170^; Cross-over | Total (23); CPAP first (10); Pbo (13) | Sleep center | No | United Kingdom | 4 active; 4 pbo | 47 | 9 | NR | 30 | 43 | 12 | Mod to severe | NR;; NR | Fair
Engleman, 1999^171^; Cross-over | Total (37); CPAP first (NR); Oral pbo first (NR) | Sleep clinic | No | United Kingdom | 4 active; 4 pbo | 44 | 38 | NR | 30 | 10 | 13 | Mild only | NR;; NR | Fair
Faccenda, 2001^172^; Cross-over | Total (71); CPAP first (35); Pbo capsule first (36) | Sleep center | No | United Kingdom | 4 active; 4 pbo | Median 50 (29–72) | 18 | NR | Medi-an 30 | Median 35 | Median 15 | Mod to severe | 0;; NR | Fair
Gottlieb, 2014^173^; Lewis, 2017^174^; Parallel; HeartBEAT | CPAP+usual care^‖^ (106); Usual care alone (106)^¶^ | Cardiology practices | Yes, Berlin^#^ | United States | 12 | 63 | 26 | Caucasian: 83–86; Black: 7–12; Asian: 2–3; Other: 3–6 | 34 | 25 | 8–10 | Mod to severe | 89;; NR | Good
Jackson, 2021^175^; Jackson, 2019^176^; Parallel | CPAP (82); Wait-list (39) | Sleep clinic | No | Australia | 16 | 52 | 42 | NR | 35 | NR | 8 | Mild to severe | NR;; NR | Fair
Lam, 2007^177^; Parallel | CPAP (34)^**^; Usual care (33)^††^ | Sleep center | No | Hong Kong | 10 | 46 | 21 | NR | 27 | 21 | 12 | Mild to severe | 19;; NR | Fair
Lim, 2007^178^; Parallel | nCPAP (17); Sham CPAP (14) | Ads, word of mouth, referrals | No | United States | 2 | 48 | NR | NR | 31–32 | 64–66 | 11–13 | Mod to severe | NR;; 0 | Fair
Lui, 2020^179^; Parallel | CPAP (45); Control (45) | Sleep clinics | No | Hong Kong | 4 | 47 | 18 | NR | 30 | 58 | 11 | Severe only | NR;; NR | Fair
Martinez-Garcia, 2013^180^; Parallel; HIPARCO | CPAP (98); No CPAP (96) | HTN clinical units | No | Spain | 12 | 56 | 31 | NR | 34 | 40 | 9 | Mod to severe | 100 (resist-ant HTN)^ǂǂ^;; NR | Good
Martinez-Garcia, 2015^181^; Parallel | CPAP (115); No CPAP (109) | Sleep lab and centers | No | Spain | 12 | 76 | 32 | NR | 33 | 50 | 10 | Severe only | 80;; NR | Fair
Masa, 2015^182^; Parallel; Pickwick | Total (150); CPAP (80); Lifestyle modification control (70) | Hospitals | Yes | Spain | 8 | 60 | 47–56 | NR | 44–45 | 69–71 | 11 | Severe only | 62-65;; 13-16 | Fair
McArdle, 2001^183^; Cross-over | Total (23); CPAP first (NR); Pbo capsule first (NR) | Sleep center | No | United Kingdom | 4 active; 4 pbo | 53 | 13 | NR | 31 | Median 40 | Median 14 | Mod to severe | NR;; NR | Fair
McMillan, 2014^184^; Parallel; PREDICT | CPAP + best supportive care (BSC) (140); BSC only (138) | Sleep centers (14) | No | United Kingdom | 52 | 71 | 18 | White: 96; Asian: 3; Other: 1 | 34 | ODI (>4% dips per hour): 28–29 | 12 | Mild to severe | 73;; 6 | Good
Ng, 2018^197^; Parallel | CPAP (17); Conservative treatment (20) | Hospital respiratory clinic | No | Hong Kong | 12 | 52 | 53–80 | NR | 26–28 | 19–22 | 8–10 | Mild to severe | NR;; NR | Fair
Peker, 2016^185–187,^ ^198,^ ^200^; Parallel; RICCADSA | Total (244); CPAP (122); No CPAP (122) | Hospitals | Yes | Sweden | 312 | 66 | 14–18 | NR | 28–29 | 28–29 | 6 | Mod only | 59–69;; NR | Fair
Ponce, 2019^188^; Parallel | CPAP (73); No CPAP (72) | Teaching clinical center | No | Spain | 12 | 75 | 35^§§^ | NR | 30 | 22 | 9 | Mod only | NR;; NR | Fair
Redline, 1998^189^; Parallel | nCPAP (59); Conservative therapy^‖‖^ (52) | Ads and referrals | No | United States | 8–12 | 48 | 48 | Non-European American (majority African American): 38; European American: 62 | 32–33 | RDI 13 | 10–11 | Mild to mod | NR;; 0 | Fair
Ruttanaum-pawan, 2008^190^; Kaneko, 2003^191^; Parallel | CPAP (19); Usual care (14) | HF clinic | Yes, ESS | Canada | 4 | 60 | 9 | NR | 30–32 | 36–51 | NR | Mod to severe | 42–58;; 100 | Fair
Salord, 2016^192^; Parallel | CPAP (42); Conservative (38) | Sleep clinics | No | Spain | 12 | 47 | 73 | NR | 47 | 56 | 8 | Severe only | NR;; NR | Good
Shaw, 2016^193^; Parallel | CPAP+usual care (151); Usual care (147) | Hospitals and specialist clinics | No | Australia and North America | 24 | 62 | 36 | White: 84; Black: 6; Hawaiian/Pacific Islander: 1; Asian: 8; Other or unknown: 1 | 33 | 26–28 | 9–10 | Mod to severe | NR;; NR | Fair
Tomfohr, 2011^194^; Parallel | CPAP (34); Pbo CPAP (37) | Ads and referrals | No | United States | 3 | 48 | 14 | Caucasian: 86; Asian: 2; African American: 10; Other: 2 | 29–31 | 32–39 | 9–11 | Mild to severe | NR;; NR | Fair
Traaen, 2021^199^; Parallel; A3 | CPAP+usual care (55); Usual care (54) | Outpatient cardiology clinics | Yes | Norway | 24 | 63 | 24 | NR | 29–30 | Median 21–23 | 8 | Mod to severe | 39–43;; NR | Fair
Wimms, 2020^195^; Parallel; MERGE | CPAP (115); Control (118) | Sleep centers | No | United Kingdom | 12 | 50 | 31 | White: 89; Non-White: 11 | 30 | Median 10–11 | 10 | Mild only | 24–33;; NR | Fair
Zhao, 2017^196^; Parallel; BestAIR | CPAP (83); Control (86) | Outpatient clinic | No | United States | 48 | 64 | 35 | White: 89; Black: 7; Hispanic: 4; Other: 4 | 32 | 29 | 8–9 | Mod to severe | 85;; NR | Fair

* Followup was “time until a CVD event, loss to followup or the end of the study” and ranged from 0 to 5.38 years, with a median of 4.0 years (*IQR=2.19–4.38).

† Study also had an MAD arm. Because six different orders were possible, they did not list out individuals’ actual order. Numbers represent the number of people who started treatment in that arm (104 participants total; 80 completed all three arms).

ǂ One followup visit with a physician between randomization and the final visit at 6 months.

§ Had to have >7.5 oxygen desaturations per hour of >4%, but had insufficient daytime symptoms associated with OSA to warrant CPAP therapy. This was made based on discussion with physician based on benefits of CPAP vs. potential lifelong nightly usage of CPAP.

‖ Usual care was defined as “healthy lifestyle and sleep education.”

¶ Study also included an oxygen plus usual care arm (N=106).

# Eligible patients were required to have Berlin Questionnaire score of 2 or 3 and established CAD or multiple CVD risk factors.

** Study also included a MAD arm.

†† Authors defined as “mild to moderate,” but allowed AHI up to 40, and the range of included patients included some with severe OSA.

ǂǂ BP remained above goal despite treatment with 3 or more antihypertensive medications.

§§ We used the data from Table 1 and not the text of the publication. There was a discrepancy between the two.

‖‖ Conservative therapy for all patients consisted of sleep hygiene counseling, weight loss referrals for patients who were overweight, and nasal steroid spray for those with nasal congestion. Control participants also received nasal dilator strips.

Abbreviations: A3=Atrial Fibrillation, Apnea, Airway Pressure; AHI=apnea-hypopnea index; BestAIR=Best Apnea Interventions for Research; BMI=body mass index; BP=blood pressure; BSC=best supportive care; CAD=coronary artery disease; CPAP=continuous positive airway pressure; CVD=cardiovascular disease; dur=duration; ESS=Epworth Sleepiness Scale; F=female; G=group; HeartBEAT=Heart Biomarker Evaluation in Apnea Treatment; HF=heart failure; HTN=hypertension; IQR=interquartile range; KQ=key question; MAD=mandibular advancement device; mod=moderate; MOSAIC=Multicentre Obstructive Sleep Apnoea Interventional Cardiovascular; N=sample size; nCPAP=nasal continuous positive airway pressure; NR=not reported; ODI=oxygen desaturation index; OSA=obstructive sleep apnea; pbo=placebo; pts=patients; RDI=respiratory disturbance index; RICCADSA=Randomized Intervention with Continuous Positive Airway Pressure in CAD and OSA; tx=treatment.

Appendix E Table 4 Results of Included Randomized, Controlled Trials Assessing CPAP: Health Outcomes (KQ 5)

First Author, Year; Trial Name | G1 (N); G2 (N) | Mortality, N (%) | Quality of Life | Cognitive Impairment | MVAs, N (%) | CV Events, N (%) | CBV Events, N (%) | Heart Failure, N (%) | Headache, N (%)
Arias, 2005^128^ | Total (27) nCPAP first (14); Sham nCPAP first (13) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR
Ballester, 1999^160^ | CPAP (68); Usual care (37) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR
Banghøj, 2021^161^ | CPAP (36); Control (36) | 0 (0.0); 1 (2.8) | NR | NR | NR | NR | NR | NR | NR
Barbe, 2001^127^ | Total (55); CPAP (29); Sham CPAP (26) | 0 (0.0); 0 (0.0) | FOSQ, mean (SE); BL; CPAP: 102 (3); Sham: 107 (3); 6 weeks; CPAP: 108 (2); Sham: 110 (2); Change from BL; CPAP: 7 (2); Sham: 3 (3); Between-group diff: p>0.2; SF-36 PCS, mean (SE); BL; CPAP: 49 (1); Sham: 48 (1); 6 weeks; CPAP: 51 (1); Sham: 50 (1); Change from BL; CPAP: 2 (1); Sham: 1 (1); Between-group diff: p>0.2; SF-36 MCS, mean (SE); BL; CPAP: 51 (2); Sham: 50 (2); 6 weeks; CPAP: 51 (2); Sham: 52 (2); Change from BL; CPAP change: −1 (2); Sham change: 1 (2); Between-group diff: p>0.2 | Hits on SteerClear test, mean (SE) %; Baseline; CPAP: 5 (1); Sham: 6 (2); 6 weeks; CPAP: 4 (1); Sham: 5 (2); Change from BL; CPAP: −1 (1); Sham: −1 (1); Between-group diff: p>0.2; Also reported: WAIS digit symbols, block design, digit span, PASAT 1-4, Trail Making test A and B, Wechsler memory scale | NR | NR | NR | NR | NR
Barbe, 2012^163^ | CPAP (357); Control (366) | All cause:^*^; 8 (2.2); 3 (0.8); CVD specific:; 1 (0.3); 0 (0.0) | NR | NR | NR | Total:; 19 (5.3); 19 (5.2); CV^†^ Hospitalizations:; 17 (4.8); 11 (3.0); Nonfatal myocardial infarction:; 2 (0.6); 8 (2.2) | TIA:; 2 (0.6); 5 (1.4); Nonfatal stroke:; 3 (0.8); 2 (0.5) | 3 (0.8); 5 (1.4) | NR
Barnes, 2004^164^ | CPAP (97); Pbo (98) | 0 (0.0); 0 (0.0) | FOSQ mean score, mean (SE):; Baseline: 3.1 (0.1); 3.3 (0.1), p<0.001; 3.3 (0.1), p<0.01; CPAP vs. pbo; p<0.05 | Reported: Word Pair Memory Recall; Logical Memory Test; Digit Span Backwards; Trail Making B; Digit Symbol Substitution Task; COWAT; PVT; Stroop Color Association Test | NR | NR | NR | NR | NR
Campos-Rodriguez 2016^165^ | CPAP (151); Control (156) | NR | SF-12 Physical, between-group diff (95% CI): 2.78 (0.96 to 4.61), p=0.003; SF-12 Mental, between-group diff (95% CI): 1.27 (−1.01 to 3.56), p=0.27; Reports QSQ hyper-somnolence, diurnal symptoms, nocturnal symptoms, emotions, and social interaction | NR | NR | NR | NR | NR | NR
Craig, 2012^166^; MOSAIC | CPAP (195); Standard care (196) | 1 (0.5); 0 (0.0) | MCS, Mean (SD); BL:; 48.2 (10.4); 46.6 (11.3); 24 weeks:; 52.0 (9.8); 48.5 (11.0); Between-group diff:; 2.6 (95% CI, 0.9 to 4.2; p=0.003); EQ-5D score, Mean (SD)^ǂ^; BL:; 0.80 (0.17); 0.75 (0.24); 24 weeks:; 0.83 (0.19); 0.80 (0.22); Between-group diff:; +0.20 (95% CI, −0.03 to 0.06; p=0.43); SAQLI, mean (SD); BL:; 4.9 (1.1); 4.8 (1.2); 24 weeks:; 5.6 (1.0); 5.0 (1.3); Mean change (SE); 0.7 (0.1); 0.2 (0.1); Between-group diff: p<0.0001 | NR | NR | Angina:; 1 (0.6); 3 (1.7); MI:; 0 (0.0); 0 (0.0); PVD:; 2 (1.2); 1 (0.6); AF:; 6 (3.5); 7 (4.1) | TIA:; 1 (0.6); 0 (0.0); Stroke:; 0 (0.0); 0 (0.0) | NR | NR
Dalmases, 2015^167^ | CPAP (17); Conservative (16) | NR | Reports QSQ total, sleepiness, diurnal symptoms, nocturnal symptoms, emotions, and social interaction scores | Reports RAVLT, Digit Span Forward, Digit Span Backward, Digit symbol, Trail Making A, Trail Making B, Semantic Fluency, Phonemic fluency | NR | NR | NR | NR | NR
Durán-Cantolla, 2010^133^ | CPAP (169); Sham (171) | 0 (0.0); 0 (0.0) | EuroQol, mean (SD) at baseline, 6 weeks, 12 weeks; CPAP 69 (15), 74 (14),^§^ 76 (16)^‖^; Sham CPAP 72 (17), 72 (16), 73 (15) | NR | NR | NR | NR | NR | NR
Egea, 2008^134^ | CPAP^¶^ (35); Sham CPAP (38) | 0 (0.0); 1 (2.6) | OSA Only; SF-36 PCS, Mean (SE); BL:; 41.4 (2.0); 42.0 (2.1); 12 weeks; 44.9 (1.8), p=0.10; 40.7 (2.1), p=0.41; Between-group diff: p=NS; SF-36 MCS, Mean (SE); BL:; 46.4 (3.0); 45.8 (2.7); 12 weeks; 48.8 (2.3), p=0.40; 48.7 (2.2), p=0.27; Between-group diff: p=NS | NR | NR | Angina; 0 (0.0); 1 (2.6) | NR | NR | NR
Engleman, 1994^168^ | CPAP first (17); Oral pbo first (15) | 0 (0.0); 0 (0.0) | NHP-2, 4 weeks:; 4.9 (SE 0.9); 7.9 (SE 0.9); Between-group diff; p=0.002; CPAP > pbo (p<0.05) for social life, sex life, and ability to carry out domestic chores | Mental flexibility (Trail Making B); 66 (SE 5); 75 (SE 5); Between groups p=0.02; Coding efficiency (Digit symbol substitution); 52 (SE 2); 51 (SE 2); Between groups p=0.05; Vigilance (Steer Clear, N objects hit); 76 (SE 5); 81 (SE 6); Between groups p=0.01; IQ decrement score; 4.0 (SE 2.1); 7.2 (SE 2.0); Between groups p=0.04; Concentration (PASAT 2); Between groups p=0.02; however, after adjustment for order effect, p=0.11 | NR | NR | NR | NR | NR
Engleman, 1997^169^ | CPAP first (8); Oral pbo first (8) | 0 (0.0); 0 (0.0) | Nottingham Health Profile Part 2, total score; 4 weeks; 3.8 (SE 1.1); 5.8 (SE 1.4); Between groups p=NS | Reports IQ decrement, Trail Making, SteerClear, PASAT2, RVIPT, reaction time, verbal fluency, BVRT; Only significant changes on Trail Making B; no changes on other various cognitive functioning measures | NR | NR | NR | NR | NR
Engleman, 1998^170^ | CPAP first (10); Pbo (13) | 0 (0.0); 0 (0.0) | NHP-2; Baseline, mean (SD); 8.0 (5.0); 4 weeks, mean (SD); 5.8 (5.4); 6.3 (5.7); Between-group change:; −0.5 (95% CI, −2.5 to 1.5; p=NS) | No significant difference between groups on changes in the following: 30-minute SteerClear; Trail Making B; WAIS-R performance IQ (Block Design and Digit Symbol Substitution); NART; RVIP;^#^ 8-choice reaction time; PASAT;^**^ Verbal fluency; BVRT^††^ | NR | NR | NR | NR | NR
Engleman, 1999^171^ | Total (37); CPAP first (NR); Oral pbo first (NR) | 0 (0.0); 0 (0.0) | NHP-2 score, mean (SD); Baseline: 10.5 (4.8); 4 weeks CPAP: 6.1 (4.7); 4 weeks pbo: 7.3 (5.2); Between groups p=NS; SF-36 Domains only:; Physical Function; Baseline: 75 (27); 4 weeks CPAP: 84 (22); 4 weeks pbo: 83 (23); Between groups p=NS; Mental health; Baseline: 64 (19); 4 weeks CPAP: 79 (16); 4 weeks pbo: 75 (15); Between groups p=NS; General Health; Baseline: 68 (21); 4 weeks CPAP: 76 (19); 4 weeks pbo: 74 (20); Between groups p=NS | SteerClear (obstacles hit), mean (SD); Baseline: 295 (183); 4 weeks CPAP: 189 (156); 4 weeks pbo: 195 (158); Between groups p=NS; Also reported Trail Making A, Trail Making B, Digit Symbol, Block Design, performance IQ, PASAT | NR | NR | NR | NR | 0 (0.0); 3 (8.8)
Faccenda, 2001^172^ | Total (71); CPAP first (35); Pbo capsule first (36) | 0 (0.0); 0 (0.0) | FOSQ total, mean change from baseline (SE):; 12.4 (0.5); 11.6 (0.7); p=0.010 | NR | NR | NR | NR | NR | NR
Gottlieb, 2014^173^; Lewis, 2017^174^; HeartBEAT | CPAP+ usual care (106); Usual care alone (106) | 0 (0.0); 0 (0.0) | SF-36 MCS, mean (SD); BL; 48.9 (11); 48.9 (12.3); 12 weeks; 52.6 (10); 49.7 (11); Within-group diff; 3.7 (8.2), p=0.001; 0.8 (8.1), p=0.3342; Between-group diff (95% CI): 2.88 (0.9 to 4.87), p=0.005; SF-36 PCS mean (SD); BL; 44.7 (9.5); 43.6 (9); 12 weeks; 44.6 (10.2), p=0.8275; 42.9 (9.3), p=0.2211; Within-group diff; −0.1 (5.1), p=0.8275; −0.8 (6.4), p=0.2211; Between-group diff (95% CI): 0.86 (−0.77 to 2.49), p=0.3 | NR | 0 (0.0); 0 (0.0) | Unstable angina:; 0 (0.0); 1 (0.9); MI:; 0 (0.0); 1 (0.9); AF:; 1 (0.9); 0 (0.0); Arrhythmia^ǂǂ^; 0 (0.0); 1 (0.9) | Stroke:; 0 (0.0); 1 (0.9) | NR | NR
Haensel, 2007^135^ | CPAP (25); Sham CPAP (25) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR
Jenkinson, 1999^138^; Hack, 2000^139^ | CPAP (54); Sub-therapeutic CPAP (53) | 0 (0.0); 0 (0.0) | SF-36 MCS, mean (SD); BL:; 44.8 (10.4); 43.5 (10.7); 4 weeks:; 55.4 (7.0); 47.8 (10.1); Between-group diff: p=0.002; SF-36 PCS, mean (SD):; BL:; 43.7 (11.6); 42.6 (10.1); 4 weeks:; 49.4 (10.1); 45.5 (10.4); 5.7 (NR); p<0.001; 2.9 (NR); p=0.007; Between-group diff: p=0.080 | | NR | NR | NR | NR | NR
Kushida, 2012^141^ Batool-Anwar, 2016^142^; APPLES | CPAP (558); Sham (547) | 2 (0.4); 2 (0.4) | SAQLI, mean (SD); Compliance <4 hours; BL:; 4.7 (0.8); 4.6 (0.8); 6 months:; 4.7 (0.8); 4.6 (1.0); Between-group change: p≥0.05; Compliance >4 hours; BL:; 4.7 (0.8); 4.8 (0.8); 6 months:; 5.0 (0.7); 4.9 (0.7); Between-group diff: p<0.05 | No difference between groups on multiple measures of neurocognitive function (Pathfinder NumberTest, Buschke Selective Reminding Test, Sustained Working Memory Test) | 10 (1.8); 11 (2.0) | CV events reported as “adverse events” but not defined:; 31 (5.6); 29 (5.3) | NR^§§^ | NR | NR
Lam, 2007^177^ | CPAP (34); Usual care (33) | 0 (0.0); 0 (0.0) | SAQLI total score, mean (SE); BL:; 5.0 (0.1); 5.1 (0.1); 10 weeks:; 5.5 (0.1); 5.0 (0.1); Between-group diff: 0.77 (−1.5 to 0.4); p=0.04; SF-36, mean (SEM); p-value of within-group change from baseline; between-group diff from BL vs. usual care; Physical function domain, Baseline; 84.7 (2.2); 82.3 (2.6); 10 weeks; 88.2 (1.7); p<0.05; p<0.05; 78.9 (3.6); General health domain, Baseline; 48.3 (3.1); 51.2 (3.3); 10 weeks; 58.9 (3.3); p<0.05; p=NS; 54.8 (3); Mental health domain, Baseline; 66.8 (2.5); 65.6 (2.5); 10 weeks; 71.8 (2.8); p=NS; p=NS; 68.0 (2.5) | NR | NR | NR | NR | NR | NR
Lee, 2011^144^ | Total (38); CPAP (17); Sham CPAP (21) | 0 (0.0); 0 (0.0) | NR | Measured: WAIS-III; Digit Symbol; Digit Span; Letter-Number Sequencing; Symbol Search; Brief Visuospatial Memory Test-Rev; Hopkins Verbal Learning Test-Rev; Trail Making A/B; Digit Vigilance; Stroop Color-Word; Word Fluency | NR | NR | NR | NR | NR
Lim, 2007^178^ | Total (46); nCPAP (17); Sham CPAP (14) | NR | NR | Reports multiple cognitive function outcomes | NR | NR | NR | NR | NR
Marshall, 2005^146^ | Total (31); CPAP first (15); Sham first (16) | 0 (0.0); 0 (0.0) | FOSQ total, mean (SE):; Baseline: 12.6 (0.3); 13.6 (0.3), p<0.01; 13.3 (0.3), p=ns; Between-group diff 0.3 (−0.5 to 1.1); SF-36 domains; Mental health; Baseline: 75 (3); 77 (2) p=NS; 80 (2) p<0.05; Between-group diff=-3 (−10 to 3) | Psychomotor vigilance task:; Mean (SE) reaction time (ms):; Baseline: 264 (5); 266 (5) p=NS; 259 (5) p=NS; Between-group diff=7 (−7 to 20); Mean (SE) lapses (>500 ms reaction time):; Baseline: 1.3 (0.3); 3.2 (0.7) p=NS; 3.3 (0.7) p=NS; Between-group diff=0.4 (−0.7 to 1.4); Errors, mean (SE):; Baseline: 2.8 (0.5); 3.2 (0.7) p=NS; 3.3 (0.7) p=NS; Between-group diff=-0.1 (−2.0 to 1.9) | NR | Nonfatal MI:; 0 (0.0); 1 (3.2) | NR | NR | NR
Martinez-Garcia, 2015^181^ | CPAP (115); No CPAP (109) | NR | Reports QSQ hypersomnol-ence, diurnal symptoms, nocturnal symptoms, emotions, and social interaction | Reports digit span, digit symbol, Trail Making A, and Trail Making B | NR | NR | NR | NR | NR
Masa, 2015^182^; Pickwick | Total (150); CPAP (80); Control (70) | NR | SF-36 MCS, mean (SD); BL:; 42.0 (14.0); 44.0 (12.0); 8 weeks:; 46.6 (NR); 45.2 (NR); Between-group diff: p=NS; SF-36 PCS, mean (SD):; Baseline:; 36.0 (10.0); 37.0 (11.0); 8 weeks:; 37.2 (NR); 37.2 (NR); Between-group diff: p=NS; FOSQ total, mean (SD):; BL:; 71.0 (21.0); 77.0 (23.0); 8 weeks:; 76.1 (NR); 75.3 (NR); Between-group diff: p=0.027 | NR | NR | NR | NR | NR | 0; NR
McMillan, 2014^184^; PREDICT | Total (278); CPAP+BSC (140); BSC only (138) | NR | SAQLI, baseline, mean (SD); 4.8 (1.2); 4.7 (1.2); 12 weeks, mean (SD); 5.3 (1.1); 5.0 (1.1); between groups p=0.005; 52 weeks, mean (SD); 5.5 (1.1); 5.1 (1.1); between groups p=0.001; SF-36 reported in figure only; authors reported improvement on the energy and vitality subscales | No difference between groups in cognitive function measures:; Digit symbol substitution; Trail Making B; Simple reaction time | 52 weeks:; 2 (3.0); 1 (1.0) | 52 weeks:; MI; 3 (2.1); 0 (0.0); New Angina; 2 (1.4); 3 (2.2); New AF; 6 (4.3); 12 (8.7); New PVD; 1 (0.3); 0 (0.0); All; 12 (4.3); 15 (10.1); between groups for all CV events p=0.72 | 52 weeks:; Stroke; 0 (0.0); 0 (0.0); “Mini-stroke”; 1 (0.3); 2 (1.4); between groups for all adverse CV events p=0.72 | NR
Melehan, 2018^147^ | CPAP (31); Sham CPAP (30) | NR | Numerical data NR. Authors note that overall scores for SF-36 and FOSQ did not change in the CPAP group (intention-to-treat population). | NR | NR | NR | NR | NR | NR
Montserrat, 2001^148^ | CPAP (24); Pbo CPAP (24) | 0 (0.0); 0 (0.0) | FOSQ total, mean change from baseline (SD):; 25.0 (NR); p<0.001; 14.5 (NR); p=0.008; Between groups p=0.12; SF36 MCS, mean change from baseline (SD):; 1.32 (NR); p=0.61; 4.92 (NR); p=0.006; Between groups p=0.52; SF36 PCS, mean change from baseline (SD):; 4.18 (NR); p=0.002; 1.62 (NR); p=0.36; Between groups p=0.23 | NR | NR | NR | NR | NR | NR
Neikrug, 2014^149^ | CPAP (19); Sham CPAP (19) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR
Ng, 2018^197^ | CPAP (17); Conservative treatment (20) | NR | SF36 MCS, mean change from baseline (SD):; 4.7 (22.9); p=NR; −2.8 (12.6); p=NR; Between groups p=0.243; SF36 PCS, mean change from baseline (SD):; 8.8 (17.6); p=NR; −0.8 (12.3); p=NR; Between groups p=0.061 | NR | NR | NR | NR | NR | NR
Nguyen, 2010^150^ | nCPAP (10), sham CPAP (10) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR
Peker, 2016^185–187,^ ^198,^ ^200^; RICCADSA | Total (244); CPAP (122); Control (122) | 7 (6); 9 (7) | SF-36 MCS, mean (SD); BL:; 51.8 (9.2); 52.3 (9.4); 52 weeks:; 54.2 (7.3); 52.1 (9.7); Between-group diff: p=NR; SF-36 PCS, mean (SD):; Baseline:; 45.2 (9.3); 44.9 (9.6); 52 weeks:; 44.1 (10.5); 45.4 (10.4); Between-group diff: p=NR | NR | NR | Total (repeat revasculariz-ation, acute MI, CV death, and acute hospital admissions for CVD); 61 (50); 61 (50); Repeat revasculariz-ation; 17 (14); 14 (11); Acute MI; 11 (9); 8 (7); CV death; 3 (2); 7 (6) | Stroke; 3 (2); 6 (5) | NR | NR
Phillips, 2011^153^ | Total (37); CPAP first (18); Sham CPAP first (19) | NR | FOSQ total, mean (SD):; Baseline:; 15.2 (3.1); 8 weeks, mean (SE):; 16.0 (0.53); 16.7 (0.52); Between groups p=0.056 | NR | NR | NR | NR | NR | NR
Ponce, 2019^188^ | CPAP (73); No CPAP (72) | NR | | Also reported digit span and symbol test | NR | NR | NR | NR | NR
Redline, 1998^189^ | Total (111); nCPAP (59); Conservative therapy (52) | 0 (0.0); 0 (0.0) | | NR | NR | NR | NR | NR | NR
Robinson, 2006^154^ | Total (35); CPAP first (18); Sham first (17) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR
Ruttanaum-pawan, 2008^190^; Kaneko, 2003^191^ | CPAP (12); No treatment (12) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | All pts had HF | NR
Siccoli, 2008^155^ | CPAP (51); Sham CPAP (51) | 0 (0.0); 0 (0.0) | SF-36 PCS,^‖‖^ mean (SD); Baseline; 62.0 (20.0); 69.4 (21.5); 4 weeks; 70.8 (18.5) p<0.0001; 70.0 (18.8) p=0.68; Between groups p=0.010; SF-36 MCS, mean (SD); Baseline; 62.2 (20.2); 64.8 (21.2); 4 weeks; 76.8 (16.2) p<0.0001; 68.6 (22.7) p=0.17; Between groups p=0.002; SAQLI, mean (SD); Baseline; 3.5 (1.0); 3.8 (1.1); 4 weeks; 4.4 (1.1) p<0.0001; 3.8 (1.6) p=0.65; Between groups p=0.001 | NR | NR | NR | NR | NR | NR
Shaw, 2016^193^ | CPAP (151); Control (147) | NR | SF-36 MCS, mean (SD); BL:; 50 (11.3); 50.9 (10); 24 weeks:; 52.6 (10.1); 51.8 (10.3); Between-group diff; 1.5 (SD −0.7 to 3.7) | NR | NR | NR | NR | NR | NR
Smith, 2007^156^ | Total (24); CPAP first (11); Sham first (13) | 0 (0.0); 0 (0.0) | MLHF; Baseline: 38 (27); G1: 36 (29); G2: 34 (28); Between-group difference 1.0 (−4.3 to 6.4) p=0.70; SF36 PCS; Baseline: 34 (16); G1: 34 (14); G2: 35 (14); Between-group diff −1.0 (−3.6 to 1.6); p=0.43; SF36 MCS; BL: 51 (10); G1: 49 (12); G2: 50 (11); Between-group diff −0.5 (−4.2 to 3.2); p=0.79 | NR | NR | NR | NR | NR | NR
Traaen, 2021^199^; A3 | CPAP+usual care (54); Usual care (54) | NR | FOSQ; Baseline; G1: 17.4 (1.9); G2: 17.7 (2.0); 6 months; G1: 17.6 (2.0); G2: 17.7 (2.0); Between-group difference in mean change from BL (95% CI): 0.1 (−0.5 to 0.6); p=0.850; SF-36 PCS; Baseline; G1: 43.1 (9.1); G2: 43.3 (10.2); 6 months; G1: 43.6 (10.2); G2: 45.9 (9.6); Between-group difference in mean change from BL (95% CI): −2.1 (−5.1 to 0.8); p=0.160; SF-36 MCS; Baseline; G1: 49.9 (9.5); G2: 52.8 (6.6); 6 months; G1: 52.5 (8.7); G2: 51.5 (8.8); Between-group difference in mean change from BL (95% CI): 2.8 (−0.1 to 5.8); p=0.058 | NR | NR | Pacemaker implantation due to syncope and prolonged pauses; G1: 2 (4); G2: 0 | Hemorrhagic stroke; G1: 0; G2: 1 (2) | NR | NR
Weaver, 2012^157^; CATNAP | Total (281); CPAP (141); Sham CPAP (140) | 0 (0.0); 0 (0.0) | FOSQ total, unadj mean change from BL (SD):; 0.98 (2.89) p=0.0005; −0.14 (2.61) p=0.57; Adj mean change from BL (SD):; 0.89 (NR); −0.06 (NR); Adj diff in mean change from BL (SE);; 0.95 (0.34); Between-group diff; p=0.006; SF-36, PCS; Adj mean change from BL:; 3.89; 0.04; Adj between-group diff in mean change from BL (SE):; 3.85 (1.17); 95% CI, 1.53 to 6.17; p=0.001; SF-36, MCS; Adj mean change from BL:; 3.07; 2.21; Adj between-group diff in mean change from BL (SE):; 0.86 (1.42); 95% CI, −1.95 to 3.67; p=0.546 | NR | NR | NR | NR | NR | NR
West, 2007^158^; West, 2009^159^ | CPAP (20); Sham CPAP (22) | NR | SAQLI, mean (SD); Baseline; 4.3 (1.1); 4.4 (0.9); Change from BL at 12 weeks:; +0.8 (1.0); +0.03 (1.2); Between-group diff (95% CI):; 0.77 (−1.5 to 0.04); p=0.04 | NR | NR | 1 CPAP patient (5%) had emergency cardiac surgery | NR | NR | NR
Wimms, 2020^195^; MERGE | Total (233); CPAP (115); Standard care (118) | NR | Very mild OSA; SF-36 MCS; Within-group diff (95% CI); 5.8 (3.6 to 8.1); −0.8 (−3.2 to 1.6); Between-group diff (95% CI); 6.6 (3.3 to 9.9), p=0.0001; SF-36 PCS (mean, SD); SF-36 PCS; Within-group mean change (95% CI); 0.8 (−0.9 to 2.5); −2.1 (−3.9 to −0.3); Between-group diff (95% CI); 2.9 (0.4 to 5.4), p=0.03; Mild OSA; SF-36 MCS (mean, SD); BL; 46.9 (11.1); 44.3 (12.3); Within-group diff (95% CI); 4.2 (2.8 to 5.6); −0.7 (−2.1 to 0.7); Between-group diff (95% CI); 4.9 (2.9 to 6.9), p<0.0001; SF-36 PCS (mean, SD); BL:; 48 (9.7); 47.2 (10.2); Within-group diff (95% CI); 1 (−0.1 to 2.2); −0.7 (−1.8 to 0.4); Between-group diff (95% CI); 1.7 (0.1 to 3.3), p=0.05; FOSQ, mean (SD); BL:; 16.4 (2.9); 15.9 (2.7); 12 weeks; 18 (NR); 16.1 (NR); Within-group diff (95% CI); 1.6 (1.1 to 2.0); 0.2 (−0.2 to 0.7); Between-group diff (95% CI); 1.3 (0.7 to 2), p<0.0001; EQ-5D: Index, mean (SD); BL:; 0.76 (0.19); 0.74 (0.19); Change at 12 weeks (95% CI); 0.03 (0 to 0.06); 0 (−0.03 to 0.02); Between-group diff (95% CI); 0.03 (0 to 0.07), p=0.08; EQ-5D: VAS, mean (SD); BL:; 70.9 (18.8); 65.8 (18.5); Change at 12 weeks (95% CI); 3.1 (0.3 to 5.9); −0.9 (−3.7 to 1.8); Between-group diff (95% CI); 4 (0.1 to 7.9), p=0.05 | NR | NR | NR | CPAP: 1 (0.8); Standard care: 1 (0.8) | NR | NR
Zhao, 2017^196^; BestAIR | Total (169); CPAP (83); Control+ Sham (86) | NR | SF-36 PCS, mean (SD); BL:; 45.2 (9.4); 44.3 (9.6); 12 weeks; 45.6 (9.7); 42.7 (10.1); 24 weeks; 46.2 (9.6); 42.9 (8.7); Between-group diff (95% CI); 3.4 (1.4 to 5.3), p<0.001; SF-36 MCS; BL:; 49.7 (12); 50.3 (0.6); 12 weeks; 52.2 (11.3); 52.2 (9.7); 24 weeks; 51.3 (9.7); 54 (11.5); Between-group diff (95% CI); 0.2 (−2.1 to 2.4), p=0.869 | NR | NR | NR | Total: 4 (2.4); CPAP: 2 (2.4); Control+Sham: 2 (2.3) | NR | NR

* For all-cause mortality, the authors also reported an incidence density ratio: 2.6 (95% CI, 0.70 to 11.8; p=0.16).

† Hospitalizations were for unstable angina or arrhythmias.

ǂ Authors also reported the EQ-5D Health Status (Visual Analogue Score); there were no differences between groups in the total score (p=0.095).

§ p<0.001 compared with baseline; effect size (SD units) 0.31.

‖ p<0.001 compared with baseline; effect size (SD units) 0.38; EuroQol scores improved significantly only in the CPAP group.

¶ Sample size includes some patients who had central sleep apnea.

# Rapid visual information processing.

** 2 second presentation rate.

†† Benton visual retention test.

ǂǂ Per authors, one person in the control group developed “unspecified tachyarrhythmia requiring hospitalization.”

§§ Authors reported counts for neurological “adverse events” but did not specify how these were measured or defined: CPAP 36 events (6.5%) vs. sham 32 events (5.9%).

‖‖ Authors also report a score for the PCS and MCS components of the SF-12; results are similar to those seen on the SF-36.

Abbreviations: A3=Atrial Fibrillation, Apnea, Airway Pressure; adj=adjusted; A-fib=atrial fibrillation; APPLES=Apnea Positive Pressure Long-term Efficacy Study; BestAIR=Best Apnea Interventions for Research; BL=baseline; BSC=best supportive care; BVRT=Benton Visual Retention Test; CATNAP=CPAP Apnea Trial North American Program; CBV=cerebrovascular; CI=confidence interval; COWAT=Controlled Oral Word Association Test; CPAP=continuous positive airway pressure; CV=cardiovascular; CVD=cardiovascular disease; diff=difference; EQ=EuroQoL; FOSQ=Functional Outcomes of Sleep Questionnaire; G=group; HeartBEAT=Heart Biomarker Evaluation in Apnea Treatment; HF=heart failure; IQ=intelligence quotient; KQ=key question; MCS=Mental Component Score of the SF-36; MI=myocardial infarction; MLHF=Minnesota Living with Heart Failure; MOSAIC=Multicentre Obstructive Sleep Apnoea Interventional Cardiovascular; MVA=motor vehicle accident; N=sample size; NART=National Adult Reading Test; NHP=Nottingham Health Profile; nCPAP=nasal continuous positive airway pressure; NR=not reported; NS=not significant; OSA=obstructive sleep apnea; PASAT=Paced Auditory Serial Addition Test; PCI=percutaneous coronary intervention; PCS=Physical Component Score of the SF-36; pts=patients; PVD=peripheral vascular disease; PVT=psychomotor vigilance test; QSQ=Quebec Sleep Questionnaire; RAVLT=Rey Auditory Verbal Learning Test; RICCADSA=Randomized Intervention with Continuous Positive Airway Pressure in CAD and OSA; RVIP=Rapid Visual Information Processing; RVIPT=Rapid Visual Information Processing Test; SAQLI=Sleep Apnea Quality of Life Index; SD=standard deviation; SE=standard error; SEM=subjects with a mean; SF-12=12-Item Short Form Health Survey; SF-36=36-Item Short Form Health Survey; TIA=transient ischemic attack; unadj=unadjusted; WAIS=Wechsler Adult Intelligence Scale; WAIS-R=Wechsler Adult Intelligence Scale-Revised.

Appendix E Table 5 Characteristics of Included Randomized, Controlled Trials That Evaluated Mandibular Advancement Devices (KQs 5 and 6)

First Author, Year; Design | G1 (N); G2 (N) | Source of Patients | Screen Detected? | Country | Duration, Weeks | Mean (Range) Age | % F | % Race/Ethnicity | Mean BMI | Mean AHI | Mean ESS | OSA Severity | % HTN;; % HF | Benefits Quality
Aarab, 2011^206^; Nikolopoulou, 2020^207^; Parallel | MAD (20); Intraoral pbo device (19)^*^ | Sleep clinic | No | The Netherlands | 24 | 52 (includ-ing drop-outs) | 27 | NR | 29 | 20 | 11 | Mild to mod | NR;; NR | Fair
Andren, 2013^208^; Parallel | MAD (36); Intraoral sham/pbo device (36) | Sleep clinics | No | Sweden | 12 | 58 | 21 | NR | 29–30 | 23–24 | 11 | Mild to severe | 100;; NR | Fair
Barnes, 2004^164^; Cross-over | MAD^†^ (99); Pbo (98) | Referrals | No | Australia | 12 CPAP; 12 MAD; 12 placebo | 47 | 20 | NR | 31 | 21 | 11 | Mild to mod | 15;; NR | Fair
Bloch, 2000^209^; Cross-over | Total (24); MAD Monobloc first (8); MAD Herbst first (8); No treatment first (8) | NR | No | Switzerland | 1 | 51 | NR | NR | 27 | 27 | 12 | Mild to severe | NR | Fair
Durán-Cantolla, 2015^210^; Cross-over | Total (42); MAD first (NR); Sham MAD first (NR) | Sleep clinic | No | Spain | 12 active; 12 sham | 47 | 21 | NR | 28 | 15 | 12 | Mild to mod | NR | Good
Gagnadoux, 2017^216^; Parallel | MAD (75); Sham (75) | Sleep centers | No | France | 8 | 54 | 14 | NR | 27 | 41 | 9 | Severe | 21;; NR | Fair
Johnston, 2002^214^; Cross-over | Total (21); MAD first (13); Sham MAD first (8) | Sleep clinic | No | Ireland | 4–6 active; 4–6 sham | 55 | 19 | NR | 32 | 32 | 14 | Mild to severe | NR;; 0 | Fair
Lam, 2007^177^; Parallel | MAD^ǂ^ (34); Usual care^§^ (33) | Sleep center | No | Hong Kong | 10 | 46 | 22 | NR | 27 | 21 | 12 | Mild to severe^‖^ | 19;; NR | Fair
Marklund, 2015^217^; Parallel | MAD (45); Pbo device (46) | Clinic referrals | No | Sweden | 16 | 52 | 32 | NR | 28 | 16 | 11 | Mild to mod | NR;; NR | Fair
Naismith, 2005^211^; Gotsopoulos, 2002^212^; Gotsopoulos, 2004^213^; Cross-over | Total (67); MAD first (35); Sham MAD first (32) | Sleep clinic | No | Australia | 4 active; 4 sham | 48 | 19 | NR | 29 | 26–28 | 11 | Mild to severe | NR;; NR | Good
Petri, 2008^218^; Parallel | MAD (33); Sham MAD (30); No tx (30) | ENT clinic sleep lab | No | Denmark | 4 | 46–50 | 18 | NR | 31 | 35 | 11 | Mild to severe | NR;; NR | Fair
Quinnell, 2014^215^; Cross-over | Total (90); SP1 MAD (23); SP2 MAD (22); bMAD (23); No tx (22) | Sleep center | No | United Kingdom | 6 active; 4 no tx | 51 | 20 | NR | 31 | 14 | 12 | Mild to mod | 26;; NR | Fair

* Study also included a CPAP arm.

† Study also included a CPAP arm. Because six different orders were possible, study authors did not list individuals’ actual orders. Numbers represent the number of people who started treatment in that arm (104 total participants; 80 completed all three arms).

ǂ Study also included a CPAP arm.

§ Usual care was defined as conservative measures—sleep hygiene and weight loss advice (if applicable).

‖ Authors defined as “mild to moderate,” but allowed AHI up to 40, and the range of included patients included some with severe OSA.

Abbreviations: AHI=apnea-hypopnea index; bMAD=fully bespoke mandibular advancement device; BMI=body mass index; CPAP=continuous positive airway pressure; dur=duration; ENT=otolaryngology; ESS=Epworth Sleepiness Scale; F=female; G=group; HF=heart failure; HTN=hypertension; KQ=key question; MAD=mandibular advancement device; mod=moderate; N=sample size; NR=not reported; OSA=obstructive sleep apnea; pbo=placebo; pts=patients; SP=SleepPro; tx=treatment.

Appendix E Table 6 Results of Included Randomized, Controlled Trials That Evaluated Mandibular Advancement Devices: Health Outcomes (KQ 5)

First Author, Year | G1 (N); G2 (N) | Mortality, N (%) | Quality of Life | Cognitive Impairment | MVAs, N (%) | CV Events, N (%) | CBV Events, N (%) | Heart Failure, N (%) | Headache, N (%) | Other, N (%)
Aarab, 2011^206^; Nikolopoulou, 2020^207^ | MAD (20); Intraoral pbo device (19) | NR | SF-36 Mean (SD); Baseline:; PF 82.98 (22.7); SF 75.0 (23.6); RF 53.9 (48.1); RE 77.2 (41.7); MH 66.7 (14.1); Vit 49.7 (18.0); BP 79.6 (27.9); GHP 54.7 (22.3); HT 41.3 (24.7); SF-36:; Changes in the domains of SF-36 were not NS between groups at 24 weeks. Post-treatment values were NR. | NR | NR | NR | NR | NR | NR | Clinical signs of TMD; Baseline:; 0 (0); 0 (0); 6 months:; 0 (0); 0 (0); NS; FIRS score (25%\|median\|75%); Baseline:; 0\|0\|1; 0\|0\|0; 6 months; 0\|0\|0.50; 0\|0\|0; NS
Barnes, 2004^164^ | MAD (99); Pbo (98) | 0 (0.0); 0 (0.0) | NR | Reported: Word Pair Memory Recall; Logical Memory Test; Digit Span Backwards; Trail Making B; Digit Symbol Substitution Task; COWAT; PVT; Stroop Color Association Test | NR | NR | NR | NR | NR | NR
Barnes, 2004^164^ | MAD (99); Pbo (98) | 0 (0.0); 0 (0.0) | FOSQ mean score, mean (SE):; Baseline: 3.1 (0.1); 3.3 (0.1), p<0.001; 3.3 (0.1), p<0.01; MAD vs. pbo p<0.05; FOSQ domains, mean (SE):; General productivity:; Baseline: 3.2 (0.1); 3.4 (0.1), p<0.001; 3.4 (0.1), p<0.01; MAD vs. pbo p=NS; Activity level:; Baseline: 3.0 (0.1); 3.2 (0.1), p<0.001; 3.1 (0.1), p<0.05; MAD vs. pbo p=NS; Sexual relationships:; Baseline: 2.9 (0.1); 3.0 (0.1), p=NS; 3.0 (0.1), p=NS; MAD vs. pbo p=NS; Social outcomes:; Baseline: 3.3 (0.1); 3.7 (0.1), p<0.001; 3.4 (0.1), p=NS; MAD vs. pbo p<0.001; Vigilance:; Baseline: 3.0 (0.1); 3.1 (0.1), p<0.01; 3.1 (0.1), p<0.05; MAD vs. pbo p=NS; SF-36 mean score, mean (SE); Baseline: 69.4 (1.3); 73.7 (1.2); p<0.001; 71.4 (1.4); p=NS; MAD vs. pbo p=NS; Overall health; Baseline: 65.9 (1.7); 71.7 (1.6); p<0.001; 68.7 (1.6); p=NS; MAD vs. pbo p<0.05 | Reported: Word Pair Memory Recall; Logical Memory Test; Digit Span Backwards; Trail Making B; Digit Symbol Substitution Task; COWAT; PVT; Stroop Color Association Test | NR | NR | NR | NR | NR | NR
Bloch, 2000^209^ | Total (24); MAD Monobloc first (8); MAD Herbst first (8); No treatment first (8) | 0 (0.0); 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR | NR
Lam, 2007^177^ | MAD (34); Usual care (33) | NR | SAQLI, mean (SEM) continued; Treatment-related symptoms; Mean (SEM) 10 weeks; 1.8 (0.2); SF-36, mean (SEM); p-value of within-group change from BL; between-group change from BL vs. usual care; Physical function BL; 84.7 (1.7); 82.3 (2.6); Physical function 10 weeks; 86.5 (2.0); p=NS; p=NS; 78.9 (3.6); General health BL; 50.8 (3.9); 51.2 (3.3); General health 10 weeks; 58.1 (3.7); p<0.05; p=NS; 54.8 (3); Mental health BL; 65.8 (2.9); 65.6 (2.5); Mental health 10 weeks; 69.8 (3.1); p=NS; p=NS; 68.0 (2.5) | NR | NR | NR | NR | NR | NR | NR
Marklund, 2015^217^ | MAD (45); Pbo device (46) | NR | SF-36 PCS, mean (SD); BL:; 45.9 (8.9); 45.3 (8.5); 16 weeks; 48.2 (8.4); 46 (10.3); Between-group diff (95% CI); 2.2 (−1.8 to 6.3); SF-36 MCS, mean (SD); BL:; 44.3 (10.8); 46.1 (10.5); 16 weeks; 48.1 (9.7); 47.2 (12.1); Between-group diff (95% CI); 0.9 (−3.8 to 5.6); FOSQ; BL:; 16.1 (2.3); 16.3 (2.6); 16 weeks; 17.6 (2.3); 16.4 (3.4); Between-group diff (95% CI); 1.2 (−0.1 to 2.5) | NR | NR | NR | NR | NR | BL:; NR (84); NR (77); Followup:; NR (71); NR (70) | NR
Petri, 2008^218^ | MAD (33); Sham MAD (30); No tx (30) | 0 (0.0); 0 (0.0); 1 (3.3) | SF-36 PCS, Mean (SD); BL:; 45.5 (9.5); 48.1 (9.2); 46.6 (9.6); 4 weeks (within-group p-value):; 46.5 (8.0); p=0.21; 47.5 (11.2); p=0.40; 47.3 (8.7); p=0.69; SF-36 MCS, Mean (SD); BL:; 47.2 (8.5); 48.8 (10.0); 50.2 (8.9); 4 weeks (within-group p-value):; 51.1 (8.0); p=0.039; 49.8 (8.5); p=0.48; 51.2 (7.8); p=0.79 | NR | NR | NR | NR | NR | NR | NR
Quinnell, 2014^215^ | Total (90); No tx (22); SP1 MAD (23); SP2 MAD (22); bMAD (23) | 0; 0; 0; 0 | FOSQ (p-value is change from no tx); Total score; 16.62 (2.55), no tx; 17.13 (2.42), p<0.05; 17.70 (2.14), p<0.05; 17.90 (1.92), p<0.05; General productivity; 3.48 (0.45), no tx; 3.57 (0.44), p<0.05; 3.66 (0.40), p<0.05; 3.73 (0.36), p<0.05; Social outcome; 3.53 (0.58), no tx; 3.61 (0.58); 3.71 (0.53), p<0.05; 3.74 (0.49), p<0.05; Activity level; 3.11 (0.68), no tx; 3.25 (0.59), p<0.05; 3.37 (0.53), p<0.05; 3.40 (0.48), p<0.05; Vigilance; 3.25 (0.57), no tx; 3.33 (0.54); 3.48 (0.47), p<0.05; 3.53 (0.42), p<0.05; Intimate relationships; 3.20 (0.87), no tx; 3.34 (0.80); 3.45 (0.73), p<0.05; 3.49 (0.68), p<0.05; SAQLI (p is change from no tx); Total score; 5.01 (1.24), no tx; 5.25 (1.20), p<0.05; 5.60 (1.12), p<0.05; 5.64 (1.06), p<0.05; Daily activities; 4.83 (1.49), no tx; 5.16 (1.38), p<0.05; 5.56 (1.23), p<0.05; 5.47 (1.33), p<0.05; Social interactions; 5.31 (1.25), no tx; 5.49 (1.34); 5.85 (1.16), p<0.05; 5.89 (1.12), p<0.05; Emotions; 5.40 (1.25), no tx; 5.46 (1.25); 5.70 (1.25), p<0.05; 5.79 (1.09), p<0.05; Symptoms; 4.47 (1.72), no tx; 4.82 (1.59), p<0.05; 5.23 (1.52), p<0.05; 5.37 (1.47), p<0.05; SF36 (p is change from no tx); Physical component; 43.06 (12.86), no tx; 42.73 (12.22); 45.11 (12.33), p<0.05; 43.12 (13.81); Mental component; 46.20 (10.78), no tx; 46.87 (9.63); 47.34 (11.24) | NR | 2 (3%); 1 (1%); 0 (0%); 2 (3%) | 1 (1%); 0 (0%); 0 (0%); 1 (1%) | NR | NR | NR | NR

Abbreviations: BL=baseline; bMAD=fully bespoke mandibular advancement device; BP=bodily pain; CBV=cerebrovascular; COWAT=Controlled Oral Word Association Test; CV=cardiovascular; FIRS=Function Impairment Rating Scale; FOSQ=Functional Outcomes of Sleep Questionnaire; G=group; GHP=general health perceptions; HT=health transition; KQ=key question; MAD=mandibular advancement device; MCS=Mental Component Score of the SF-36; MH=mental health; MVA=motor vehicle accident; N=sample size; NR=not reported; NS=not significant; pbo=placebo; PCS=Physical Component Score of the SF-36; PF=physical functioning; PVT=Psychomotor Vigilance Test; RE=role emotional; SAQLI=Sleep Apnea Quality of Life Index; SD=standard deviation; SE=standard error; SEM=subjects with a mean; SF=social functioning; SF-36=36-Item Short Form Health Survey; SP=SleepPro; TMD=temporomandibular disorder; tx=treatment; Vit=vitality.

Appendix E Table 7 Results of Included Randomized, Controlled Trials: Harms of CPAP Compared With Sham or Control (KQ 6)

First Author, Year; Trial Name; Quality for Harms | G1 (N); G2 (N) | DC Due to Harms, N (%) | Rash, N (%) | Irritation, N (%) | Need for Additional Sleep Meds, N (%) | Claustrophobia, N (%) | Oral or Nasal Dryness, N (%) | Nosebleed, N (%) | Pain, N (%) | Excess Salivation, N (%) | Dental, N (%)
Engleman, 1999^171^; Fair | Total (37); CPAP first (NR); Oral pbo first (NR) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | 4 (12); 0 (0) | NR | 0 (0.0); 1 (2.9) | NR | NR
Hui, 2006^137^; Fair | CPAP (28); Sham CPAP (28) | 0 (0.0); 5 (17.8) | NR | NR | NR | NR | NR | NR | NR | NR | NR
Kushida, 2012^141^; Batool-Anwar, 2016^142^; APPLES; Fair | CPAP (556); Sham CPAP (542) | NR | Dermato-logical; 102 (18.3); 61 (11.3) | NR | NR | NR | NR | NR | NR | NR | NR
Lam, 2007^177^; Fair | CPAP (34); Usual care (33) | 0 (0.0); 0 (0.0) | NR | Facial skin abrasion:; 7 (21); 0 (0) | NR | NR | 16 (47); 0 (0) | NR | TMJ pain:; 0 (0.0); 0 (0.0) | 0 (0); 0 (0) | 0 (0); 0 (0)
Malow, 2008^219^; Fair | Total (35); CPAP (22); Sham CPAP (13) | 0 (0.0); 0 (0.0) | NR | 2 (9.1); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR
Redline, 1998^189^; Fair | CPAP (59); Conservative therapy (52) | 3 (5.1); 0 (0.0) | NR | 2 (3.3); 0 (0.0) | NR | NR | NR | 1 (1.7); 2 (3.6) | NR | NR | NR
Shaw, 2016^193^; Fair | CPAP (151), Control (147) | 1 (0.6); 1 (0.6) | NR | NR | NR | NR | NR | 1 (0.7); 0 (0.0) | 1 (0.7); 1 (0.7) | NR | NR
Smith, 2007^156^; Fair | Total (24); CPAP first (11); Sham first (13) | 0 (0.0); 1 (3.9) | NR | NR | NR | 1 (3.9), but unclear which arm | NR | NR | NR | NR | NR
Weaver, 2012^157^; CATNAP; Fair | CPAP (141); Sham CPAP (140) | 1 (0.8); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR | NR | NR
Weinstock, 2012^201,^ ^220^; Fair | Total (50); CPAP first (25); Sham CPAP first (25) | 0 (0.0); 0 (0.0) | NR | Skin irritation:; 6 (12.0); 2 (4.0); Eye irritation:; 1 (2.0); 0 (0.0) | NR | 0 (0.0); 1 (2.0) | NR | NR | Ear pain:; 1 (2.0); 0 (0.0); Non-cardiac chest pain:; 1 (2.0); 0 (0.0) | NR | NR

Abbreviations: APPLES=Apnea Positive Pressure Long-term Efficacy Study; CATNAP=CPAP Apnea Trial North American Program; CPAP=continuous positive airway pressure; DC=discontinued; G=group; KQ=key question; meds=medications; N=sample size; NR=not reported; pbo=placebo; TMJ=temporomandibular.

Appendix E Table 8 Results of Included Randomized, Controlled Trials: Harms of MADs Compared With Sham or Control (KQ 6)

First Author, Year; Trial Name; Quality for Harms | G1 (N); G2 (N) | DC Due to Harms, N (%) | Rash, N (%) | Irritation, N (%) | Need for Addl Sleep Meds, N (%) | Claustro, N (%) | Oral or Nasal Dryness, N (%) | Nosebleed, N (%) | Excess Saliv, N (%) | Pain, N (%) | Dental, N (%) | Other
Aarab, 2011^206^; Nikolopoulou, 2020^207^; Fair | MAD (20); Intraoral pbo device (19) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | 4 (20.0); 0 (0.0) | NR | 9 (45.0); 0 (0.0) | 10^*^ (50.0); 0 (0.0) | 9^†^ (45.0); 0 (0.0)
Bloch, 2000^209^; Fair | Total (24); MAD Monobloc first (8); MAD Herbst first (8); No treatment first (8) | 0 (0.0); 0 (0.0) | NR | NR (but reported dental discomfort and mucosal erosions—see Dental column) | NR | NR | NR | NR | NR | TMJ pain Both MADs: 7 (29.2); No tx: 0 (0.0); Muscle discomfort Both MADs: 4 (16.7); No tx (0.0) | Dental discomfort Both MADs: 3 (12.5); No tx: 0 (0.0); Mucosal erosions Herbst MAD: 3 (12.5); Monobloc MAD: 0 (0.0); No tx: 0 (0.0)
Durán-Cantolla, 2015^210^; Fair | Total (42); MAD first (NR); Sham MAD first (NR) | NR | NR | NR | NR | NR | Oral dryness:; 2 (4.8); 1 (2.6) | NR | 15 (35.7); 22 (57.9) | Dental or gingival pain:; 7 (16.7); 4 (10.5); Tongue pain:; 3 (7.1); 4 (10.5); TMJ pain:; 3 (7.1); 1 (2.6) | Temporal bite change:; 5 (11.9); 2 (5.3); Damage to dental restorations:; 2 (5.1); 1 (2.6)
Gagnadoux, 2017^216^; Fair | MAD (75); Sham (75) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR | NR | NR | Mean side effect score^‡^ (Range); 2 (1–4); 2 (0–3); p=0.14
Johnston, 2002^214^; Fair | Total (21); MAD first (13); Sham first (8) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR (68) | TMJ discomfort on waking:; NR (42); NR; Persistent TMJ discomfort: 1 (5.0); NR | Temporary occlusal changes:; NR (4)
Lam, 2007^177^; Fair | MAD (34); Usual care (33) | 4 (11.8); 0 (0.0) | NR | NR | NR | NR | 11 (33); 0 (0) | NR | 19 (56); 0 (0) | TMJ pain:; 13 (38); 0 (0.0) | 11 (33); 0 (0)
Marklund, 2015^217^; Fair | MAD (45); Pbo device (46) | 0 (0.0) | NR | NR | NR | NR | NR | NR | N NR, but statistic-ally significant (p=0.03) | N NR, but statistically significant for jaw pain (p=0.004), and tooth pain (p=0.02) | N not reported, but statistically significant for bite changes (p<0.001) | Restless legs (BL, followup); Oral device: (41%, 13%) p<0.001; Pbo: (31%, 31%); Diff: (28%, p=0.02); also reported nasal congestion, fatigue, and nightmares
Naismith, 2005^211^; Gotsopoulos, 2002^212^; Gotsopoulos, 2004^213^; Fair | Total (67); MAD first (35); Sham MAD first (32) | 0 (0.0); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR; p<0.05 | Jaw discomfort: NR; p<0.0001 | Tooth tenderness: NR; p<0.0001
Petri, 2008^218^; Fair | MAD (33); Sham MAD (30); No tx (30) | 4 (12.1); 2 (6.7); 0 (0.0) | NR | NR | NR | NR | NR | NR | NR | 1 (3.0); 0 (0.0); 0 (0.0) | 1 (3.0); 1 (3.3); 0 (0.0)
Quinnell, 2014^215^; TOMADO; Fair | Total (90); SP1 MAD (23); SP2 MAD (22); bMAD (23); No tx (22) | 1 (4.3); 0 (0); 2 (8.6); 0 (0) | NR | NR | NR | NR | 20 (24.7); 24 (30.8); 18 (23.4); 10 (12.8) | NR | 32 (39.5); 18 (23.1); 29 (37.7); 2 (2.6) | 60^§^ (74.1); 52 (66.7); 74 (96.1); 13 (16.7) | 1 (4.3); 0 (0); 2 (8.6); 0 (0)

* Discomfort in wearing MAD.

† Data reported were for sensitive teeth upon awakening (study also reported tenderness in the masseter muscle region upon awakening, n=13 in MAD group).

‡ Participants were asked to rate (0, absent; 1, mild; 2, moderate; 3, severe) six common side effects of oral appliance therapy, including jaw pain, tooth pain, muscle stiffness, dry mouth, hypersalivation, and occlusal change.

§ Data were for “discomfort/mouth problems.”

Abbreviations: addl=additional; BL=baseline; bMAD=fully bespoke mandibular advancement device; claustro=claustrophobia; DC=discontinued; diff=difference; G=group; KQ=key question; meds=medications; MAD=mandibular advancement device; N=sample size; NR=not reported; pbo=placebo; saliv=salivation; SP=SleepPro; TMJ=temporomandibular; TOMADO=Trial of Oral Mandibular Advancement Devices for Obstructive sleep apnoea-hypopnoea; tx=treatment.