# Appendix D Quality Assessments

Appendix D Table 1 Quality Ratings of Studies of Screening Questionnaires and Clinical Prediction Tools (KQ 2)

First Author, Year | Index Test | Reference Standard | Definition (AHI Cut Point) Used to Define OSA Based on Reference Standard | Bias Due to Patient Selection | Comments | Bias Due to Index Test | Comments | Bias Due to Reference Standard | Comments
Baird, 2018^282^ | BQ | PSG: 95% in clinic; 5% in home | RDI >5 | Unclear | Participants were part of a larger cross-sectional cohort study of Australian veterans. No description of how participants were selected for the larger study. | Unclear | Unclear whether the index and reference tests were interpreted separately; participants in the retrospective cohort (20% of participants) may have answered index questions differently based on their knowledge of their OSA diagnosis. Threshold for positive index test was not described clearly; however, authors reference separate study. | Unclear | A small proportion of patients (7%) had in-home PSG; unknown accuracy of in-home diagnosis.
Edmonds, 2019^115^ | BQ | In-lab PSG | Separate accuracy for OSA severity: mild (AHI 5–14); mod (AHI 15–29); severe (AHI >30) | Low | | Low | No description of whether the screening test was performed without knowledge of PSG, however this is unlikely to influence screening questionnaire responses. Thresholds were not prespecified in the methods; however, the results indicate that commonly used thresholds were used and likely were prespecified. | Low | None
Edmonds, 2019^115^ | STOP-BANG | In-clinic PSG | Separate accuracy for OSA severity: Mild (AHI 5–14); mod (AHI 5–29); severe (AHI >30) | Low | | Low | No description of whether the screening test was performed without knowledge of PSG, however this is unlikely to influence screening questionnaire responses. Thresholds were not prespecified in the methods; however, the results indicate that commonly used thresholds were used and likely were prespecified. | Low | None
Gurubhaga-vatula, 2013^114^ | MVAP and MVAP+AHI from in-home PM | In-lab PSG | s-OSAS: AHI ≥30 and ESS >10; Any OSAS: AHI ≥5 and ESS >10 | Low | | Low | Eligible data for the OSA risk score is derived from a validation sample. Multiple cut points were evaluated to determine the optimal accuracy. | Low | None
Hrubos-Strom, 2011^112^ | BQ | In-lab PSG | AHI ≥5 and AHI ≥10 | Unclear | A consecutive sample was used to recruit participants to complete the index test; the sample recruited for PSG oversampled the high-risk group, had higher ESS scores, and had higher rates of snoring. | Low | | Low | None
Jorge, 2019^116^ | BQ | In-lab PSG | Accuracy reported at multiple AHI cut points (dichotomized at >5, 15, and 30 events/hour) | Unclear | Some exclusion criteria apply to larger study on dementia in participants with and without OSA and may not be appropriate for purposes of screening for OSA (e.g., participants with other reasons for cognitive impairment, participants who slept <180 minutes during PSG). | Low | Unclear whether the index and reference tests were interpreted separately. However, because the index test is patient-reported, it is unlikely that participants’ knowledge of their PSG results would affect scoring. | Low | None
Jorge, 2019^116^ | Modified STOP-BANG | In-lab PSG | Accuracy reported at multiple AHI cut points (dichotomized at >5, 15, and 30 events/hour) | Unclear | Some exclusion criteria apply to larger study on dementia in participants with and without OSA and may not be appropriate for purposes of screening for OSA (e.g., participants with other reasons for cognitive impairment, participants who slept <180 minutes during PSG). | Unclear | Unclear whether the index and reference tests were interpreted separately. However, because the index test is patient-reported, it is unlikely that participant knowledge of their PSG results would affect scoring. Study used a cut point of >3 as high risk for severe OSA. Scoring does not appear to be prespecified, but this is unknown (developers of STOP-BANG suggest that >5 is high risk). | Low | None
Morales, 2012^113^ | MVAP score and MVAP plus AHI from in-home PM | In-lab PSG | Severe OSAS: AHI ≥30 and ESS >10 | Unclear | Sample was recruited from a list of participants who were enrolled in a consumer membership program for older adults based on zip code. Multiple exclusion criteria included non-English speaking, MMSE score ≤20, use of sedatives/hypnotics, presence of alcoholism, inability to travel, and other conditions that could affect breathing. Recruitment also based on MVAP score (sought to recruit equal numbers of participants for each decile of MVAP score). | Low | Multiple cut points were evaluated to determine optimal accuracy. | Low | None
Shin, 2021^117^ | Modified STOP-BANG | Portable PSG both in-lab and home testing (Embletta X100, unattended 11-channel) | Any OSA (AHI >5); subgroups of mild to moderate (5 < AHI < 30) and severe (AHI >30) | Unclear | Unclear sampling; participants from a large community-based cohort study. Authors noted that current sample included those who underwent a PSG but did not say how sample was selected for PSG. | Unclear | Index test results were taken from interviews and structured health exams based on cohort protocol; not stated whether results of PSG were known. | Low | Although a portable monitor was used with all patients (both in-home and in-clinic), the description of the monitor appears to include all the components of nonportable testing.
Selvanathan, 2021^118^ | Two-step screening: STOP-BANG + resting daytime Sp02, followed by Oxygen Desaturation Index values from overnight oximetry. | In-lab PSG | Any OSA (AHI >5); moderate to severe OSA (AHI >15); severe OSA (AHI >30) | Unclear | Although the study did not say whether a consecutive sample of patients was included, one of the papers from the study from which this was drawn used the same n of 204. | Low | Threshold was specified for STOP-BANG, daytime Sp02; threshold for overnight oximetry determined by assessing optimal AUC. | Low | None

Abbreviations: AHI=apnea-hypopnea index; BQ=Berlin Questionnaire; ESS=Epworth Sleepiness Scale; KQ=key question; lab=laboratory; MMSE=Mini-

Mental Status Examination; mod=moderate; MVAP=Multivariable Apnea Prediction; OSA=obstructive sleep apnea; OSAS=obstructive sleep apnea syndrome; PM=portable monitor; PSG=polysomnography; RDI=respiratory disturbance index; OSAS=obstructive sleep apnea syndrome; STOP=Snoring, Tiredness, Observed apnea, blood Pressure.

Appendix D Table 2 Quality Ratings of Studies of Screening Questionnaires and Clinical Prediction Tools (KQ 2)

First Author, Year | Bias Due to Flow and Timing | Comments | Overall Quality Rating | Comments | Are There Concerns That the Included Patients Do Not Match the Review Question? | Are There Concerns That the Index Test, Its Conduct, or Its Interpretation Differ From the Review Question? | Comments on Applicability
Baird, 2018^282^ | High | Accuracy outcome is provided only for the overall sample (20% had prior PSG, 5% had home sleep test); no description of average timeframe between prior PSG and index test or proportion who were treated for OSA. | Poor | High risk of bias due to participant selection: 20% had prior PSG and may be aware of their diagnosis. No description of the proportion of participants with a prior PSG who were treated with OSA or the interval between the previous PSG and the screening questionnaire. Not all participants had the same reference standard; 5% had a home sleep test which may differ in diagnostic accuracy compared with in-lab PSG. | Yes | No | Sample includes Australian Vietnam veterans with and without PTSD who were recruited for a larger cohort study on the association between PTSD and sleep disturbance.
Edmonds, 2019^115^ | Unclear | Study reports accuracy for mild, moderate, and severe OSA categories, but methods are unclear about how these were calculated. Based on data provided, estimates appear to reflect accuracy for “mild only” (vs. other severity or no OSA) and not “mild or worse” (same for moderate OSA estimates). When attempting to recreate estimates of accuracy, calculated values differ 1% to 4% from reported values. | Fair | Unclear whether screening and reference standard interpreted separately. Thresholds not clearly prespecified for screening tests; however, commonly used thresholds were used. Study reports accuracy for mild, moderate, and severe OSA categories, but methods are unclear about how these were calculated. When attempting to recreate estimates of accuracy, calculated values differ 1% to 4% from reported values. | Yes | No | Sample limited to participants with type 2 diabetes mellitus.
Edmonds, 2019^115^ | Unclear | Study reports accuracy for mild, moderate, and severe OSA categories, but methods are unclear about how these were calculated. Based on data provided, estimates appear to reflect accuracy for “mild only” (vs. other severity or no OSA) and not “mild or worse” (same for moderate OSA estimates). When attempting to recreate estimates of accuracy, calculated values differ 1%–4% from reported values. | Fair | Unclear whether screening and reference standard interpreted separately. Thresholds not clearly prespecified for screening tests; however, commonly used thresholds were used. Study reports accuracy for mild, moderate, and severe OSA categories, but methods are unclear about how these were calculated. When attempting to recreate estimates of accuracy, calculated values differ 1%–4% from reported values. | Yes | No | Sample limited to participants with type 2 diabetes mellitus.
Gurubhagavatula, 2013^114^ | Unclear | All participants were invited for in-lab PSG, but 21% (52/250) did not follow through with testing. Missing data addressed using multiple imputation. Interval between index and reference test not clearly specified. | Fair | Some concern for bias arising from flow and timing; 21% of recruited sample did not have in-lab PSG; however, multiple imputation was used to address missing data. | Yes | No | Enrolled sample was 80% men, had higher prevalence of any OSA (AHI ≥5 for 80%; and mean AHI of 22.5) than would be expected, age limited to 30–65. Study limited to consecutive outpatients with HTN, recruited from a VA Medical Center and a university setting.
Hrubos-Strom, 2011^112^ | Unclear | 1,772 (of 9,319 eligible for random draws) were randomly drawn. Of those 1,772, 518 (29%) had PSG; the sample of 518 overrepresented the BQ high-risk group. Interval between index and reference test not clearly stated. Missing data on BQ were addressed by imputation. | Fair | Potential risk of bias due to participant selection and flow and timing. For comparison with PSG, study oversampled of high-risk participants (based on BQ score). Risk of bias due to flow and timing and missing data; however, would expect those biases to favor the accuracy of BQ—and this study did not find good accuracy. | Yes | No | Population-based sampling from Norway; clinical sample—the sample who had PSG oversampled the high-risk group, had higher ESS scores and rates of snoring.
Jorge, 2019^116^ | Unclear | Interval between index and reference test was not clearly specified; however, methods indicate they were both completed at enrollment in larger cohort study; 11% of participants excluded for analysis due to “invalid questionnaire.” | Fair | Some exclusion criteria apply to larger study on dementia in people with and without OSA, and may not be appropriate for purposes of screening. Of the 91 assessed, 11 (12%) were excluded due to “invalid questionnaire.” | Yes | No | Sample selected from outpatients attending a cognitive disorders clinic in Spain, recruited for a separate study on the cognitive progression of Alzheimer disease among those with and without OSA.
Jorge, 2019^116^ | Low | | Fair | Some exclusion criteria apply to larger study on dementia in those with and without OSA and may not be appropriate for purposes of screening for OSA. Study used a cut point of >3 as high risk for severe OSA. It does not appear to be prespecified, but this is unknown (developers of STOP-BANG suggest that >5 is high risk). | Yes | No | Sample was selected from outpatients attending a cognitive disorders clinic in Spain who were recruited for a separate study on the cognitive progression of Alzheimer disease among those with and without OSA.
Morales, 2012^113^ | Unclear | All were invited for in-lab PSG, 19% (104/556) of all those screened did not receive PSG, primarily due to ineligibility (roughly 13% of those eligible declined). Of those enrolled, about 2% had incomplete data. Interval between index and reference standard not clearly stated. | Fair | Potential bias due to participant selection and flow and timing. All were invited for in-lab PSG, 19% (104/556) of all those screened did not receive PSG, primarily due to ineligibility (roughly 13% of those eligible declined). Of those enrolled, about 2% had incomplete data. Interval between index and reference standard not clearly stated. | Yes | No | All participants were age 65 years and older (mean age 71 years), had higher prevalence of sleepiness than would be expected (74% reported that they had a problem staying awake every day or several [≥3] days/week; 32% had ESS >10).
Shin, 2021^117^ | Unclear | Interval between reference and index test not described. Difference between those eligible/invited for PSG and sample included in analysis not clear. Note: Using data provided and the diagnostic accuracy calculator and Open Epi, neither the PPV nor the NPV for all OSA or mild to moderate was correct. | Fair | Unclear patient selection, index test, and flow and timing. Sample taken from larger cohort; authors stated the sample analyzed included those with PSG results (but no mention of whether all cohort participants were invited for PSG or a subsample).; Index test—not stated whether results of PSG were known; unlikely but not able to say.; Flow and timing—not stated whether results of PSG were known. | Yes | No | All patients were Korean adults.
Selvanathan, 2021^118^ | Unclear | Only 2% (5/204) with PSG had missing data on screening test. No data on prevalence included so it is not possible to check accuracy. | Fair | Unclear ratings for patient selection (unclear whether patient selection was random or consecutive) and flow and timing (no data). | Yes | No | Participants were all patients on opioids for chronic pain; whether the results are applicable to a general population is not known.

Abbreviations: AHI=apnea-hypopnea index; BQ=Berlin Questionnaire; ESS=Epworth Sleepiness Scale; HTN=hypertension; KQ=key question; NPV=negative predictive value; OSA=obstructive sleep apnea; PPV=positive predictive value; PSG=polysomnography; PTSD=post-traumatic stress disorder; STOP=Snoring, Tiredness, Observed apnea, blood Pressure; VA=U.S. Department of Veterans Affairs; vs.=versus.

Appendix D Table 3 Relevance of Systematic Reviews and Meta-Analyses for KQ 4 (AHI and Blood Pressure Outcomes)

First author, Year | Did the review focus on studies of persons with a confirmed diagnosis of OSA randomized to an eligible treatment vs. control (PAP vs. control or sham PAP, and/or MADs vs. no treatment or inactive MAD) and report on change in AHI or blood pressure outcomes? | Did the review limit to RCTs or report pooled results separately for RCTs vs. other designs? | Did the review pool results for AHI and blood pressure outcomes? | Did the review limit to studies conducted in countries categorized as “Very High” on the UN Human Development Index (HDI) or report subgroup analyses by country setting? | Are there other factors related to the eligibility criteria of the review that differ from our own criteria for treatment studies? | What was the date of the last database search used to identify relevant studies? | Relevant?
Bartolucci, 2021^283^ | Review included RCTs evaluating customized MADs vs. any comparator; of 50 included studies, approximately 12 compared MAD vs. inactive control. | Yes: However, results not pooled separately based on comparator. | Yes: However, not clear what proportion of pooled studies compared MAD with inactive control. | No limit on country setting was described; results did not comment on country setting. | Focus was on effectiveness of different customized MAD designs in reducing AHI vs. any control; no pooled subgroups based on comparators. Of the included studies, most compared MAD with another active therapy. | February 2020 | No
de Vries, 2018^123^ | Yes | Yes | Yes: 11 | NR | No | December 31, 2016 | Yes
Green, 2021^284^ | Review included RCTs; methods are not clear about comparators. | Results for BP were pooled separately for RCTs. | Yes (10 RCTs comparing PAP vs. control pooled for BP outcomes). | No limit on country setting was described; results did not comment on country setting. | Yes: Main focus was on change in levels of catecholamines. Included RCTs reporting on BP had to also report on catecholamine levels. | May 2020 | No
Ilea, 2019^285^ | No: Included a variety of study designs, not just RCTs. Also did not clarify what the comparison is even from the RCTs. However, can identify which studies are RCTs. | Partially: Can use Table 1 for RCTs only, no meta-analysis for these. | No | NR | Yes: Variety of study designs and comparisons not clearly described. | 2018 | No
Labarca, 2021^124^ | Yes | Yes | Yes: 6–8 studies included pooled BP outcomes (varies by BP measurement). | No limit on country setting was described; results did not comment on country setting. | Review was focused on studies that evaluated benefit of PAP vs. control for populations with resistant hypertension. | March 2020 | Yes
Patil, 2019^125^ | Yes | Yes | Yes: 11 for AHI, 26 for BP | NR | No | February 2018 | Yes
Rossi, 2021^286^ | Review included RCTs comparing MAD vs. any comparator; approximately 8 (of 17 included studies) had an inactive comparator. | Review limited to RCTs but did not pool results of studies. | No | No limit on country setting is described; results do not comment on country setting. | Inclusion criteria state that RCTs enrolling fewer than 50 participants and those reporting on “secondary RCTs (studies with secondary analysis compared to the primary endpoint of the trial)” were excluded. | February 2019 | No
Zhang, 2016^126^ | Yes | Yes | Yes: 7 | NR | No | April 1, 2016 | Yes

Abbreviations: AHI=apnea-hypopnea index; BP=blood pressure; HDI=Human Development Index; KQ=key question; MAD=mandibular advancement device; NR=not reported; OSA=obstructive sleep apnea; PAP=positive airway pressure; RCT=randomized, controlled trial; UN=United Nations; vs.=versus.

Appendix D Table 4 Quality Ratings of Systematic Reviews and Meta-Analyses for KQ 4 (AHI and Blood Pressure Outcomes)

First author, Year | Was the review based on a focused question of interest? | Was the literature search strategy clearly described? | Was there evidence of a substantial effort to search for all relevant research? | Were there explicit inclusion/exclusion criteria for the selection of studies? | Did at least 2 people independently review studies? | Was the validity of included studies adequately assessed? | Was publication bias assessed? | Was heterogeneity assessed and addressed? | Was the approach used to synthesize the information adequate and appropriate? | Quality rating | Comments
de Vries, 2018^123^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good | Includes good evidence of effect of oral appliances vs. inactive controls on two measures of BP. Seemed to have a good approach to assessing quality, bias, and heterogeneity.
Labarca, 2021^124^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good | None
Patil, 2019^125^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good | This study includes AHI and BP outcomes of interest but has many BP outcomes, see supplement figures S10-S33. Also assessed harms.
Zhang, 2016^126^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good | Included pooled results for the effect of CPAP on AHI or ODI with 3 studies included, only 1 which presents AHI. Used Jadad scale to assess clinical trial quality.

Abbreviations: AHI=apnea-hypopnea index; BP=blood pressure; CPAP=continuous positive airway pressure; KQ=key question; MAD=mandibular advancement device; NA=Not applicable; NR=not reported; ODI=oxygen desaturation index; RCT=randomized, controlled trial.

Appendix D Table 5 Quality Ratings of Randomized, Controlled Trials of Interventions for OSA (KQs 5 and 6)

First author, Year; Trial name | Was random-ization adequate? | Was allocation conceal-ment adequate? | Were groups similar at baseline? | Was interven-tion fidelity adequate? | What was the reported adherence to the intervention? | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias? | Did the study have cross-overs or contamination raising concern for bias?
Aarab, 2011^206^; Nikolopoulou, 2020^207^ | Yes | Yes | Yes | NA | MAD use 91% of nights; nCPAP 83% of nights; Intraoral pbo device 94% of nights | 11% | 13% (MAD: 5% vs. nCPAP: 18%), 5% (MAD: 5% vs. Intraoral pbo device: 10%); 8% (nCPAP: 18% vs. Intraoral pbo device: 10%) | Partially | No
Aarab, 2020^287^ | Unclear | NR | Yes | NA | 6.4 hours (1.8)^*^ | 28% overall; 32% for ESS | 4% | No | No
Andren, 2013^208^ | Yes | NR | Mostly | Yes | NR | 1% | 3% | No | No
Arias, 2005^128^ | NR | NR | Yes (cross-over study) | NA | 7% were nonadherent (used <3.5 hours/night) and excluded from analysis; of the rest: CPAP: 6 hours/night; sham 6 hours/night | 7% | 7% | No | No
Baillieul, 2021^288^ | Yes | Yes | No | NA | CPAP: 66% used device ≥4 hours/night; Sham CPAP: 37% used device ≥4 hours/night | 12.5% | 25% | Yes | No
Ballester, 1999^160^ | NR | NR | Yes | NA | Mean CPAP 5.2 hours/night; 73% used it >4.5 hours/night | 0% | 0% | No | No
Banghøj, 2021^161^ | Yes | Unclear | Partially | NA | 44% used CPAP >4 hours/night more than 70% of nights | 17% | 5.5% | No | No
Barbe, 2001^127^ | Yes | NR | Yes | NA | CPAP: 5 hours/night; Sham: 4 hours/night | 2% | 2% | No | No
Barbe, 2010^162^ | Yes | Yes | Mostly | NR | CPAP: mean use 4.7 hours/night | 4% | 6% | No | No
Barbe, 2012^163^ | Yes | Yes | Yes, although AHI was a little higher in CPAP group | NA | CPAP: median 5 hours/night; 36% with mean use <4 hours/night | Loss to followup: 17% | 1% | No | No
Barnes, 2004^164^ | Yes | Yes | Yes | NA | CPAP: 3.6 hours/night; MAD: 5.5 hours/night; Pbo: 94.3% | 23% | 6% | Yes, high overall | No
Bigini, 2019^289^ | Yes | Yes^†^ | NR | NR | Calculated mean CPAP: 5.3 hours/night | 23% | 43% | Yes | No
Bloch, 2000^209^ | Yes | NR | Yes (cross-over study) | NA | MADs: ≥4–7 nights/week; No treatment: NA | 0% | NA | No | No
Campos-Rodriguez, 2006^129^ | NR | Unclear | Yes | NA | 5.0 vs. 4.4 hours/day for CPAP vs. sham | 6% | 0% | No | No
Campos-Rodriguez, 2016^165^ | Yes | Yes | Minor^ǂ^ differences between CPAP vs. control in mean age (56 vs. 59), % smokers (47 vs. 36), and % using sedative drugs (23 vs. 28) | NA | 5% did not tolerate or begin CPAP; mean use was 4.8 hours/day (SD: 2.5) in those who began CPAP | 3% | 0% | No | No
Caples, 2019^290^ | Yes | Yes | Yes | NA | Mean 6 hours, 60% <4 (3 months) and 71.8% >4 (12 months) | 42% | 9% | No | 2 crossed over
Chasens, 2014^130^ | Yes | NR | Partially | NA | 74% adherent for ≥4 hours/night | 4.3% | 9% | No | No
Chong, 2006^131^ | NR | No | Yes | NA | 5.2 hours/night | 5% | 0% | No | No
Coughlin, 2007^132^ | Yes | NR | Yes (cross-over) | NA | CPAP: 3.9 hours/night; Sham CPAP: 2.6 hours/night | 3% | 0% | No | No
Craig, 2012^166^; MOSAIC | Yes | Yes | Yes | NA | Median CPAP usage: 2.39 hours/night (IQR: 0.36 to 4.59) | 13% for the coprimary outcome ESS (lower for some secondary outcomes) | For ESS: 0%; CPAP: 25 (13%); Standard: 25 (13%) | No | No
Dalmases, 2015^167^ | Yes | Yes | Yes | NA | NR | 6% | 0% | No | No
Durán-Cantolla, 2010^133^ | Yes | Yes | Yes | NA | Mean 4.2 (sham) to 4.5 (CPAP) hours/day over 12 weeks; 59% (sham) and 65% (CPAP) used >4 hours/day | 20% did not complete the trial (either refused to continue, were intolerant of CPAP, had protocol violation, or had technical problems) | 2% | Borderline for overall attrition; no for differential attrition | No
Durán-Cantolla, 2015^210^ | Yes | Yes | NA (cross-over) | NA | MAD: 6.4 hours/night; Pbo: 6.2 hours/night | 10% | 5% | No | No
Egea, 2008^134^ | NR | NR | Yes based on N randomized, but partially based on N analyzed | NA | NR | 18% | 4% | No | No
Engleman, 1994^168^ | NR | NR | Yes | NA | CPAP: mean 3.7 hours/night | 9% | Unclear | No | No
Engleman, 1997^169^ | NR | NR | Yes | NA | CPAP mean 3.2 hours/night | 11% | 20% | Partially | No
Engleman, 1998^170^ | NR | NR | Yes | NA | Mean CPAP runtime: 3.2 hours/night; effectively used 2.8 hours/night | 0% | 0% | No | No
Engleman, 1999^171^ | NR | NR | Yes | NA | CPAP 3.5 hours/night | 8% | NR (at most 8%) | No | No
Faccenda, 2001^172^ | NR | NR | Yes (cross-over study) | NA | 47% of patients used CPAP ≥3.5 hours/night; mean use 3.3 hours/night; pbo adherence almost 100% | 4% | 2% | No | No
Gagnadoux, 2017^216^ | Yes | Yes | No, but only a few differences | NA | 6.6 hours/night in effective MAD group; 96.1% compliance | 18% | 1% | No | No
Gottlieb, 2014^173^; Lewis, 2017^174^; HeartBEAT | Yes | Yes | Partially | NA | CPAP: 3.5 hours/night; Mean oxygen: 4.8 hours/night | 12% for primary outcome; 5% to 7% for other outcomes | 3% to 7% | No | No
Haensel, 2007^135^ | NR | NR | Yes | NA | CPAP: 6.6 hours/night; Sham CPAP: 6.0 hours/night | 0% | 0% | No | No
Hoyos, 2012^136^ | Yes | Yes | Yes | NA | CPAP: 3.6 hours/night; Sham CPAP: 2.8 hours/night | Loss to followup at 12 weeks: 20%; Missing data for ESS and BP: 23% | 11% (from published correction); 2% (from Table 2) | Yes | No
Hui, 2006^137^ | NR | NR | Yes | NA | CPAP: 5.1 hours/night; Sham: 2.6 hours/night | 18% | 0% | No | No
Jackson, 2021^175^; Jackson, 2019^176^ | Unclear | Unclear | No | NA | CPAP group used their CPAP for an average of 4.5 (2.6) hours/night | 15% | 10.6% | No | No (Note: pool together CPAP and CPAP plus education groups)
Jenkinson, 1999^138^; Hack, 2000^139^ | NR | Yes | Yes | NA | CPAP: 5.4 hours/night; Sham: 4.6 hours/night | 6% | 4% | No | No
Johnston, 2002^214^ | NR | NR | Yes | NA | MAD 68% every or almost every night; 79% ≥4 hours/night | 5% | 5% | No | No
Jones, 2013^140^ | Yes | NR | Yes | NA | CPAP: 3.0 hours/night; Sham CPAP: 2.0 hours/night | 19% | 5% | No | No
Kushida, 2012^141^; Batool-Anwar, 2016^142^; APPLES | Yes | Yes | Yes | NA | CPAP: 5.8 hours/night; Sham: 4.3 hours/night | 23% (for ESS at 6 months; varies by outcome and timing) | 5% | Yes | No
Lam, 2007^177^ | Yes | NR | Yes | NA | CPAP: 4.2 hours/night; MAD: 6.4 hours/night | 10% | 3% to 12% | Partially | Partially
Lam, 2010^143^ | Yes | NR | Yes | NA | CPAP: 6.2 hours/night; Sham: 4.5 hours/night | 0% | 0% | No | No
Lee, 2011^144^ | NR | NR | Yes | NA | CPAP: 5.0 hours/night; Pbo CPAP: 6.9 hours/night | NR, presume 0 | NR, presume 0 | No | No
Lim, 2007^178^ | NR | NR | Yes | NA | NR | 0 | 0 | No | No
Loredo, 2006^145^ | NR | NR | Yes | NA | CPAP: 6.6 hours/night; Sham CPAP: 6.0 hours/night | Unclear which exclusions were prior to vs. after randomization (maximum would be 17%) | NR | No for overall; unclear for differential | No
Lui, 2020^179^ | Yes | NR | Yes | NA | 55.6% (treatment group) >4 hours/night | No attrition, though noncompliance used in per-protocol analysis | 0% | No | No
Malow, 2008^219^ | Yes | Yes | Yes | NA | CPAP: 4.7 hours/night; Sham CPAP: 3.6 hours/night | 9% | 14% | Yes; all noncompleters were from G1; 9% of G1 dc due to inability to tolerate CPAP, perhaps due to higher severity | No
Marklund, 2015^217^ | Yes | Yes | Partially | NA | Active appliance group wore for mean of 86% of nights, pbo for 83% of nights, >75% of those in both groups wore for full night | 5% | 2% | No | No
Marshall, 2005^146^ | Yes | Yes | Yes (cross-over study) | NA | CPAP: 4.9 hours/night; Sham CPAP 4.9 hours/night | 7% | <1% | No | No
Martinez-Garcia, 2013^180^; HIPARCO | Yes | Yes | Yes | NA | CPAP: 5 hours/night; 72% ≥4 hours/night | 10% | 2%: CPAP: 11/98=11%; Control: 9/96=9% | No | No
Martínez-García, 2015^181^ | Yes | Yes | Yes | NA | 69.9% >4 hours | 17.9% | 27.4% | Yes | No
Masa, 2015^182^; Pickwick | Yes | Yes | Partially, no formal statistical comparison, appear to be some slight differences in various comorbidities and drinking | NA | Mean compliance 5.3 hours/day | CPAP and control only: 9.3% (14/150); CPAP, NIV, and control: 9.5% (21/221) | 10% | No | No
McArdle, 2001^183^ | Yes | Yes | NA (cross-over) | NA | Median 4.5 hours/night | 4% | 4% | No | No
McMillan, 2014^184^; PREDICT | Yes | Yes | Partially | Yes | 71% reported still using CPAP at 12 months; at 3 months, median usage of 1 hour 52 minutes per night; at 12 months, 2 hours 22 minutes/night 35% at 3 months and 35% at 12 months used CPAP >4 hours/night | 17% | 4%:; CPAP: 26/140=19%; BSC: 21/138=15% | No | No
Melehan, 2018^147^ | Yes | Yes | Yes | NA | ≥4 hours/night: 39% of CPAP users (mean use 3.7 hours/night) and 27% of sham users (2.6 hours/night) | 10% | 7% | No | No
Montserrat, 2001^148^ | Yes | NR | Partially | NA | CPAP 4.3 hours/night; sham 4.5 hours/night | 4% | 0% | No | No
Naismith, 2005^211^; Gotsopoulos, 2002^212^; Gotsopoulos, 2004^213^ | Yes | Yes | Yes (cross-over study) | NA | Both MAD and sham MAS: 6.7 hours/night; 96% to 97% of nights | 9% | 5% | No | No
Neikrug, 2014^149^ | Yes | NR | Yes | NA | CPAP: 5.2 hours/night | 18% | 5% | No | No
Ng, 2018^197^ | Yes | Unclear | Yes | NA | 71% used CPAP >4 hours/night (mean 5 and 5.2 hours/night at 1 and 3 months, respectively) | 19% | 13% | Yes | No
Nguyen, 2010^150^ | NR | NR | Yes | Yes | Assessed but NR | 0% | 0% | No | No
Peker, 2016^185^; Balcan, 2019^186^; Celik, 2021^187^; Celik, 2021^198^; Wallstrom, 2019^200^; RICCADSA | Unclear | Yes | Yes | NA | 4.4–6.6 hours/night (1 month to 6 years) | 41% based on primary outcome, unclear on depression and anxiety outcomes | 12% based on primary outcome, unclear on depression and anxiety outcomes^§^ | Yes | Partially (22 of the no CPAP group started CPAP during the full study, 5 within the first year, which is the period for the Celik and Balcan studies), would bias the results toward the null
Pepperell, 2002^151^; Kohler, 2008^152^ | NR | NR | Yes | NA | CPAP: 4.9 hours/night; Sham CPAP: 4.5 hours/night | 20% (for missing blood pressure data) | 1% (for blood pressure outcomes) | No | No
Petri, 2008^218^ | Yes | Yes | Yes | NA | NR | 13% | 1%-15% | Partially (G1 vs. G3) | No
Phillips, 2011^153^ | Yes | Yes | Yes | NA | CPAP: 4.4 hours/night; Sham CPAP: 3.4 hours/night | 24% | 5% | Yes overall, but not differential | No
Ponce, 2019^188^ | Yes | Yes | Yes | NA | 73% ≥4 hours/night | ESS: 2.1%; QSQ: 4.8% | NR | No | No
Quinnell, 2014^215^; TOMADO | Yes | Yes | Yes | NA | Mean (SD) for 3 MAD groups: 4.4 (2.4) to 5.7 (2.0) hours/night | 18% did not complete; 8% not analyzed | Low when comparing most groups, but high for bMAD group vs. others (17% to 30% differential) | Yes (high differential attrition for bMAD group compared with other groups) | No
Redline, 1998^189^ | Yes | NR | Mostly (slightly higher RDI in CPAP arm, and fewer women) | NA | CPAP: 44% of sleep time; 3.1 hours/night; CT: 82% of nights | 13% | 2% | No | Possibly^ǁ^
Robinson, 2006^154^ | NR | Yes | Yes | NA | CPAP: 5.2 hours/night; Sham CPAP: 4.3 hours/night | 9% | 9% | No | No
Ruttanaum-pawan, 2008^190^; Kaneko, 2003^191^ | NR | NR | Partially; higher AHI in control, but they adjusted for it in analyses | NA | CPAP: 6.2 hours/night | NR, presume 0 | NR, presume 0 | No | No
Salord, 2016^192^ | Yes | Yes | Yes | NA | Mean 5.4 hours per night, 86% >4 hours at 12 weeks | Tx: 9 lost, 3 noncomplete (22%); C: 6 lost (13%) | 9% | No | NR
Schwarz, 2018^291^ | Yes | NR (reported blinding for patients and outcome assessors, but NR for others on the research team such as those enrolling participants) | Yes, except the therapeutic group had more patients with HTN | NA | 6 to 7 hours per night | 46.6% | 9% (12/23 [52%] vs. 9/22 [41%]) | Yes | No
Shaw, 2016^193^ | Yes | Yes | Yes | NA | Mean PAP use: 3 hours/night at 3 months; 4.9 hours/night at 6 months; 45% adherent at 3 months; 61.3% adherent at 6 months | 14.1% | 13.8% | Yes; there was 14% differential attrition due to treatment intolerance in the intervention arm | No
Siccoli, 2008^155^ | NR | NR | Yes | NA | CPAP: 4.7 hours/night; Sham CPAP: 3.9 hours/night | 3% | 2% | No | Possibly: 52 has been involved in previous study on CPAP effect on BP
Smith, 2007^156^ | Yes | NR | Yes | NA | CPAP: 3.5 hours/night; Sham: 3.3 hours/night | 15% | Unable to determine | No | No
Tomfohr, 2011^194^ | NR | NR | Yes | NA | CPAP: 5.5 hours/night; Sham CPAP: 6.6 hours/night | 17% | 4% | No | No
Traaen, 2021^199^ | Yes | Yes | Unclear | NA | 66.7% used CPAP ≥4 hours/night (mean 5.3 hours/night) | 5% | 2% | No | No
Weaver, 2012^157^; CATNAP | Yes | Yes | Yes, except slightly higher score on mental health component of SF-36 for sham CPAP group | NA | CPAP: 4.0 hours/night; Sham: 3.1 hours/night | Overall: 21% who were randomized were not included in analyses (15% withdrew prior to receiving CPAP or sham; another 6% were missing for the primary outcome) | 1% | Yes, high overall | No
Weinstock, 2012^201^; Redline, 2014^220^ | Yes | NR | Yes | NA | Mean CPAP use: 4.8 hours/night; Mean sham CPAP: 3.4 hours/night; p<0.1 | 2% (1 participant completed the first [CPAP] period only) | 4% | No | No
West, 2007^158^; West, 2009^159^ | Yes | NR | Yes | NA | CPAP: 3.6 hours/night; Sham CPAP: 3.3 hours/night | 5% | 0% | No | No
Wimms, 2020^195^; MERGE | Yes | Yes | Yes | NA | Median CPAP use: 4 hours/night (range, 1.36–5.44) | 10% | 5% | No | No
Zhao, 2017^196^; BestAIR | Yes | Yes | Yes | NA | Mean CPAP use, first 6 months: 3.8 hours/night; 51.8% used for ≥4 hours/night (43.4% adherent by Medicare definition; Note: adherence data only available for one arm [CPAP] out of 4 arms) | 18% | 0.5% | No | No

* We used the data from Table 4 and not the text of the publication. There was a discrepancy between the two.

† Answered using the study’s methods article: https://www.ncbi.nlm.nih.gov/pmc/articles/PMC6311443/.

ǂ The BMI difference was statistically significant, but mean difference was very small and unlikely clinically important (33.8 vs. 33.5).

§ Depression and anxiety participants were only included if they had data available.

ǁ Subjects with symptoms of nasal congestion were provided with a nasal steroid spray, and it is NR whether there was an equal proportion of such patients in each arm. Control patients got nasal dilator strips.

Abbreviations: AHI=apnea-hypopnea index; APPLES=Apnea Positive Pressure Long-term Efficacy Study; BSC=best supportive care; BestAIR=Best Apnea Interventions for Research; bMAD=fully bespoke mandibular advancement device; BMI=body mass index; BP=blood pressure; BQ=Berlin Questionnaire; CATNAP=CPAP Apnea Trial North American Program; CPAP=continuous positive airway pressure; CT=conservative therapy; ESS=Epworth Sleepiness Scale; G=group; HeartBEAT=Heart Biomarker Evaluation in Apnea Treatment; HTN=hypertension; IQR=interquartile ratio; KQ=key question; MAD=mandibular advancement device; MAS=mandibular advancement splint; MOSAIC=Multicentre Obstructive Sleep Apnoea Interventional Cardiovascular; MVAP=Multivariable Apnea Prediction; N=number; NA=not applicable; nCPAP=nasal continuous positive airway pressure; NIV=noninvasive ventilation; NR=not reported; OSA=obstructive sleep apnea; PAP=positive airway pressure; pbo=placebo; PSG=polysomnography; QSQ=Quebec Sleep Questionnaire; RCT=randomized, controlled trial; RDI=respiratory disturbance index; SD=standard deviation; SF-36=Medical Outcome Short-Form (36-Item) Health Survey; STOP=Snoring, Tiredness, Observed apnea, blood Pressure; TOMADO=Trial of Oral Mandibular Advancement Devices for Obstructive sleep apnoea-hypopnoea; tx=treatment; vs.=versus.

Appendix D Table 6 Quality Ratings of Randomized, Controlled Trials of Interventions for OSA (KQs 5 and 6)

First author, Year; Trial name | Were outcome measurements equal, valid, and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the study use acceptable statistical methods? | Quality rating | Comments
Aarab, 2011^206^; Nikolopoulou, 2020^207^ | Yes | Partially | NR | Partially; both oral appliance groups were masked for question-naires | Yes | Worst- and best-case sensitivity analyses | Yes | Fair | Differential attrition between two treatment groups; do not suspect that this contributes to significant bias when both groups are compared to pbo. Only the comparison of the active and sham oral device was masked; patients receiving CPAP were not masked.
Aarab, 2020^287^ | Yes | No | No | No | Yes | None | No | Poor | High attrition, inappropriate statistical methods, no adjustment for potential confounders, unlikely that analysis of ESS considered baseline values to guard against risk of bias.
Andren, 2013^208^ | Yes | Yes | NR | Yes for ambulatory BP monitoring and AHI; NR for ESS | Yes | BOCF | Yes | Fair | Allocation concealment is not described. Compliance with intervention and control is not described. More patients in the control group were on antihypertensive medications compared to the active treatment group (47% vs. 25%, respectively). Not clear whether changes in antihypertensives were allowed during the trial (and BP measures are the primary outcome).
Arias, 2005^128^ | Yes | Yes | NR | NR | Yes | Excluded | Partially | Fair | Excluded nonadherent patients from analysis, but N=2. No description of randomization or blinding of assessors.
Baillieul, 2021^288^ | Yes | Yes | Yes | Yes | Yes - ESS; Unclear-MMSE | None | No | Poor | Baseline AHI was higher in the CPAP group than Sham CPAP (54 vs. 38 events/hour); other measures of OSA severity were also higher in CPAP group (e.g., ODI, time spent with Sp% <90%). Adherence was lower in the Sham CPAP vs. CPAP group (37% vs. 66%), suggesting participants may have been aware of treatment assignment. Small sample size (n=24) with differential attrition of 25% due to 3 participants lost to followup in the CPAP arm. No analysis to address missing data.
Ballester, 1999^160^ | Yes | No | No | No | Yes | NR, but suggests there was no missing data | Yes | Fair | No masking; methods of randomization and allocation concealment NR.
Banghøj, 2021^161^ | Yes | No | No | No | Yes | NR | NR, did not use ITT but used controlled regressions | Fair | Differences based on BMI, no information on concealment, adherence to CPAP was low. Masking not possible. No information on how missing data were handled, mention some missing data for some outcomes, not sure if it affected ESS. Looks like they only included those with completed CGM data but probably did not affect ESS data.
Barbe, 2001^127^ | Yes | Yes | NR | Yes | Yes | Excluded | Yes | Fair | Methods of allocation concealment NR.
Barbe, 2010^162^ | Yes | No | NR | NR | Yes | None | Yes | Fair | Differences in baseline AHI and other variables associated with OSA severity (oxygen saturation) were statistically significant but unlikely to be clinically significant. Multiple ROB domains NR. This is a completers’ analysis; however, overall and differential attrition are low and unlikely to bias results.
Barbe, 2012^163^ | Unclear (the composite outcome lumps less severe with more serious outcomes) | No | No | Yes | Yes | None (exposure time ended upon withdrawal or loss to followup) | Yes | Fair | Outcome assessors were masked, but statisticians and researchers were not. No sham CPAP (control group received nothing). Could perhaps have improved blood pressure measurement validity/reliability if using 24-hour ambulatory blood pressure monitoring. Trial may have been underpowered. Some concern with using a composite outcome that combines incidence of HTN with CV events. The latter have a much more significant impact on health and quality of life (and there were few events).
Barnes, 2004^164^ | Yes | Yes | NR | NR | Yes | Multiple imputation | Yes | Fair | Risk of attrition bias; masking of providers and outcome assessors NR.
Bigini, 2019^289^ | Yes: Pittsburgh Sleep Quality Index; ESS | Yes | Yes^*^ | No: PSIQ and ESS are self-report | Yes | None | No | Poor | Very small subset of patients enrolled in a large, randomized trial that has not yet been reported. It is unclear whether the subsample was randomly selected. Significant attrition and attrition differences.
Bloch, 2000^209^ | Yes | No | NR | NR | Yes | NA | Yes | Fair | Open-label trial for patients; other masking NR; sequential open-label tx could bias self-reported outcomes.
Campos-Rodriguez, 2006^129^ | Yes | Yes | Yes | Yes | Yes | None, excluded | Other than no handling of missing data, acceptable methods | Fair | Methods or generating randomization sequence NR; unclear if allocation concealed (used presealed envelopes, but unclear whether the person assigning to treatment groups was the person who knew the sequence and filled the envelopes).
Campos-Rodriguez, 2016^165^ | Yes | No | Partially | Partially | Yes | Imputed (baseline observation carried forward) for QSQ; unclear for other measures | Yes | Fair | Some baseline differences between groups (control group slightly older and higher proportion were using sedative drugs). Those in treatment arm had additional visits for mask fitting; however, authors stated that no additional counseling was provided. Missing data were addressed for primary outcome only; however, overall attrition was low and not differential.
Caples, 2019^290^ | Yes | No | NR | NR | Yes | NR | NR | Poor | Small study, 42% lost to followup, low external validity.
Chasens, 2014^130^ | Yes | Yes | NR | No | Yes | NR | Yes | Fair | Very small study (N=23) that aimed to determine feasibility of conducting an RCT of CPAP vs. sham CPAP focused on improving activity; Baseline AHI and oxygen desaturation indexes were higher in the active CPAP group; research staff were masked to group except for the night PSG technician who performed the overnight titration and the study’s sleep physician co-investigator.
Chong, 2006^131^ | Yes | Yes | No | Yes | Yes | NR | NR, unclear if ITT or per protocol analysis; otherwise acceptable | Fair | Methods of randomization NR; lack of allocation concealment. Likely used completers analysis because no description of handling of missing data, but very low attrition (1 person in each group at 3 weeks).
Coughlin, 2007^132^ | Yes | Yes | Yes | Yes | Yes | Excluded | Yes | Good | Only 1 person lost/excluded, and since it is cross-over, not a big concern.
Craig, 2012^166^; MOSAIC | Yes | No | No | Partially | Yes for the primary outcomes; likely not adequate for some secondary outcomes (e.g., stroke, vascular events) | None for primary outcomes and most secondary outcomes; used multiple imputation for risk score analyses | No, completers analysis (analyzed on ITT basis but excluded those with missing data and those who attended their 6-month visit either more than 4 weeks earlier or 8 weeks later than the expected data) | Fair | Lack of masking (according to the supplemental appendix, “it was not possible to blind all trial staff, although the assessments were done blind whenever possible”); completer’s analysis (but not a lot of missing data).
Dalmases, 2015^167^ | Yes | No | No | Partially (some patient reported and not blinded) | Yes | NR | NR | Fair | Did not use ITT, unclear how missing data were handled. Providers and pts unable to be masked.
Durán-Cantolla, 2010^133^ | Yes | Yes | Yes | Yes | Yes | Baseline observation carried forward | Yes | Good | Although the study had borderline overall attrition, with 20% not completing the 12-week study; they used a conservative BOCF analysis (assuming that blood pressure was not changed from baseline) for people who did not complete. ITT analysis with all randomized subjects. No medications were allowed for hypertension during the study.
Durán-Cantolla, 2015^210^ | Yes | Yes | Yes | Yes | Yes | NR; looks like excluded | Partially | Good | Small amount of missing data excluded.
Egea, 2008^134^ | Yes | Yes | NR | Partially | Yes | Excluded | Partially | Fair | Completer’s analysis, no information on randomization, blinding of outcome assessors other than pts.
Engleman, 1994^168^ | Yes | Yes | NR | NR | Yes | Excluded from analysis | Yes, other than exclusion of missing | Fair | Self-reported outcome assessors masked because patients were masked.
Engleman, 1997^169^ | Yes | Yes | NR | NR | Yes | Excluded from analysis | Yes, other than exclusion of missing | Fair for cognitive out-comes; Poor for ESS | Only 9 of 18 reported ESS, unclear how many from each arm.
Engleman, 1998^170^ | Yes | Yes | No | NR | Yes | NR | Yes | Fair | Methods of randomization and allocation concealment NR; not clear if outcome assessors masked; approach to missing data NR.
Engleman, 1999^171^ | Yes | Yes | NR | Partially | Yes | Excluded | Yes | Fair | Methods of randomization and allocation concealment NR; outcome assessors not masked for some outcomes (patient-reported outcomes masked, others NR).
Faccenda, 2001^172^ | Yes | Yes | NR | Yes | Yes | Excluded | Yes | Fair | Consider patients masked because they were told that pbo was beneficial. Poor adherence to CPAP, but analysis of all pts vs. adherent yielded same result for BP; since outcomes were self-reported or via 24-hour BP monitor, consider outcome assessors masked.
Gagnadoux, 2017^216^ | Yes | Yes | No | Yes | Yes | Multiple imputation for primary measures, but no information regarding secondary measures (i.e., ESS, OSA symptoms) | Yes | Fair | Some baseline differences that may have introduced bias: significantly more women in the MAD arm, and more than twice as many current smokers in the sham arm as the MAD arm (difference nearly significant).
Gottlieb, 2014^173^; Lewis, 2017^174^; HeartBEAT | Yes | No | Unclear | Yes | Yes | Excluded, though they did multiple imputation sensitivity analyses | Yes | Good | Since all outcomes were objectively recorded, not concerned about lack of blinding causing bias.
Haensel, 2007^135^ | Yes | Yes | NR | NR | Yes | NA | Unclear | Fair | No clear method of randomization/allocation; masking NR for providers and assessors so questionable for AHI (self-report outcomes masked).
Hoyos, 2012^136^ | Unclear | Yes | Yes | Yes | Yes | None | No, completers analysis | Fair | Moderate risk of attrition bias, but it was nondifferential for outcomes eligible for our review (ESS, BP); no handling of missing data; completers analysis.
Hui, 2006^137^ | Yes | Yes | Yes | Yes | Yes | None, excluded subjects with missing data | No, completers analysis; otherwise acceptable | Fair | Methods of randomization and allocation concealment NR. Completer’s analysis introducing some risk of selection bias and confounding but, low attrition and no differential attrition.
Jackson, 2021^175^; Jackson, 2019^176^ | Yes | No | No | Partially | Yes | Multiple imputation | Yes | Fair | No details provided on randomization and concealment process. Patients and providers unable to be masked. Outcome assessors partially masked, clinical interviews were blinded but ESS was not. Somewhat high differential attrition (10.6 percentage points).
Jenkinson, 1999^138^; Hack, 2000^139^ | Yes | Yes | No | Yes | Yes | None, excluded | Other than no handling of missing data, acceptable methods | Fair
Johnston, 2002^214^ | Yes | Yes | NR | NR | Yes | None, excluded | Minimal reporting of methods, completers analysis | Fair | Methods of randomization and allocation concealment NR. Missing data excluded, but little missing data.
Jones, 2013^140^ | Yes | Yes | Yes | Yes | Yes | Excluded non-completers | Yes | Fair | Inadequate methods of handling missing data, allocation concealment NR.
Kushida, 2012^141^; Batool-Anwar, 2016^142^; APPLES | Yes | Yes | Yes | Yes | Yes | None | Yes | Fair | High overall attrition; no imputation was performed except for the analysis of adherence, where one version imputed missing values to zeros; analyses used GEE, GLM, or GLMM approaches.
Lam, 2007^177^ | Yes | No | No | NR | Yes | Missing values replaced by baseline values | Yes | Fair | Many but not all subjects were referred to a weight-loss program; NR which proportion in each arm; contamination possible. Since more patients withdrew from control arm vs. CPAP and BL values were imputed, it could bias the result against the null. Not as much concern about MAD vs. control; similar rates of attrition.
Lam, 2010^143^ | Yes | Yes | Yes | NR | Yes for AHI; unclear for ESS and BP | NA, no missing values for outcomes of interest | Yes | Fair | Methods of allocation concealment NR; unclear if outcome assessors were masked; only 1 week of followup (focus was on insulin sensitivity measures, but they also report AHI, ESS, and blood pressure).
Lee, 2011^144^ | Yes | Yes | Yes | Yes | Uncertain | NA | Yes | Fair | No mention of how patients were randomized. CPAP group was less compliant than the sham CPAP group. Uncertain if 3 weeks is long enough for cognitive changes.
Lim, 2007^178^ | Yes | Yes | Yes | Yes | Unclear | NA | Yes | Fair | Information on methods of randomization and allocation concealment was not described. Compliance with CPAP and sham CPAP was not described. The authors noted that 2 weeks may not be sufficient time to assess for improvements in some neurocognitive measures.
Loredo, 2006^145^ | Yes | Yes | Yes | Yes | Yes | Excluded | Other than no handling of missing data, acceptable methods | Fair | Methods of randomization and allocation concealment NR. Ns randomized are NR; thus attrition rates by group are unclear (but max overall attrition was 17%, depending on whether some of the exclusions were pre- or post- randomization. Missing data excluded from analysis; completers only.
Lui, 2020^179^ | Yes | No | No | No | Yes | NA | Yes | Fair | CPAP vs. no treatment control, not masked, low adherence at 56% to CPAP >4 hours/night.
Malow, 2008^219^ | Yes | Yes | Yes | Yes | Yes | Excluded | Partially | Fair | Only usable outcome in this study is AHI, and it is only at 2 nights; pilot/feasibility study not designed to examine efficacy.
Marklund, 2015^217^ | Yes | Yes | No | Yes | Yes | NR | No, however did used controlled regressions for analyses if continuous outcomes | Fair | Not ITT (although relatively few dropped out), differences in age at baseline, no information on missing data, providers unable to be masked.
Marshall, 2005^146^ | Yes | Yes | Yes | Yes | Yes | Excluded | Partially | Good | Excluded nonadherent patients from analysis, but N=2. Adjusted appropriately.
Martinez-Garcia, 2013^180^; HIPARCO | Yes | No | No | No | Yes | Multiple imputation | Yes | Fair | ESS is patient rated and thus could be biased.
Martínez-García, 2015^181^ | Yes | No | No | Yes | Yes | Imputed | ITT | Fair | High overall attrition (18%) and differential attrition (27%, higher in control group); imputation used to address missing data in analysis. However, unclear whether those lost to followup had worse outcomes at baseline or higher rates of OSA symptoms during study. Potential for reporting bias; sleep-related QOL measure reported as individual domain scores only, not overall score.
Masa, 2015^182^; Pickwick | Yes | No | No | No | Yes | Multiple imputation | Yes | Fair | May be some differences at baseline in comorbidities, differential attrition close to 10%, and unclear if providers and assessors were blinded (probably not a major concern). Also note that noninvasive ventilation is one of the tx arms.
McArdle, 2001^183^ | Yes | Yes | NR | Yes | Yes | NR | Mostly | Fair | Very small sample size; missing data excluded.
McMillan, 2014^184^; PREDICT | Yes | No | No | No | Yes | Sensitivity analyses with multiple imputation | Yes | Fair | Eligible outcomes were questionnaires filled out by patients who were not blinded.
Melehan, 2018^147^ | Yes | Yes | Yes | Yes | Yes | Unclear | Yes: ITT | Fair | Not clear whether sexual function is acceptable outcome. Secondary outcomes do not have means associated with them, only a statement that there were no CPAP related differences. Adherence generally low.
Montserrat, 2001^148^ | Yes | Yes | NR | Yes | Yes | None, excluded | Other than no handling of missing data, acceptable methods | Fair | Methods of allocation concealment NR; excluded dropouts, but just 1 in each group.
Naismith, 2005^211^; Gotsopoulos, 2002^212^; Gotsopoulos, 2004^213^ | Yes | Yes | Yes | Yes | Yes | Conducted both ITT and completers | Yes | Good
Neikrug, 2014^149^ | Yes | Yes | No | Yes | Yes | None, excluded | Other than no handling of missing data, acceptable methods | Fair
Ng, 2018^197^ | Yes | No | No | Partially | Yes | ITT | Yes | Fair | Potential for selection bias was present because a portable home study, rather than PSG, was used to diagnose OSA, possibly leading to some missed cases. Overall attrition and differential attrition of 19% and 13%, respectively, may have introduced potential bias, but there is no evidence this substantially affected findings. Several important factors—baseline asthma control, sleepiness, and nocturnal symptoms—were similar between those who dropped out and study completers. Unclear if allocation concealment was used in randomizing the sample.; This paper did not report whether allocation concealment took place in the article or supplement. There was no sham CPAP, so the study is not blinded. Outcomes are non-OSA related questionnaires, but it was not stated whether questionnaires were administered by someone blinded. This study had appropriate adherence. The attrition is higher in control arm.
Nguyen, 2010^150^ | Yes | Yes | NR | Yes | Yes | NA | NR | Fair | Multiple ROB domains NR (e.g., randomization, allocation concealment, and adherence).
Peker, 2016^185^; Balcan, 2019^186^; Celik, 2021^187^; Celik, 2021^198^; Wallstrom, 2019^200^; RICCADSA | Yes | No | No | Partially | Yes | LOCF, imputation | Yes | Fair | Group assignment was based on the cardiorespiratory PG recordings, unable to mask patients and providers. High attrition for the Peker study, but very long followup, appears to be differential attrition in Celik and Balcan, but some lack of clarity on attrition and sample sizes.
Pepperell, 2002^151^; Kohler, 2008^152^ | Yes | Yes | Yes | Yes | Yes | BOCF (assumed no change in BP for missing) | Yes | Fair | Methods of sequence generation and allocation concealment NR (they used presealed and numbered envelopes, but NR whether the nurse who assigned groups filled the envelopes).
Petri, 2008^218^ | Yes | Yes (G1 vs. G2) No (G1 vs. G3) | Yes (G1 vs. G2) No (G1 vs. G3) | Yes (G1 vs. G2); No (G1 vs. G3) | Yes | Sensitivity analyses with different scenarios | Partially | Fair | Active vs. sham MAD was triple-masked; no masking in the no treatment arm. Not concerned about the small amount of cross-over (2 total subjects) and that would bias results toward null (not in favor of the MAD). Missing data handled by use of sensitivity analyses, but those results are not presented.
Phillips, 2011^153^ | Yes | Yes | Yes | Yes | Yes | Excluded; completers only | Other than no handling of missing data, acceptable methods | Fair | 24% overall attrition (but low differential attrition); no handling of missing data.
Ponce, 2019^188^ | Yes | No | No | Not for ESS or QSQ | Yes | ITT with multiple imputation | Yes | Fair | Unclear about measurement and reporting of sleep-related symptoms. Neither participants nor providers blind to group assignment; some difference in attrition but minimal.
Quinnell, 2014^215^; TOMADO | Yes | No | No | Yes for AHI; unclear for other outcomes | Yes | None, excluded | Other than no handling of missing data, acceptable methods | Fair | Open-label trial; high differential attrition between some groups (but overall attrition and missing data were not high).
Redline, 1998^189^ | Yes | No | NR | NR | Yes | Excluded but examined in sensitivity analyses | Yes | Fair | Methods of allocation concealment NR; no masking reported.
Robinson, 2006^154^ | Yes | Yes | Yes | Yes | Yes | None, excluded | Yes | Fair | Method of random sequence generation NR; missing data were excluded from analysis.
Ruttanaum-pawan, 2008^190^; Kaneko, 2003^191^ | Yes | No | No | Yes | Yes | NA | Yes | Fair | Open-label trial, randomization and allocation NR, big difference in AHI at BL that would favor CPAP, but they adjusted for it. Good adherence; seems like no attrition.
Salord, 2016^192^ | Yes | No | No | No | Yes | Dropped | ITT | Good | Unsure about management of missing data
Schwarz, 2018^291^ | Yes | Yes | NA | Yes | Uncertain | Excluded | No (only analyzed those in the NIRS substudy who also had complete data for certain outcomes) | Poor | High risk of bias due to attrition, missing data, and methods of handling missing data; ESS is the eligible outcome for our purposes (the trial focused more so on outcomes that we’re not looking at, such as measures of cerebral tissue oxygenation).
Shaw, 2016^193^ | Yes | No | No | Yes | Yes | LOCF and imputation | Yes | Fair | Low attrition but significant differential attrition (14%) due to treatment intolerance in the intervention arm. Low adherence to intervention. Missing data addressed by LOCF and imputation.
Siccoli, 2008^155^ | Yes | Yes | Yes | Yes | Yes | ITT: LOCF | Yes | Fair | Methods of randomization and allocation concealment NR.
Smith, 2007^156^ | Yes | Yes | Yes | Yes | Yes | Unclear | Unclear | Fair | Unclear methods of allocation concealment; limited reporting of methods for handling missing data (although attrition was not too high, it was 4/26 participants) and likely nothing done to handle missing data.
Tomfohr, 2011^194^ | Yes | Yes | No | Yes | Yes | None | No, completers analysis | Fair | Methods of randomization and allocation concealment NR; completers only analysis with no handling of missing data, but relatively low attrition and low differential attrition.
Traaen, 2021^199^ | Yes | No | No | Partially | No | ITT | Yes | Fair | This study had decent adherence and very little missing data, so lack of a sensitivity analysis is not concerning. It is mildly underpowered given lower incidence of AF episodes than expected. They did not use sham CPAP, so the study is not blinded.
Weaver, 2012^157^; CATNAP | Yes | Yes | Yes | Yes for primary outcome and most outcomes; those performing PSGs were not masked | Yes | None (21% of those randomized were not included in analyses in their modified ITT) | No, modified ITT does not include 21% of those randomized | Fair | No handling of missing data; 21% of those randomized not included in analyses.
Weinstock, 2012^201^; Redline, 2014^220^ | Yes | Yes | NR | NR | Yes | NR (but just 1 subject with some missing data) | Yes | Fair | Methods of allocation concealment and masking of outcome assessors were not described. Although the sequence 1 group had higher baseline AHI, this is a cross-over and both groups had almost identical AHIs after CPAP and after sham conditions.
West, 2007^158^; West, 2009^159^ | Yes | Yes | Yes | Yes | Yes | Excluded | Partially | Fair | Missing data excluded; consider assessors blinded because outcomes of interest were all patient reported.
Wimms, 2020^195^; MERGE | Yes | No | No | No | Yes | LOCF | Yes | Fair | Patients and providers were unable to be masked. Does not look like assessors were masked; some if not all measures were self-reported.
Zhao, 2017^196^; BestAIR | Yes | Partially (CPAP vs. sham masked, but other tx arms unable to be masked) | No | Partially (yes for nonpatient-reported outcomes) | Yes | NR | Yes | Fair | Providers unable to be masked, attrition, no information on how missing data were handled. Groups were comparable but no information provide on whether they were significant differences between groups.

* Answered using the study’s ClinicalTrials.gov page: https://clinicaltrials.gov/ct2/show/NCT01901055.

Abbreviations: AHI=apnea-hypopnea index; APPLES=Apnea Positive Pressure Long-term Efficacy Study; BestAIR=Best Apnea Interventions for Research; BL=baseline; BMI=body mass index; BOCF=baseline observation carried forward; BP=blood pressure; CATNAP=CPAP Apnea Trial North American Program; CGM=continuous glucose monitoring; CPAP=continuous positive airway pressure; CV=cardiovascular; ESS=Epworth Sleepiness Scale; G=group; GEE=generalized estimating equation; HeartBEAT=Heart Biomarker Evaluation in Apnea Treatment; HTN=hypertension; ITT=intention to treat; KQ=key question; LOCF=last observation carried forward; MAD=mandibular advancement device; MOSAIC=Multicentre Obstructive Sleep Apnoea Interventional Cardiovascular; N=number; NA=not applicable; NIRS=near-infrared spectroscopy; NR=not reported; OSA=obstructive sleep apnea; pbo=placebo; PG=polygraphy; PSG=polysomnography; pts=patients; QSQ=Quebec Sleep Questionnaire; RCT=randomized, controlled trial; RICCADSA=Randomized Intervention with Continuous Positive Airway Pressure in CAD and OSA; ROB=risk of bias; TOMADO=Trial of Oral Mandibular Advancement Devices for Obstructive sleep apnoea-hypopnoea; tx=treatment; vs.=versus.

For RCTs and cohorts, definition of ratings based on below criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.
Poor: Studies are graded “poor” if any of the following fatal flaws exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Appendix D Table 7 Quality Ratings of Randomized, Controlled Trials of Interventions for OSA That Reported Harms (KQ 6)

First Author, Year; Trial Name | Were harms pre-specified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Harms Quality rating | Comments
Aarab, 2011^206^; Nikolopoulou, 2020^207^ | NR | NR | NR | Yes | Fair | Methods NR, but they reported a lot of harms information.
Aarab, 2020^287^ | Yes | Yes | Unclear | Yes | Poor | High attrition, inappropriate statistical methods, no adjustment for potential confounders.
Bloch, 2000^209^ | NR | NR | NR | Yes | Fair | No information on harms assessment, but it looks like they did gather some harms information.
Durán-Cantolla, 2015^210^ | NR | Partially | NR | Yes | Fair | No description of methods for harms assessment.
Engleman, 1999^171^ | NR | NR | NR | Yes | Fair | No description of methods for harms assessment, but they recorded many.
Gagnadoux, 2017^216^ | Yes | Yes | Yes | Yes | Fair | Some baseline differences that may have introduced bias: significantly more women in the MAD arm, and more than twice as many current smokers in the sham arm as the MAD arm (difference nearly significant).
Hui, 2006^137^ | NR | NR | NR | Yes | Fair | Only harm reported was withdrawal due to adverse effects (discomfort).
Johnston, 2002^214^ | Yes | Partially | NR | Yes | Fair
Kushida, 2012^141^; Batool-Anwar, 2016^142^; APPLES | NR | NR | Yes (equal); NR for valid and reliable | Yes | Fair
Lam, 2007^177^ | NR | Partially | NR | Yes | Fair | Page 355: “Side effects of treatment were evaluated by self-reporting using questionnaires in a clinical setting.” Implied prespecification and definition.
Malow, 2008^219^ | NR | Partially | NR | Yes | Fair
Marklund, 2015^217^ | Yes | Yes | Yes | Yes | Fair
Naismith, 2005^211^; Gotsopoulos, 2002^212^; Gotsopoulos, 2004^213^ | Partially | Yes | Unclear | Yes | Fair | Gotsopoulos, 2002, page 744: “A self-administered detailed, in-house questionnaire was used to document … treatment-related side effects …”
Peker, 2016^185^; Balcan, 2019^186^; Celik, 2021^187^; Celik, 2021^198^; Wallstrom, 2019^200^; RICCADSA | Unclear | Unclear | Unclear | Unclear | Poor | No information provided in article or on clinicaltrials.gov on whether harms and adverse events were prespecified, defined, or ascertainment.
Petri, 2008^218^ | NR | NR | NR | Yes | Fair | No description of methods for harms assessment. However, the harms they are reporting were discontinuation due to adverse effects, and the reasons for discontinuation. Therefore, not much concern for high risk of bias despite limited reporting.
Quinnell, 2014^215^; TOMADO | NR | NR | NR | Yes | Fair | No description of methods for harms assessment. However, the harms they are reporting were discontinuation due to adverse effects, and the reasons for discontinuation; therefore, not high risk of bias despite limited reporting.
Redline, 1998^189^ | NR | NR | NR | Yes | Fair | No information on harms assessment, but it looks like they did gather a lot of harms information based on the results reported.
Shaw, 2016^193^ | NR | NR | Probably | Yes | Fair | No description of measurement in methods, but broad harms are reported in results and compared between treatment and control groups post hoc.
Smith, 2007^156^ | NR | NR | NR | Yes | Fair | No information on harms assessment, but it looks like they did gather a lot of harms information based on the results reported.
Weaver, 2012^157^; CATNAP | NR | NR | NR | Yes | Fair | Methods NR, but they reported a lot of harms information.
Weinstock, 2012^201^; Redline, 2014^220^ | NR | NR | Probably | Yes | Fair | Various harms of PAP and Sham PAP reported for both groups, no description of how harms were measured in methods.

Abbreviations: APPLES=Apnea Positive Pressure Long-term Efficacy Study; CATNAP=CPAP Apnea Trial North American Program; KQ=key question; MAD=mandibular advancement device; OSA=obstructive sleep apnea; NR=not reported; RICCADSA=Randomized Intervention with Continuous Positive Airway Pressure in CAD and OSA; TOMADO=Trial of Oral Mandibular Advancement Devices for Obstructive sleep apnoea-hypopnoea.