# Appendix C Excluded Studies

X1 Non-English
X2 Ineligible Population
X3 Ineligible Screening
X4 Ineligible Treatment
X5 Ineligible Comparison
X6 Ineligible Outcome
X7 Ineligible Setting
X8 Ineligible Study Design
X9 Intermediate Outcome Only
X10 Ineligible Country
X11 Non-English Screener
X12 Abstract Only
X13 Poor Quality
X14 Irretrievable
X15 Irrelevant Systematic Review

1 Aarab G, Arcache P, Lavigne GJ, . The effects of mandibular advancement appliance therapy on jaw-closing muscle activity during sleep in patients with obstructive sleep apnea: a 3-6 months follow-up. J Clin Sleep Med. 2020 Sep 15;16(9):1545–53. doi: 10.5664/jcsm.8612. PMID: 32501212. Exclusion Code: X13.32501212
2 Aarab G, Nikolopoulou M, Ahlberg J, . Oral appliance therapy versus nasal continuous positive airway pressure in obstructive sleep apnea: a randomized, placebo-controlled trial on psychological distress. Clin Oral Investig. 2017 Sep;21(7):2371–8. doi: 10.1007/s00784-016-2045-3. PMID: 28083705. Exclusion Code: X6.28083705
3 Abdeyrim A, Tang L, Muhamat A, . Receiver operating characteristics of impulse oscillometry parameters for predicting obstructive sleep apnea in preobese and obese snorers. BMC Pulm Med. 2016 Aug 22;16(1):125. doi: 10.1186/s12890-016-0284-3. PMID: 27549623. Exclusion Code: X3.27549623
4 Abdeyrim A, Zhang Y, Li N, . Impact of obstructive sleep apnea on lung volumes and mechanical properties of the respiratory system in overweight and obese individuals. BMC Pulm Med. 2015 Jul 25;15:76. doi: 10.1186/s12890-015-0063-6. PMID: 26209328. Exclusion Code: X3.26209328
5 Abdullah B, Idris AI, Mohammad ZW, . Validation of Bahasa Malaysia STOP-BANG questionnaire for identification of obstructive sleep apnea. Sleep Breath. 2018 Dec;22(4):1235–9. doi: 10.1007/s11325-018-1663-1. PMID: 29682698. Exclusion Code: X2.29682698
6 Abumuamar AM, Dorian P, Newman D, . The STOP-BANG questionnaire shows an insufficient specificity for detecting obstructive sleep apnea in patients with atrial fibrillation. J Sleep Res. 2018 Dec;27(6):e12702. doi: 10.1111/jsr.12702. PMID: 29682848. Exclusion Code: X5.29682848
7 Abuzaid AS, Al Ashry HS, Elbadawi A, . Meta-analysis of cardiovascular outcomes with continuous positive airway pressure therapy in patients with obstructive sleep apnea. Am J Cardiol. 2017 Aug 15;120(4):693–9. doi: 10.1016/j.amjcard.2017.05.042. PMID: 28651851. Exclusion Code: X8.28651851
8 Adderley NJ, Subramanian A, Toulis K, . Obstructive sleep apnea, a risk factor for cardiovascular and microvascular disease in patients with type 2 diabetes: Findings from a population-based cohort study. Diabetes Care. 2020;43(8):1868–77. doi: 10.2337/dc19-2116. Exclusion Code: X8.32345651
9 Ağan K, Özmerdivenli R, Değirmenci Y, . Evaluation of sleep in women with menopause: results of the Pittsburg Sleep Quality Index and polysomnography. Journal of the Turkish German Gynecology Association. 2015;16(3):149–52. doi: 10.5152/jtgga.2015.15087. Exclusion Code: X3.
10 Agarwal P, Ariga P, Jain AR. Efficacy of custom-made mandibular advancement appliance on patients with obstructive sleep apnea: A prospective clinical trial. Drug Invention Today. 2018;10(6):864–9. Exclusion Code: X5.
11 Agha M, Shehab-Eldin W, Helwa M. Obstructive sleep apnea in patients with type 2 diabetes mellitus. Egyptian Journal of Chest Diseases and Tuberculosis. 2019;68(4):560–6. doi: 10.4103/ejcdt.ejcdt_17_19. Exclusion Code: X5.
12 Ahlin S, Manco M, Panunzi S, . A new sensitive and accurate model to predict moderate to severe obstructive sleep apnea in patients with obesity. Medicine (Baltimore). 2019 Aug;98(32):e16687. doi: 10.1097/md.0000000000016687. PMID: 31393370. Exclusion Code: X7.31393370
13 Ahmad AN, McLeod G, Al Zahrani N, . Screening for high risk of sleep apnea in an ambulatory care setting in Saudi Arabia. Int J Environ Res Public Health. 2019 Feb 5;16(3)doi: 10.3390/ijerph16030459. PMID: 30764527. Exclusion Code: X3.30764527
14 Aiyer A, Surani SR, Khan A. Influence of obesity on severity of sleep apnea and CPAP pressure requirement. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X6.
15 Aiyer I, Hesselbacher S, Surani Z, . Is epworth sleepiness score reliable as a screening tool for OSA? Sleep Medicine. 2019;64:S6. doi: 10.1016/j.sleep.2019.11.018. Exclusion Code: X8.
16 Aiyer I, Reddy S, Ramos Ramirez M, . Prevalence of normal Epworth sleepiness score in sleep apnea and gender influences. Chest. 2019;155(4):305A. doi: 10.1016/j.chest.2019.02.296. Exclusion Code: X6.
17 Akkurt BCO, Dogru S, Koyuncu O, . The relationship between disease severity and predictors of difficult intubation in patients with obstructive sleep apnea syndrome. 2015;31(1):67–71. Exclusion Code: X6.
18 Alessandri-Bonetti A, Bortolotti F, Moreno-Hay I, . Effects of mandibular advancement device for obstructive sleep apnea on temporomandibular disorders: A systematic review and meta-analysis. Sleep Med Rev. 2019 Dec;48:101211. doi: 10.1016/j.smrv.2019.101211. PMID: 31605905. Exclusion Code: X6.31605905
19 Alessi CA, Martin JL, Fung CH, . Randomized controlled trial of an integrated behavioral treatment in veterans with obstructive sleep apnea and coexisting insomnia. Sleep. 2018;41:A155. Exclusion Code: X4.
20 Alhaddad A, Stansbury RC, Weaver B. Three-month adherence to positive airway pressure therapy for treatment of obstructive sleep apnea (OSA) in patients undergoing ambulatory versus in-lab pathways of care. results from a rural tertiary care academic center. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccmconference.2017.C80F. Exclusion Code: X6.
21 Al-Jewair TS. High-quality randomized controlled trials are needed to confirm the effectiveness of oral appliances in the management of obstructive sleep apnea syndrome. J Evid Based Dent Pract. 2016 Jun;16(2):110–2. doi: 10.1016/j.jebdp.2016.05.002. PMID: 27449838. Exclusion Code: X8.27449838
22 Allahwala UK, Cistulli P, Ciofani JL, . Influence of Obstructive Sleep Apnoea on Outcomes in Patients With ST Elevation Myocardial Infarction (STEMI): the Role of the Coronary Collateral Circulation. Heart Lung and Circulation. 2021doi: 10.1016/j.hlc.2021.07.008. Exclusion Code: X5.
23 Allahwala UK, Cistulli PA, Dissanayake HU, . Influence of Obstructive Sleep Apnoea Severity on Coronary Collateral Recruitment During Coronary Occlusion. Lung. 2021doi: 10.1007/s00408-021-00462-6. Exclusion Code: X8.
24 Alonderis A, Raskauskiene N, Gelziniene V, . The association of sleep disordered breathing with left ventricular remodeling in CAD patients: a cross-sectional study. BMC Cardiovasc Disord. 2017 Sep 18;17(1):250. doi: 10.1186/s12872-017-0684-1. PMID: 28923022. Exclusion Code: X6.28923022
25 Alsharif AM, Potts M, Laws R, . Unattended sleep studies in a VA population: initial evaluation by chart review versus clinic visit by a midlevel provider. South Med J. 2016 Oct;109(10):677–81. doi: 10.14423/smj.0000000000000543. PMID: 27706510. Exclusion Code: X3.27706510
26 Alvarez D, Hornero R, Abasolo D, . Nonlinear measure of synchrony between blood oxygen saturation and heart rate from nocturnal pulse oximetry in obstructive sleep apnoea syndrome. Physiol Meas. 2009 Sep;30(9):967–82. doi: 10.1088/0967-3334/30/9/008. PMID: 19696463. Exclusion Code: X3.19696463
27 Alvarez D, Hornero R, Marcos JV, . Feature selection from nocturnal oximetry using genetic algorithms to assist in obstructive sleep apnoea diagnosis. Med Eng Phys. 2012 Oct;34(8):1049–57. doi: 10.1016/j.medengphy.2011.11.009. PMID: 22154238. Exclusion Code: X3.22154238
28 Amini M, Heravi F, Zandi B, . The effect of mandibular advancement device on physiologic parameters and volumetric MRI in mild to moderate obstructive sleep apnea-a randomized controlled trial. Sleep Medicine. 2017;40:e14–e5. Exclusion Code: X10.
29 Amra B, Javani M, Soltaninejad F, . Comparison of Berlin Questionnaire, STOP-Bang, and Epworth Sleepiness Scale for diagnosing obstructive sleep apnea in Persian patients. Int J Prev Med. 2018;9:28. doi: 10.4103/ijpvm.IJPVM_131_17. PMID: 29619152. Exclusion Code: X10.29619152
30 Amra B, Pirpiran M, Soltaninejad F, . The prediction of obstructive sleep apnea severity based on anthropometric and Mallampati indices. J Res Med Sci. 2019;24:66. doi: 10.4103/jrms.JRMS_653_18. PMID: 31523252. Exclusion Code: X10.31523252
31 Andreieva I. Effects of CPAP and mandibular advancement devices on cardiac biomarkers in patients with obstructive sleep apnea. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.4738. Exclusion Code: X5.
32 Ann S, Ariga P, Jain AR. Efficacy of custom-made mandibular advancement appliance on patients with obstructive sleep apnea: A prospective clinical trial. Drug Invention Today. 2018;10(Special Issue 1):2650–6. Exclusion Code: X8.
33 Antic NA, Heeley E, Anderson CS, . The Sleep Apnea cardioVascular Endpoints (SAVE) Trial: rationale, ethics, design, and progress. Sleep. 2015 Aug 1;38(8):1247–57. doi: 10.5665/sleep.4902. PMID: 25669180. Exclusion Code: X9.25669180
34 Apergis N, Gounidis A, Filippou DK, . The Use of CPAP Independently Improves Nocturia, Erectile Function, and Depression Symptoms in Obstructive Sleep Apnea Male Patients: an Observational Study. SN Comprehensive Clinical Medicine. 2021;3(7):1575–85. doi: 10.1007/s42399-021-00916-1. Exclusion Code: X8.
35 Araujo I, Marques F, Andre S, . Diagnosis of sleep apnea in patients with stable chronic heart failure using a portable sleep test diagnostic device. Sleep Breath. 2018 Sep;22(3):749–55. doi: 10.1007/s11325-017-1607-1. PMID: 29344749. Exclusion Code: X3.29344749
36 Araújo MTM, Borges YG, Cipriano LHC, . Short-term CPAP or moderate aerobic exercise do not improve oxidative stress and inflammatory biomarkers in obstructive sleep apnea. Sleep Science. 2020;13:15–6. Exclusion Code: X6.
37 Ardelean CL, Pescariu S, Lighezan DF, . Particularities of older patients with obstructive sleep apnea and heart failure with mid-range ejection fraction. Medicina (Kaunas). 2019 Aug 7;55(8)doi: 10.3390/medicina55080449. PMID: 31394863. Exclusion Code: X5.31394863
38 Argun Baris S, Tuncel D, Ozerdem C, . The effect of positive airway pressure therapy on neurocognitive functions, depression and anxiety in obesity hypoventilation syndrome. Multidisciplinary Respiratory Medicine. 2016;11(1):1–11. doi: 10.1186/s40248-016-0071-2. Exclusion Code: X8.
39 Arias MA, Garcia-Rio F, Alonso-Fernandez A, . CPAP decreases plasma levels of soluble tumour necrosis factor-alpha receptor 1 in obstructive sleep apnoea. Eur Respir J. 2008 Oct;32(4):1009–15. doi: 10.1183/09031936.00007008. PMID: 18508832. Exclusion Code: X9.18508832
40 Arslan BO, Hoşgör ZZU, Orman MN. Which screening questionnaire is best for predicting obstructive sleep apnea in the sleep clinic population considering age, gender, and comorbidities? Turkish Thoracic Journal. 2020;21(6):383–9. doi: 10.5152/TurkThoracJ.2019.19024. Exclusion Code: X8.33352093
41 Arta Eka Putra IDG, Pradiptha IP. Correlation between waist circumferences with obstructive sleep apnea risk in ENT clinic Sanglah hospital denpasar. Biomedical and Pharmacology Journal. 2019;12(1):347–51. doi: 10.13005/bpj/1646. Exclusion Code: X5.
42 Artz M, Series F, Lewis K, . Effects of auto-servo ventilation on cardiovascular function in patients with congestive heart failure and sleep-disordered breathing-A multicenter randomised controlled trial. European Respiratory Journal. 2011;38. Exclusion Code: X12.
43 Arzt M, Series F, Lewis K, . Treatment of central and obstructive sleep apnea in stable heart failure patients with auto-servo ventilation reduces sleep fragmentation - A randomized controlled trial. European Respiratory Journal. 2012;40. Exclusion Code: X6.
44 Aslan G, Afsar B, Siriopol D, . Cardiovascular effects of continuous positive airway pressure treatment in patients with obstructive sleep apnea: a meta-analysis. Angiology. 2018 Mar;69(3):195–204. doi: 10.1177/0003319717709175. PMID: 28506075. Exclusion Code: X8.28506075
45 Atik ND, Taşbakan S, Başoǧlu ÖK. Effect of Short Term Use of PAP Treatment on Metabolic Parameters in Patients withObstructive Sleep Apnea. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2154. Exclusion Code: X5.
46 Attali V, Collet JM, D’Ortho MP, . 2-years follow-up (FU) results of ORCADES study: long-term mandibular repositioning device (MRD) therapy in patients treated for obstructive sleep apnea (OSA). European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA2393. Exclusion Code: X5.
47 Attier-Zmudka J, Sérot JM, Valluy J, . Sleep apnea syndrome in an elderly population admitted to a geriatric unit: prevalence and effect on cognitive function. Frontiers in Aging Neuroscience. 2020;11doi: 10.3389/fnagi.2019.00361. Exclusion Code: X6.
48 Avincsal MO, Dinc ME, Ulusoy S, . Modified Mallampati Score Improves Specificity of STOP-Bang Questionnaire for Obstructive Sleep Apnea. J Craniofac Surg. 2017 Jun;28(4):904–8. doi: 10.1097/scs.0000000000003513. PMID: 28207464. Exclusion Code: X2.28207464
49 Aydin Guclu O, Ursavas A, Kasapoglu F, . The effect of CPAP treatment on excessive daytime sleepiness and serum substance p levels in OSAS patients. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X5.
50 Azeredo Bittencourt L, Luz G, Guimaraes T, . Effect of treatment of mild obstructive sleep apnea on quality of life, mood and sustained attention: Randomized, parallel, single-blind and controlled study. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X10.
51 Azevedo JCM, Cavalcanti AH, Muxfeldt ES. Blood pressure variation on cardiopulmonary test after continuous positive airway pressure therapy in resistant hypertensive patients with obstructive sleep apnea. Sleep Science. 2019;12:27–8. Exclusion Code: X9.
52 Back LJ, Liukko T, Rantanen I, . Radiofrequency surgery of the soft palate in the treatment of mild obstructive sleep apnea is not effective as a single-stage procedure: A randomized single-blinded placebo-controlled trial. Laryngoscope. 2009 Aug;119(8):1621–7. doi: 10.1002/lary.20562. PMID: 19504550. Exclusion Code: X4.19504550
53 Bahammam AS, Al-Aqee AM, Alhedyan AA, . The validity and reliability of an Arabic version of the STOP-Bang Questionnaire for identifying obstructive sleep apnea. Open Respiratory Medicine Journal. 2014;9(1):22–9. doi: 10.2174/1874306401509010022. Exclusion Code: X2.
54 Bahnasy WS, El-Heneedy YAE, El-Seidy EAS, . Sleep disturbances in diabetic peripheral neuropathy patients: a clinical and polysomnographic study. Egyptian Journal of Neurology, Psychiatry and Neurosurgery. 2018;54(1)doi: 10.1186/s41983-018-0024-0. Exclusion Code: X8.
55 Bahr K, Cámara RJA, Gouveris H, . Current treatment of comorbid insomnia and obstructive sleep apnea with CBTI and PAP-therapy: a systematic review. Front Neurol. 2018;9:804. doi: 10.3389/fneur.2018.00804. PMID: 30420826. Exclusion Code: X6.30420826
56 Baiamonte P, Gruttad’Auria CI, Mazzuca E, . Automatic bilevel ventilation in sleep-disordered breathing: a real-life experience in southern Italy. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA3425. Exclusion Code: X5.
57 Bailes S, Rizzo D, Fichten C, . Sleep apnea testing in consecutive older family medicine patients: symptoms and health status two years later. Sleep Medicine. 2019;64:S20. doi: 10.1016/j.sleep.2019.11.059. Exclusion Code: X8.
58 Baillieul S, Perennou D, Marillier M, . Impaired control of gait in patients with severe obstructive sleep apnea is reversed by continuous positive airway pressure treatment. Annals of Physical and Rehabilitation Medicine. 2016;59:e118–e9. doi: 10.1016/j.rehab.2016.07.268. Exclusion Code: X7.
59 Baillieul S, Wuyam B, Marillier M, . Impaired control of gait in patients with severe obstructive sleep apnea is reversed by continuous positive airway pressure treatment. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA5033. Exclusion Code: X8.
60 Baillieul S, Wuyam B, Pérennou D, . A randomized sham-controlled trial on the effect of continuous positive airway pressure treatment on gait control in severe obstructive sleep apnea patients. Sci Rep. 2021 Apr 29;11(1):9329. doi: 10.1038/s41598-021-88642-5. PMID: 33927278. Exclusion Code: X13.33927278
61 Baillieul S, Wuyam B, Tamisier R, . Impaired control of gait in severe obstructive sleep apnea and continuous positive airway pressure treatment: A randomized controlled trial. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA1997. Exclusion Code: X6.
62 Baird T, Theal R, Gleeson S, . Detailed polysomnography in Australian Vietnam veterans with and without posttraumatic stress disorder. J Clin Sleep Med. 2018 Sep 15;14(9):1577–86. doi: 10.5664/jcsm.7340. PMID: 30176975. Exclusion Code: X13.30176975
63 Bajpai G, Shukla G, Pandey R, . Validation of a modified Hindi version of the Epworth Sleepiness Scale among a North Indian population. Annals of Indian Academy of Neurology. 2016;19(4):499–504. doi: 10.4103/0972-2327.194427. Exclusion Code: X6.27994361
64 Bakker JP, Montesi SB, Edwards BA, . Quantifying the blood pressure reduction with positive airway pressure treatment: preliminary results of a patient-level meta-analysis. American Journal of Respiratory and Critical Care Medicine. 2013;187. Exclusion Code: X8.
65 Bakker JP, Montesi SB, Malhotra A. The effects of positive airway pressure treatment on hypertension: preliminary results of a meta-analysis. American Journal of Respiratory and Critical Care Medicine. 2012;185. Exclusion Code: X12.
66 Bakker JP, Wang R, Weng J, . Motivational enhancement as a means of increasing adherence to CPAP in clinical trial settings: a randomized controlled trial. Sleep. 2015;38:A176. Exclusion Code: X6.
67 Bala C, Roman G, Ciobanu D, . A systematic review of the effect of sleep apnea syndrome and its therapy on HbA1c in type 2 diabetes. International Journal of Diabetes in Developing Countries. 2020;40(2):158–72. doi: 10.1007/s13410-019-00784-5. Exclusion Code: X6.
68 Balat K, Pazarlı AC, Köseoğlu Hİ, . Importance of anthropometric measurements to determine cardiometabolic diseases in obstructive sleep apnea syndrome. Turkish Thoracic Journal. 2021;22(1):11–7. doi: 10.5152/TurkThoracJ.2020.19105. Exclusion Code: X6.33646098
69 Balcan B, Thunstrom E, Peker Y. Depression and response to CPAP treatment in coronary artery disease patients with sleepy vs nonsleepy obstructive sleep apnoea. European Respiratory Journal. 2018;52doi: 10.1183/13993003.congress-2018.OA4966. Exclusion Code: X5.
70 Balcan B, Thunström E, Peker Y. Effect of one-year CPAP treatment on mood in patients with coronary artery disease and obstructive sleep apnea. Sleep Medicine. 2017;40:e256. Exclusion Code: X8.
71 Balcan B, Thunström E, Yucel-Lindberg T, . Impact of CPAP treatment on leptin and adiponectin in adults with coronary artery disease and nonsleepy obstructive sleep apnoea in the RICCADSA trial. Sleep Med. 2020 Mar;67:7–14. doi: 10.1016/j.sleep.2019.10.016. PMID: 31884309. Exclusion Code: X6.31884309
72 Balk EM, Moorthy D, Obadan NO, . Diagnosis and Treatment of Obstructive Sleep Apnea in Adults Agency for Healthcare Research and Quality. Rockville, MD: Quality AfHRa; Jul 2011. Exclusion Code: X8.
73 Bamagoos A, Cistulli P, Sutherland K, . Dose-dependent effects of mandibular advancement on key pathophysiological traits that contribute to obstructive sleep apnoea. Journal of Sleep Research. 2017;26:31. doi: 10.1111/jsr.12618. Exclusion Code: X6.
74 Bamagoos AA, Cistulli PA, Sutherland K, . Polysomnographic endotyping to select patients with obstructive sleep apnea for oral appliances. Ann Am Thorac Soc. 2019 Nov;16(11):1422–31. doi: 10.1513/AnnalsATS.201903-190OC. PMID: 31394914. Exclusion Code: X8.31394914
75 Banghøj AM, Krogager C, Kristensen PL, . Effect of 12-week continuous positive airway pressure therapy on glucose levels assessed by continuous glucose monitoring in people with type 2 diabetes and obstructive sleep apnoea; a randomized controlled trial. Endocrinol Diabetes Metab. 2021 Apr;4(2):e00148. doi: 10.1002/edm2.148. PMID: 33855195. Exclusion Code: X6.33855195
76 Baniak L, Sereika SS, Bizhanova Z, . The effect of CPAP use on insomnia among persons with type 2 diabetes and obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X12.
77 Baptista M, Van Zeller M, Marinho A, . Obstructive sleep apnea syndrome-diagnostic clues and hospital referral. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X8.
78 Baptista M, Van Zeller M, Marinho A, . Diagnosis and treatment of obstructive sleep apnea syndrome in patients with heart failure. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X8.
79 Barak-Shinar D, Amos Y, Bogan RK. Sleep disordered breathing analysis in a general population using standard pulse oximeter signals. Sleep Breath. 2013 Sep;17(3):1109–15. doi: 10.1007/s11325-013-0812-9. PMID: 23386370. Exclusion Code: X3.23386370
80 Baratta F, Pastori D, Fabiani M, . Severity of OSAS, CPAP and cardiovascular events: a follow-up study. Eur J Clin Invest. 2018 May;48(5):e12908. doi: 10.1111/eci.12908. PMID: 29424037. Exclusion Code: X8.29424037
81 Barbe F, Esquinas C, Nadal N, . Primary care vs specialist sleep center management of continuous positive airway pressure treatment in obstructive sleep apnea patients. A randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. 2014;189. Exclusion Code: X6.
82 Barceló A, Morell-Garcia D, Salord N, . A randomized controlled trial: branched-chain amino acid levels and glucose metabolism in patients with obesity and sleep apnea. J Sleep Res. 2017 Dec;26(6):773–81. doi: 10.1111/jsr.12551. PMID: 28513068. Exclusion Code: X6.28513068
83 Bardwell WA, Norman D, Ancoli-Israel S, . Effects of 2-week nocturnal oxygen supplementation and continuous positive airway pressure treatment on psychological symptoms in patients with obstructive sleep apnea: a randomized placebo-controlled study. Behav Sleep Med. 2007;5(1):21–38. doi: 10.1207/s15402010bsm0501_2. PMID: 17313322. Exclusion Code: X9.17313322
84 Bartolucci ML, Bortolotti F, Corazza G, . Effectiveness of different mandibular advancement device designs in obstructive sleep apnoea therapy: A systematic review of randomised controlled trials with meta-analysis. J Oral Rehabil. 2020 Aug 17doi: 10.1111/joor.13077. PMID: 32805753. Exclusion Code: X5.32805753
85 Bartolucci ML, Bortolotti F, Corazza G, . Effectiveness of different mandibular advancement device designs in obstructive sleep apnoea therapy: a systematic review of randomised controlled trials with meta-analysis. J Oral Rehabil. 2021 Apr;48(4):469–86. doi: 10.1111/joor.13077. PMID: 32805753. Exclusion Code: X15.32805753
86 Bartolucci ML, Bortolotti F, Raffaelli E, . The effectiveness of different mandibular advancement amounts in OSA patients: a systematic review and meta-regression analysis. Sleep Breath. 2016 Sep;20(3):911–9. doi: 10.1007/s11325-015-1307-7. PMID: 26779903. Exclusion Code: X5.26779903
87 Basta J, Carter L, Gardner M, . The effect of routine testing of sleep apnea in patients with atrial fibrillation. 2016;32((Basta J.; Carter L.; Gardner M.; Gray C.; Sapp J.; Parkash R.) Halifax, NS, Canada):S208–S9. Exclusion Code: X8.
88 Bastos HN, Cardoso AV, Castro AS, . Randomised short-term trial of high-span versus low-span APAP for treating sleep apnoea. Sleep Breath. 2016 Mar;20(1):183–90; discussion 90. doi: 10.1007/s11325-015-1203-1. PMID: 26066701. Exclusion Code: X5.26066701
89 Batool-Anwar S, Quan S. The effect of continuous positive airway pressure (CPAP) on health related quality of life (HRQOL) as measured by quality of well being self administered questionnaire (QWB-SA). Sleep. 2018;41:A218–A9. Exclusion Code: X12.
90 Battan G, Kumar S, Panwar A, . Effect of CPAP therapy in improving daytime sleepiness in Indian patients with moderate and severe OSA. Journal of Clinical and Diagnostic Research. 2016;10(11):OC14–OC6. doi: 10.7860/JCDR/2016/23800.8876. Exclusion Code: X8.
91 Berger M, Solelhac G, Horvath C, . Treatment-emergent central sleep apnea associated with non-positive airway pressure therapies in obstructive sleep apnea patients: A systematic review. Sleep Med Rev. 2021 Aug;58:101513. doi: 10.1016/j.smrv.2021.101513. PMID: 34166994. Exclusion Code: X8.34166994
92 Bernasconi C, Ott SR, Fanfulla F, . SAS CARE 2 – a randomized study of CPAP in patients with obstructive sleep disordered breathing following ischemic stroke or transient ischemic attack. Sleep Medicine: X. 2020;2doi: 10.1016/j.sleepx.2020.100027. Exclusion Code: X2.
93 Bernhardt L, Brady EM, Freeman SC, . Diagnostic accuracy of screening questionnaires for obstructive sleep apnoea in adults in different clinical cohorts: a systematic review and meta-analysis. Sleep Breath. 2021 Aug 18:1–26. doi: 10.1007/s11325-021-02450-9. PMID: 34406554. Exclusion Code: X8.34406554
94 Bezeij T, Aaronson J, Bennekom CAM, . Continuous positive airway pressure in stroke patients with obstructive sleep apnea: a randomized controlled trial. Cerebrovascular Diseases. 2016;41:73. Exclusion Code: X12.
95 Bhat S, Polos PG, Gupta D, . CPAP treatment improves lapse count on psychomotor vigilance task testing in patients with OSA: Results of a pilot study. Sleep. 2017;40:A200–A1. Exclusion Code: X5.
96 Bhat S, Upadhyay H, DeBari VA, . The utility of patient-completed and partner-completed Epworth Sleepiness Scale scores in the evaluation of obstructive sleep apnea. Sleep Breath. 2016 Dec;20(4):1347–54. doi: 10.1007/s11325-016-1370-8. PMID: 27301400. Exclusion Code: X2.27301400
97 Bigini EG, Chasens ER, Conley YP, . DNA methylation changes and improved sleep quality in adults with obstructive sleep apnea and diabetes. BMJ Open Diabetes Res Care. 2019;7(1):e000707. doi: 10.1136/bmjdrc-2019-000707. PMID: 31798891. Exclusion Code: X13.31798891
98 Bilgin C, Erkorkmaz U, Ucar MK, . Use of a portable monitoring device (Somnocheck Micro) for the investigation and diagnosis of obstructive sleep apnoea in comparison with polysomnography. Pakistan Journal of Medical Sciences. 2016;32(2):471–5. doi: 10.12669/pjms.322.9561. Exclusion Code: X3.27182264
99 Bilyukov RG, Nikolov MS, Pencheva VP, . Cognitive impairment and affective disorders in patients with obstructive sleep apnea syndrome. Frontiers in Psychiatry. 2018;9(AUG)doi: 10.3389/fpsyt.2018.00357. Exclusion Code: X5.
100 Binar M, Gokgoz MC. Olfactory function in patients with obstructive sleep apnea and the effect of positive airway pressure treatment: a systematic review and meta-analysis. Sleep Breath. 2021 Mar 18:1–12. doi: 10.1007/s11325-021-02349-5. PMID: 33738753. Exclusion Code: X8.33738753
101 Bittencourt L, Servante D, Javaheri S, . Effects of exercise training and CPAP in patients with heart failure and obstructive sleep apnea. Sleep. 2015;38:A177. Exclusion Code: X12.
102 Bjornsdottir E, Janson C, Sigurdsson JF, . Insomnia phenotypes response to obstructive sleep apnea treatment in co-morbid insomnia/OSA. Journal of Sleep Research. 2016;25:44–5. doi: 10.1111/jsr.12446. Exclusion Code: X5.
103 Black JK, Whittaker AC, Balanos GM. Undiagnosed obstructive sleep apnea and physical activity in older manual workers. J Aging Phys Act. 2019 Jun 1;27(3):293–9. doi: 10.1123/japa.2018-0096. PMID: 30117357. Exclusion Code: X6.30117357
104 Blackman J, Swirski M, Clynes J, . Pharmacological and non-pharmacological interventions to enhance sleep in mild cognitive impairment and mild Alzheimer’s disease: A systematic review. J Sleep Res. 2021 Aug;30(4):e13229. doi: 10.1111/jsr.13229. PMID: 33289311. Exclusion Code: X8.33289311
105 Blackwell T, Yaffe K, Laffan A, . Associations between sleep-disordered breathing, nocturnal hypoxemia, and subsequent cognitive decline in older community-dwelling men: the Osteoporotic Fractures in Men Sleep Study. J Am Geriatr Soc. 2015 Mar;63(3):453–61. doi: 10.1111/jgs.13321. PMID: 25803785. Exclusion Code: X3.25803785
106 Blanco M, Jaritos V, Ernst G, . Patients’ preferences and the efficacy of a hybrid model of a minimal contact nasal mask in patients with sleep apnea treated with CPAP. Sleep Science. 2018;11(4):254–9. doi: 10.5935/1984-0063.20180040. Exclusion Code: X5.30746043
107 Boerner B, Tini GM, Fachinger P, . Significant improvement of olfactory performance in sleep apnea patients after three months of nasal CPAP therapy - Observational study and randomized trial. PLoS One. 2017;12(2):e0171087. doi: 10.1371/journal.pone.0171087. PMID: 28158212. Exclusion Code: X5.28158212
108 Bohning N, Zucchini W, Horstmeier O, . Sensitivity and specificity of telemedicine-based long-term pulse-oximetry in comparison with cardiorespiratory polygraphy and polysomnography in patients with obstructive sleep apnoea syndrome. J Telemed Telecare. 2011;17(1):15–9. doi: 10.1258/jtt.2010.100205. PMID: 20959395. Exclusion Code: X3.20959395
109 Borel AL, Tamisier R, Böhme P, . Obstructive sleep apnoea syndrome in patients living with diabetes: which patients should be screened? Diabetes Metab. 2019 Apr;45(2):91–101. doi: 10.1016/j.diabet.2018.08.006. PMID: 30189344. Exclusion Code: X8.30189344
110 Borsini E, Blanco M, Bosio M, . “Diagnosis of sleep apnea in network” respiratory polygraphy as a decentralization strategy. Sleep Science. 2016;9(3):244–8. doi: 10.1016/j.slsci.2016.10.009. Exclusion Code: X3.28123669
111 Borsini E, Blanco M, Schonfeld S, . Performance of Epworth Sleepiness Scale and tiredness symptom used with simplified diagnostic tests for the identification of sleep apnea. Sleep Science. 2019;12:287–94. doi: 10.5935/1984-0063.20190095. Exclusion Code: X11.32318250
112 Borsini E, Ernst G, Salvado A, . Utility of the STOP-BANG components to identify sleep apnea using home respiratory polygraphy. Sleep Breath. 2015 Dec;19(4):1327–33. doi: 10.1007/s11325-015-1174-2. PMID: 25903074. Exclusion Code: X5.25903074
113 Borsini EE, Blanco M, Ernst G, . Simulated intention-to-treat analysis based on clinical parameters of patients at high risk for sleep apnea derivated to respiratory polygraphy. Sleep Science. 2018;11(3):160–5. doi: 10.5935/1984-0063.20180030. Exclusion Code: X6.30455848
114 Borsini EE, Blanco M, Ernst G, . Contribution of pulse oximetry in relation to respiratory flow events in a home-based approach aimed at diagnosing obstructive sleep apnea. Sleep Science. 2021;14(1):77–81. doi: 10.5935/1984-0063.20200042. Exclusion Code: X3.34104342
115 Boulos M, Kamra M, Patel N, . SLEep APnea Screening using Mobile Ambulatory Recorders after TIA/stroke (SLEAP SMART): a randomized controlled trial. International Journal of Stroke. 2017;12(4):23. doi: 10.1177/1747493017721569. Exclusion Code: X2.
116 Bratton D, Gaisl T, Wons AM, . Comparison of the effect of continuous positive airway pressure and mandibular advancement devices on blood pressure in patients with obstructive sleep apnea: a network meta-analysis. European Respiratory Journal. 2015;46doi: 10.1183/13993003.congress2015.PA2406. Exclusion Code: X8.
117 Bratton DJ, Gaisl T, Schlatzer C, . Comparison of the effects of continuous positive airway pressure and mandibular advancement devices on subjective daytime sleepiness in patients with obstructive sleep apnea: a network meta-analysis. Thorax. 2015;70:A133–A4. doi: 10.1136/thoraxjnl-2015-207770.254. Exclusion Code: X8.
118 Bratton DJ, Gaisl T, Wons AM, . CPAP vs mandibular advancement devices and blood pressure in patients with obstructive sleep apnea: a systematic review and meta-analysis. Jama. 2015 Dec 1;314(21):2280–93. doi: 10.1001/jama.2015.16303. PMID: 26624827. Exclusion Code: X8.26624827
119 Bravata DM, McClain V, Austin C, . Diagnosing and managing sleep apnea in patients with chronic cerebrovascular disease: a randomized trial of a home-based strategy. Sleep Breath. 2017 Sep;21(3):713–25. doi: 10.1007/s11325-017-1494-5. PMID: 28386781. Exclusion Code: X9.28386781
120 Brill AK, Horvath T, Seiler A, . CPAP as treatment of sleep apnea after stroke: a meta-analysis of randomized trials. Neurology. 2018 Apr 3;90(14):e1222–e30. doi: 10.1212/wnl.0000000000005262. PMID: 29523641. Exclusion Code: X2.29523641
121 Browaldh N, Nerfeldt P, Lysdahl M, . SKUP3 randomised controlled trial: polysomnographic results after uvulopalatopharyngoplasty in selected patients with obstructive sleep apnoea. Thorax. 2013 Sep;68(9):846–53. doi: 10.1136/thoraxjnl-2012-202610. PMID: 23644225. Exclusion Code: X4.23644225
122 Brown A, Jones S, Perez-Algorta G. Experiences of Using Positive Airway Pressure for Treatment of Obstructive Sleep Apnoea: A Systematic Review and Thematic Synthesis. Sleep. 2021 May 27doi: 10.1093/sleep/zsab135. PMID: 34043010. Exclusion Code: X8.34043010
123 Bruyneel M, Sanida C, Art G, . Sleep efficiency during sleep studies: results of a prospective study comparing home-based and in-hospital polysomnography. J Sleep Res. 2011 Mar;20(1 Pt 2):201–6. doi: 10.1111/j.1365-2869.2010.00859.x. PMID: 20561176. Exclusion Code: X3.20561176
124 Budhiraja R, Javaheri S, Pavlova MK, . Prevalence and correlates of periodic limb movements in OSA and the effect of CPAP therapy. Neurology. 2020 Apr 28;94(17):e1820–e7. doi: 10.1212/wnl.0000000000008844. PMID: 31882530. Exclusion Code: X6.31882530
125 Budhiraja R, Kushida C, Nichols D, . Residual sleepiness on continuous positive airway pressure (CPAP) therapy in patients with obstructive sleep apnea (OSA). Sleep. 2017;40:A190–A1. Exclusion Code: X12.
126 Budhiraja R, Kushida CA, Nichols DA, . Impact of randomization, clinic visits, and medical and psychiatric comorbidities on continuous positive airway pressure adherence in obstructive sleep apnea. J Clin Sleep Med. 2016 Mar;12(3):333–41. doi: 10.5664/jcsm.5578. PMID: 26518698. Exclusion Code: X6.26518698
127 Budhiraja R, Kushida CA, Nichols DA, . Predictors of sleepiness in obstructive sleep apnoea at baseline and after 6 months of continuous positive airway pressure therapy. Eur Respir J. 2017 Nov;50(5)doi: 10.1183/13993003.00348-2017. PMID: 29191951. Exclusion Code: X8.29191951
128 Burks SV, Anderson JE, Panda B, . Employer-mandated obstructive sleep apnea treatment and healthcare cost savings among truckers. Sleep. 2020;43(4)doi: 10.1093/sleep/zsz262. Exclusion Code: X8.
129 Byun JI, Kim DH, Kim JS, . Usefulness of using alternative body-mass index and neck circumference criteria for STOP-bang questionnaire in screening South Korean obstructive sleep apnea patients. Sleep Medicine Research. 2020;11(1):38–43. doi: 10.17241/SMR.2020.00591. Exclusion Code: X2.
130 Cammaroto G, Costa F, Ruiz MVG, . Obstructive sleep apnoea syndrome and endothelial function: potential impact of different treatment strategies-meta-analysis of prospective studies. Eur Arch Otorhinolaryngol. 2019 Aug;276(8):2331–8. doi: 10.1007/s00405-019-05486-6. PMID: 31197532. Exclusion Code: X6.31197532
131 Campbell AJ, Neill AM. Home set-up polysomnography in the assessment of suspected obstructive sleep apnea. J Sleep Res. 2011 Mar;20(1 Pt 2):207–13. doi: 10.1111/j.1365-2869.2010.00854.x. PMID: 20561173. Exclusion Code: X3.20561173
132 Campos-Rodriguez F, Asensio-Cruz MI, Cordero-Guevara J, . Effect of continuous positive airway pressure on inflammatory, antioxidant, and depression biomarkers in women with obstructive sleep apnea: a randomized controlled trial. Sleep. 2019 Oct 9;42(10)doi: 10.1093/sleep/zsz145. PMID: 31314107. Exclusion Code: X6.31314107
133 Campos-Rodriguez F, Gonzalez-Martinez M, Sanchez-Armengol A, . Effect of continuous positive airway pressure on blood pressure and metabolic profile in women with sleep apnoea. Eur Respir J. 2017 Aug;50(2)doi: 10.1183/13993003.00257-2017. PMID: 28798089. Exclusion Code: X9.28798089
134 Campos-Rodríguez F, Reina-González Á, Reyes-Núñez N, . Clinical and cardiovascular characteristics of patients with obstructive sleep apnoeas without excessive daytime sleepiness. Archivos de Bronconeumologia. 2010;46(11):594–9. doi: 10.1016/S1579-2129(10)70127-0. Exclusion Code: X8.20952119
135 Campos-Rodriguez F, Reyes-Nuñez N, Cordero-Guevara J, . Effect of continuous positive airway pressure on blood pressure and the metabolic profile of women with obstructive sleep apnoea. A randomized-controlled trial. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.OA1805. Exclusion Code: X6.
136 Campos-Rodriguez F, Reyes-Nuñez N, Queipo-Corona C, . Continuous positive airway pressure treatment does not reduce uric acid levels in OSA women. Arch Bronconeumol. 2019 Apr;55(4):201–7. doi: 10.1016/j.arbres.2018.09.012. PMID: 30446250. Exclusion Code: X6.30446250
137 Caples SM, Mansukhani MP, Friedman PA, . The impact of continuous positive airway pressure treatment on the recurrence of atrial fibrillation post cardioversion: a randomized controlled trial. Int J Cardiol. 2019 Mar 1;278:133–6. doi: 10.1016/j.ijcard.2018.11.100. PMID: 30522886. Exclusion Code: X13.30522886
138 Cardoso AVS, Pereira N, Santos V, . Obstructive sleep apnoea and interstitial lung disease: a quality of life analysis. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA2358. Exclusion Code: X8.
139 Cardoso CRL, Roderjan CN, Cavalcanti AH, . Effects of continuous positive airway pressure treatment on aortic stiffness in patients with resistant hypertension and obstructive sleep apnea: A randomized controlled trial. J Sleep Res. 2020 Aug;29(4):e12990. doi: 10.1111/jsr.12990. PMID: 32048379. Exclusion Code: X6.32048379
140 Carneiro-Barrera A, Amaro-Gahete FJ, Jurado-Fasoli L, . Interdisciplinary weight loss and lifestyle intervention for obstructive sleep apnoea in adults: The INTERAPNEA randomized controlled trial. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X4.
141 Casitas R, Martínez-Cerón E, Galera R, . The effect of treatment for sleep apnoea on determinants of blood pressure control. Eur Respir J. 2017 Nov;50(5)doi: 10.1183/13993003.01261-2017. PMID: 29146604. Exclusion Code: X9.29146604
142 Castello Branco N, Nunes S, Martins RO, . Comparison of objective adherence and effectiveness between two types of mandibular advancement devices for the treatment of obstructive sleep apnea: A crossover randomized study. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.A80-A. Exclusion Code: X5.
143 Castorena-Maldonado A, Espinosa-Morett L, Arredondo Del Bosque F, . Diagnostic value of the morphometric model and adjusted neck circumference in adults with obstructive sleep apnea syndrome. Rev Invest Clin. 2015 Jul–Aug;67(4):258–65. PMID: 26426592. Exclusion Code: X2.26426592
144 Catalán P, Martínez A, Herrejón A, . Internal consistency and validity of the Spanish version of the “Quebec Sleep Questionnaire” Quality-of-Life Questionnaire for Obstructive Sleep Apnea. Archivos de Bronconeumologia. 2012;48(4):107–13. doi: 10.1016/j.arbr.2011.10.007. Exclusion Code: X3.22209160
145 Cattazzo F, Pengo MF, Giontella A, . Effect of continuous positive airway pressure treatment on glycemic and lipid profiles in patients with obstructive sleep APNEA: A systematic review and meta-analysis. Journal of Hypertension. 2021;39(SUPPL 1):e364. doi: 10.1097/01.hjh.0000748756.24655.1b. Exclusion Code: X6.
146 Cedermark Magnusson M, Widell EC. Screening of obstructive sleep apnea in patients with atrial fibrillation. European Journal of Cardiovascular Nursing. 2018;17(1):79. doi: 10.1177/14745151187877. Exclusion Code: X12.
147 Celik E, Zaim M, Baydar C, . The upper respiratory tract findings that affect the compliance to positive airway pressure treatment with nasal mask in obstructive sleep apnea syndrome. Acta Medica Mediterranea. 2016;32(4):991–5. doi: 10.19193/0393-6384_2016_4_121. Exclusion Code: X6.
148 Celik Y, Thunström E, Peker Y. Association of anxiety scores at baseline with long-term adherence to CPAP in adults with coronary artery disease and obstructive sleep apnoea in the RICCADSA trial. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X6.
149 Celik Y, Thunström E, Strollo PJ, . CPAP treatment increases anxiety in coronary artery disease patients with nonsleepy obstructive sleep apnoea: The RICCADSA randomized controlled trial. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2497. Exclusion Code: X12.
150 Cepeda FX, Virmondes L, Rodrigues S, . Identifying the risk of obstructive sleep apnea in metabolic syndrome patients: diagnostic accuracy of the Berlin Questionnaire. PLoS One. 2019;14(5):e0217058. doi: 10.1371/journal.pone.0217058. PMID: 31112558. Exclusion Code: X10.31112558
151 Chai-Coetzer CL, Antic N, Hamilton G, . A randomised controlled trial comparing patient outcomes following full polysomnography versus limited sleep study testing for suspected obstructive sleep apnea. Sleep and Biological Rhythms. 2015;13:44. doi: 10.1111/sbr.12132. Exclusion Code: X5.
152 Chai-Coetzer CL, Antic NA, Hamilton GS, . Physician decision making and clinical outcomes with laboratory polysomnography or limited-channel sleep studies for obstructive sleep apnea: a randomized trial. Ann Intern Med. 2017 Mar 7;166(5):332–40. doi: 10.7326/m16-1301. PMID: 28114683. Exclusion Code: X4.28114683
153 Chalegre ST, Lins-Filho OL, Lustosa TC, . Impact of CPAP on arterial stiffness in patients with obstructive sleep apnea: a meta-analysis of randomized trials. Sleep Breath. 2020 Oct 22doi: 10.1007/s11325-020-02226-7. PMID: 33094411. Exclusion Code: X6.33094411
154 Chalegre ST, Lins-Filho OL, Lustosa TC, . Impact of CPAP on arterial stiffness in patients with obstructive sleep apnea: a meta-analysis of randomized trials. Sleep Breath. 2021 Sep;25(3):1195–202. doi: 10.1007/s11325-020-02226-7. PMID: 33094411. Exclusion Code: X8.33094411
155 Chan K, Cossa G, Laks L, . Impact on objective cough severity by continuous positive airway pressure (CPAP) in subjects with chronic cough and obstructive sleep apnoea-a randomized controlled trial. European Respiratory Journal. 2011;38. Exclusion Code: X6.
156 Chang E. CPAP treatment can improved cognition and memory dysfunction in obstructive sleep apnea syndrome. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X5.
157 Chang ET, Wang HM. Cognitive function was improved after continuous positive airway pressure treatment in obstructive sleep apnea syndrome. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA2368. Exclusion Code: X12.
158 Chang J, Arguelles J, Kim J, . Evaluating the use of a titratable prefabricated mandibular advancement device to predict response to a custom device. Sleep. 2018;41:A206. Exclusion Code: X5.
159 Chang YS, Yee BJ, Hoyos CM, . The effects of continuous positive airway pressure therapy on Troponin-T and N-terminal pro B-type natriuretic peptide in patients with obstructive sleep apnoea: a randomised controlled trial. Sleep Med. 2017 Nov;39:8–13. doi: 10.1016/j.sleep.2017.08.007. PMID: 29157592. Exclusion Code: X6.29157592
160 Chapman JL, Hoyos CM, Killick R, . Development and validation of a model for diagnosis of obstructive sleep apnoea in primary care. Respirology. 2021doi: 10.1111/resp.14122. Exclusion Code: X3.
161 Chasens ER, Atwood CW, Burke LE, . Diabetes sleep treatment trial: premise, design, and methodology. Contemp Clin Trials. 2019 Jan;76:104–11. doi: 10.1016/j.cct.2018.11.014. PMID: 30517889. Exclusion Code: X8.30517889
162 Chasens ER, Burke LE, Korytkowski M, . Effect of continuous positive airway pressure (CPAP) treatment of obstructive sleep apnea on physical activity and glucose control in adults with type 2 diabetes: Results of a pilot study. American Journal of Respiratory and Critical Care Medicine. 2012;185. Exclusion Code: X12.
163 Chasens ER, Burke LE, Korytkowski M, . Use of sham-continuous positive airway pressure (CPAP) in a pilot study of treatment of obstructive sleep apnea in adults with diabetes. American Journal of Respiratory and Critical Care Medicine. 2012;185. Exclusion Code: X6.
164 Chasens ER, Sereika SM, Kortykowski M, . Diabetes sleep treatment trial: the effect of treatment of OSA with CPAP on glycemic control in type 2 diabetes. Sleep. 2020;43(SUPPL 1):A261–A2. doi: 10.1093/sleep/zsaa056.682. Exclusion Code: X6.
165 Chatterjee D, Sharma A, Brar H, . Continuous positive airway pressure treats distressing dreams in sleep apnea. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA4146. Exclusion Code: X6.
166 Chen H, Aarab G, de Lange J, . The effects of noncontinuous positive airway pressure therapies on the aerodynamic characteristics of the upper airway of obstructive sleep apnea patients: a systematic review. J Oral Maxillofac Surg. 2018 Jul;76(7):1559.e1–.e11. doi: 10.1016/j.joms.2018.02.017. PMID: 29567436. Exclusion Code: X8.29567436
167 Chen L, Kuang J, Pei JH, . Continuous positive airway pressure and diabetes risk in sleep apnea patients: a systemic review and meta-analysis. Eur J Intern Med. 2017 Apr;39:39–50. doi: 10.1016/j.ejim.2016.11.010. PMID: 27914881. Exclusion Code: X6.27914881
168 Chen L, Pivetta B, Nagappa M, . Validation of the STOP-Bang questionnaire for screening of obstructive sleep apnea in the general population and commercial drivers: a systematic review and meta-analysis. Sleep Breath. 2021 Jan 28doi: 10.1007/s11325-021-02299-y. PMID: 33507478. Exclusion Code: X8.33507478
169 Chen L, Tang W, Wang C, . Diagnostic Accuracy of Oxygen Desaturation Index for Sleep-Disordered Breathing in Patients With Diabetes. Frontiers in Endocrinology. 2021;12doi: 10.3389/fendo.2021.598470. Exclusion Code: X3.
170 Chen LD, Lin QC, Liu JN. Effect of continuous positive airway pressure on adiponectin in patients with obstructive sleep apnea: a meta-analysis. Chest. 2016;149(4):A562. doi: 10.1016/j.chest.2016.02.587. Exclusion Code: X6.
171 Chen Q, Cheng YB, Shen M, . A randomized controlled trial on ambulatory blood pressure lowering effect of CPAP in patients with obstructive sleep apnea and nocturnal hypertension. Blood Press. 2020 Feb;29(1):21–30. doi: 10.1080/08037051.2019.1686343. PMID: 31696741. Exclusion Code: X10.31696741
172 Chen Q, Lin G, Huang J, . Effects of CPAP on visceral adipose tissue in patients with obstructive sleep apnea: a meta-analysis. Sleep Breath. 2020 Jun;24(2):425–32. doi: 10.1007/s11325-019-01932-1. PMID: 31463777. Exclusion Code: X6.31463777
173 Chen R, Liu W, Cheng J, . The no-apnea score vs. the other five questionnaires in screening for obstructive sleep apnea-hypopnea syndrome in patients with cerebral infarction. Journal of Thoracic Disease. 2019;11(10):4179–87. doi: 10.21037/jtd.2019.09.75. Exclusion Code: X2.31737301
174 Chen Y, Chen Y, Wen F, . Does continuous positive airway pressure therapy benefit patients with coronary artery disease and obstructive sleep apnea? A systematic review and meta-analysis. Clin Cardiol. 2021 Aug;44(8):1041–9. doi: 10.1002/clc.23669. PMID: 34145595. Exclusion Code: X8.34145595
175 Cheung YY, Tai BC, Loo G, . Screening for obstructive sleep apnea in the assessment of coronary risk. Am J Cardiol. 2017 Apr 1;119(7):996–1002. doi: 10.1016/j.amjcard.2016.11.058. PMID: 28159193. Exclusion Code: X8.28159193
176 Cho YJ, Shim CY, Kim D, . Effects of continuous positive airway pressure therapy on left ventricular diastolic function in patients with severe obstructive sleep apnea (CPAP-OASIS): A randomized, sham-controlled clinical trial. Sleep Medicine. 2017;40:e62. Exclusion Code: X9.
177 Choi JH, Kim EJ, Kim YS, . Validation study of portable device for the diagnosis of obstructive sleep apnea according to the new AASM scoring criteria: Watch-PAT 100. Acta Otolaryngol. 2010 Jul;130(7):838–43. doi: 10.3109/00016480903431139. PMID: 20082567. Exclusion Code: X3.20082567
178 Chou KT, Tsai YL, Yeh WY, . Risk of work-related injury in workers with obstructive sleep apnea: A systematic review and meta-analysis. Journal of Sleep Research. 2021doi: 10.1111/jsr.13446. Exclusion Code: X8.
179 Christensson E, Franklin KA, Sahlin C, . Can STOP-Bang and pulse oximetry detect and exclude obstructive sleep apnea? Anesth Analg. 2018 Sep;127(3):736–43. doi: 10.1213/ane.0000000000003607. PMID: 29958223. Exclusion Code: X2.29958223
180 Chua A, Koo C, Kristanto W, . Sleep study-guided multidisciplinary therapy for acute coronary syndrome: a randomized clinical trial. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X5.
181 Chua AP, Koo CY, Kristanto W, . Sleep study-guided multidisciplinary therapy (SGMT) for patients with acute coronary syndrome: trial rationale and design. Clin Cardiol. 2018 Jun;41(6):721–8. doi: 10.1002/clc.22950. PMID: 29582447. Exclusion Code: X4.29582447
182 Chumjan S, Ariyanuchitkul S, Sawanyawisuth K. The short-term quality of life improvement by CPAP therapy in OSA associated hypertensive patients. Sleep Medicine. 2017;40:e66. Exclusion Code: X5.
183 Chung F, Wong J, Bellingham G, . Predictive factors for sleep apnoea in patients on opioids for chronic pain. BMJ Open Respir Res. 2019;6(1):e000523. doi: 10.1136/bmjresp-2019-000523. PMID: 31908788. Exclusion Code: X2.31908788
184 Ciancio N, Di Maria A, Bivona L, . Effect of short-term treatment with CPAP on cardiopulmonary exercise test (CPX) in patients with severe obstructive sleep apnea syndrome (OSAS). European Respiratory Journal. 2014;44. Exclusion Code: X6.
185 Cignarelli A, Castellana M, Castellana G, . Effects of CPAP on testosterone levels in patients with obstructive sleep apnea: a meta-analysis study. Front Endocrinol (Lausanne). 2019;10:551. doi: 10.3389/fendo.2019.00551. PMID: 31496991. Exclusion Code: X6.31496991
186 Cistulli P. CPAP or oral appliances for OSA: Time for a personalised approach. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X8.
187 Clark SD, Salonen BR, Reddy Bs NV, . Utilization of overnight pulse oximetry in fibromyalgia patients. Global Advances In Health and Medicine. 2019;8doi: 10.1177/2164956119847125. Exclusion Code: X8.
188 Clynes J, Blackman J, Swirski M, . Interventions to enhance sleep in mild cognitive impairment and mild Alzheimer’s dementia: a systematic review. Sleep Medicine. 2019;64:S77. doi: 10.1016/j.sleep.2019.11.212. Exclusion Code: X8.
189 Cochen DeCock V, Castel M, Bonafé I. Mandibular advancement device in Parkinson’s disease: an efficacious and usable device in a disabling disease. Movement Disorder. 2019;34:S631–S2. Exclusion Code: X12.
190 Colas des Francs C, Meksen B, Dinkelacker V, . Obstructive sleep apnea syndrome in EUROPE: results from the multicentric ESADA (European Sleep Apnea Data) study. Medecine du Sommeil. 2016;13(3):109–21. doi: 10.1016/j.msom.2016.07.004. Exclusion Code: X1.
191 Contreras JB, Anders G, Pena-Orbea C, . Effectiveness of WatchPAT test to evaluate adequacy of treatment response with oral appliance for obstructive sleep apnea. Sleep. 2018;41:A183. Exclusion Code: X8.
192 Corral J, Mogollon MV, Sánchez-Quiroga M, . Echocardiographic changes with non-invasive ventilation and CPAP in obesity hypoventilation syndrome. Thorax. 2018 Apr;73(4):361–8. doi: 10.1136/thoraxjnl-2017-210642. PMID: 29146865. Exclusion Code: X5.29146865
193 Corral J, Sánchez-Quiroga M, Carmona-Bernal C, . Conventional polysomnography is not necessary for the management of most patients with suspected obstructive sleep apnea. Noninferiority, randomized controlled trial. Am J Respir Crit Care Med. 2017 Nov 1;196(9):1181–90. doi: 10.1164/rccm.201612-2497OC. PMID: 28636405. Exclusion Code: X3.28636405
194 Cort BP, Figuera AP, Calle CR, . Impact of obstructive sleep apnea and CPAP treatment on mortality and cardio and cerebrovascular consequences in men of the general population after 20 years of follow-up. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2551. Exclusion Code: X12.
195 Costa JC, Rebelo-Marques A, Machado JPN, . STOP-Bang and NoSAS questionnaires as a screening tool for OSA: which one is the best choice? Rev Assoc Med Bras (1992). 2020 Sep;66(9):1203–9. doi: 10.1590/1806-9282.66.9.1203. PMID: 33027446. Exclusion Code: X2.33027446
196 Coutinho Costa J, Rebelo-Marques A, Machado JN, . Validation of NoSAS (Neck, Obesity, Snoring, Age, Sex) score as a screening tool for obstructive sleep apnea: Analysis in a sleep clinic. Pulmonology. 2019 Sep–Oct;25(5):263–70. doi: 10.1016/j.pulmoe.2019.04.004. PMID: 31196834. Exclusion Code: X2.31196834
197 Cowie MR, Linz D, Redline S, . Sleep Disordered Breathing and Cardiovascular Disease: JACC State-of-the-Art Review. Journal of the American College of Cardiology. 2021;78(6):608–24. doi: 10.1016/j.jacc.2021.05.048. Exclusion Code: X8.34353537
198 Craig S, Kylintireas I, Kohler M, . Effect of CPAP on cardiac function in minimally symptomatic patients with OSA: results from a subset of the MOSAIC randomized trial. J Clin Sleep Med. 2015 Sep 15;11(9):967–73. doi: 10.5664/jcsm.5004. PMID: 25979104. Exclusion Code: X9.25979104
199 Cross MD, Mills NL, Al-Abri M, . Continuous positive airway pressure improves vascular function in obstructive sleep apnoea/hypopnoea syndrome: a randomised controlled trial. Thorax. 2008 Jul;63(7):578–83. doi: 10.1136/thx.2007.081877. PMID: 18390635. Exclusion Code: X9.18390635
200 Cruz FCSG, Queiróz DBC, Vieira MLC, . Morbidity in patients with uncontrolled hypertension and obstructive sleep apnea: baseline profile of the MORPHEOS study. Sleep Science. 2019;12:63. Exclusion Code: X12.
201 Cunali PA, Cunha TCA, Guimarães TM, . Effect of the mandibular repositioning appliance in the treatment of obstructive sleep apnea in patients with temporomandibular dysfunction - Fast versus Slow protrusion, assisted or not supported by therapy - Randomized, controlled, double blind study. Sleep Science. 2019;12:8. Exclusion Code: X2.
202 da Silva Paulitsch F, Zhang L. Continuous positive airway pressure for adults with obstructive sleep apnea and cardiovascular disease: a meta-analysis of randomized trials. Sleep Med. 2019 Feb;54:28–34. doi: 10.1016/j.sleep.2018.09.030. PMID: 30529774. Exclusion Code: X6.30529774
203 Damy T, Tamisier R, Davy J, . FACE: Phenotyping analysis of chronic heart failure (CHF) patients with sleep disordered breathing (SDB) indicated for adaptive servoventilation (ASV): 2-year follow-up results. Archives of Cardiovascular Diseases Supplements. 2021;13(1):35. doi: 10.1016/j.acvdsp.2020.10.106. Exclusion Code: X2.
204 Damy T, Tamisier R, Pepin JL, . Morbidity and mortality of chronic heart failure (CHF) patients with central sleep apnoea (CSA) treated by adaptive servoventilation (ASV): Interim results of FACE cohort study. Archives of Cardiovascular Diseases Supplements. 2017;9(1):37. Exclusion Code: X2.
205 Dasgupta R, Strausbaugh B, Thatcher F, . Bilevel PAP experience in a community sleep center. Sleep. 2017;40:A205. Exclusion Code: X8.
206 Dashzeveg S, Otgonbayar L, Amartogtokh T. Characteristics of sleep apnea patients in Mongolian first sleep center. Sleep Medicine. 2019;64:S84–S5. doi: 10.1016/j.sleep.2019.11.231. Exclusion Code: X12.
207 Davies SE, Bishopp A, Turner AM, . Systematic review: does continuous positive airway pressure (CPAP) treatment of obstructive sleep apnoea (OSA) improve asthma-related clinical outcomes? Thorax. 2018;73:A131–A2. doi: 10.1136/thorax-2018-212555.216. Exclusion Code: X6.
208 Davies SE, Cachada N, Wharton S, . Co-existing obstructive sleep apnoea (OSA) adversely impacts on asthma related symptoms and quality of life. Thorax. 2018;73:A130–A1. doi: 10.1136/thorax-2018-212555.215. Exclusion Code: X8.
209 Davtyan KV, Arutyunyan GG, Topchyan AG, . The effectiveness of catheter ablation in paroxysmal atrial fibrillation in patients with obstructive sleep apnea with/without use of continuous positive airway pressure: results of a 12-month follow-up. Cardiovascular Therapy and Prevention (Russian Federation). 2020;19(2):27–32. doi: 10.15829/1728-8800-2020-2427. Exclusion Code: X1.
210 De Aguiar Mendes B, Figueiredo CL, Cabral MC, . Nasal vs. oronasal mask: a real-life analysis in adults undergoing auto-adjusting CPAP titration. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2140. Exclusion Code: X5.
211 De Batlle J, Bertran S, Turino C, . Continuous positive airway pressure (CPAP) treatment reduces mortality at the population level. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X8.
212 de Godoy LBM, Palombini LO, Guilleminaulth C, . Treatment of upper airway resistance syndrome in adults: where do we stand? Sleep Science. 2015;8(1):42–8. doi: 10.1016/j.slsci.2015.03.001. Exclusion Code: X8.26483942
213 De Juana Izquierdo C, Ponce S, Pastor E, . Role of CPAP treatment in elderly with moderate obstructive sleep apnea. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA4152. Exclusion Code: X12.
214 de Menezes Júnior LAA, Fajardo VC, do Nascimento Neto RM, . Diagnostic accuracy of the Berlin questionnaire and the NoSAS score in detecting risk for obstructive sleep apnea in rotating shift workers. Sleep Breath. 2021 Aug 2doi: 10.1007/s11325-021-02446-5. PMID: 34338952. Exclusion Code: X7.34338952
215 De Meyer MMD, Vanderveken OM, De Weerdt S, . Use of mandibular advancement devices for the treatment of primary snoring with or without obstructive sleep apnea (OSA): A systematic review. Sleep Med Rev. 2020 Nov 29;56:101407. doi: 10.1016/j.smrv.2020.101407. PMID: 33326914. Exclusion Code: X8.33326914
216 De Meyer MMD, Vanderveken OM, De Weerdt S, . Use of mandibular advancement devices for the treatment of primary snoring with or without obstructive sleep apnea (OSA): A systematic review. Sleep Med Rev. 2021 Apr;56:101407. doi: 10.1016/j.smrv.2020.101407. PMID: 33326914. Exclusion Code: X2.33326914
217 de Souza F, Muxfeldt ES, Margallo V, . Effects of continuous positive airway pressure treatment on aldosterone excretion in patients with obstructive sleep apnoea and resistant hypertension: a randomized controlled trial. J Hypertens. 2017 Apr;35(4):837–44. doi: 10.1097/hjh.0000000000001254. PMID: 28129246. Exclusion Code: X6.28129246
218 De Vries GE, Hoekema A, Houwerzijl EJ, . Cardiovascular effects of oral appliance therapy in obstructive sleep apnea: a systematic review and meta-analysis. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA4727. Exclusion Code: X12.
219 De Vries GE, Hoekema A, Vermeulen KM, . Clinical and cost-effectiveness of a mandibular advancement device versus continuous positive airway pressure in moderate obstructive sleep apnea: a randomized controlled trial. European Respiratory Journal. 2018;52doi: 10.1183/13993003.congress-2018.PA2261. Exclusion Code: X5.
220 de Vries GE, Hoekema A, Vermeulen KM, . Clinical- and cost-effectiveness of a mandibular advancement device versus continuous positive airway pressure in moderate obstructive sleep apnea. J Clin Sleep Med. 2019 Oct 15;15(10):1477–85. doi: 10.5664/jcsm.7980. PMID: 31596213. Exclusion Code: X5.31596213
221 Dediu G, Dragomir P, Dumitrache-Rujinski S, . The effect of continuous positive airway pressure on blood pressure in patients with obstructive sleep apnea syndrome. Archives of the Balkan Medical Union. 2017;52(4):430–3. Exclusion Code: X8.
222 Deflandre E, Piette N, Bonhomme V, . Comparison of clinical scores in their ability to detect hypoxemic severe OSA patients. PLoS One. 2018;13(5):e0196270. doi: 10.1371/journal.pone.0196270. PMID: 29734398. Exclusion Code: X7.29734398
223 Derose S, Zhou H, Huang B, . Pap therapy and health care utilization. Sleep. 2017;40:A439–A40. Exclusion Code: X5.
224 Deshmukh NV. Screening for risk of obstructive sleep apnoea in hypertensive geriatric individuals using stop bang questionnaire. Turkish Journal of Physiotherapy and Rehabilitation. 2021;32(3):6630–7. Exclusion Code: X6.
225 Desplan M, Mercier J, Sabate M, . A comprehensive rehabilitation program improves disease severity in patients with obstructive sleep apnea syndrome: a pilot randomized controlled study. Sleep Med. 2014 Aug;15(8):906–12. doi: 10.1016/j.sleep.2013.09.023. PMID: 24947878. Exclusion Code: X4.24947878
226 Diaféria G, Santos-Silva R, Truksinas E, . Myofunctional therapy improves adherence to continuous positive airway pressure treatment. Sleep Breath. 2017 May;21(2):387–95. doi: 10.1007/s11325-016-1429-6. PMID: 27913971. Exclusion Code: X10.27913971
227 Dias C, Sousa L, Batata L, . Titration with automatic continuous positive airway pressure in obstructive sleep apnea. Revista Portuguesa de Pneumologia (English Edition). 2017;23(4):203–7. doi: 10.1016/j.rppnen.2017.04.002. Exclusion Code: X5.
228 Dieltjens M, Van de Heyning C, Van Haesendonck G, . Mandibular advancement device is an efficacious tool to treat obstructive sleep apnea and reverse left ventricular hypertrophic remodeling. Sleep Medicine. 2019;64:S91–S2. doi: 10.1016/j.sleep.2019.11.250. Exclusion Code: X8.
229 Dillow K, Essick G, Sanders A, . Patient response to sleep apnea screening in a dental practice. J Public Health Dent. 2017 Dec;77(1):13–20. doi: 10.1111/jphd.12165. PMID: 27335269. Exclusion Code: X5.27335269
230 Dissanayake HU, Sutherland K, Phillips CL, . Comparative effects of CPAP and mandibular advancement splint therapy on blood pressure variability in moderate to severe obstructive sleep apnoea. Sleep Med. 2021 Apr;80:294–300. doi: 10.1016/j.sleep.2021.01.059. PMID: 33610954. Exclusion Code: X5.33610954
231 Dixon JB, Schachter LM, O’Brien PE, . Surgical vs conventional therapy for weight loss treatment of obstructive sleep apnea: a randomized controlled trial. JAMA. 2012 Sep 19;308(11):1142–9. doi: 10.1001/2012.jama.11580. PMID: 22990273. Exclusion Code: X4.22990273
232 Djavadkhani Y, Marshall NS, D’Rozario AL, . Ethics, consent and blinding: lessons from a placebo/sham controlled CPAP crossover trial. Thorax. 2015 Mar;70(3):265–9. doi: 10.1136/thoraxjnl-2014-206354. PMID: 25595508. Exclusion Code: X6.25595508
233 Djonlagic I, Guo M, Kishore D, . The effect of CPAP therapy on sleep dependent memory consolidation. Journal of Sleep Research. 2016;25:301–2. doi: 10.1111/jsr.12446. Exclusion Code: X12.
234 Djonlagic I, Guo M, Matteis P, . First night of CPAP: impact on memory consolidation attention and subjective experience. Sleep Med. 2015 Jun;16(6):697–702. doi: 10.1016/j.sleep.2015.01.017. PMID: 25953301. Exclusion Code: X6.25953301
235 Djonlagic IE, Guo M, Igue M, . CPAP restores declarative memory deficit in obstructive sleep apnea. Am J Respir Crit Care Med. 2020 Dec 21doi: 10.1164/rccm.202011-4253LE. PMID: 33347378. Exclusion Code: X6.33347378
236 Dodds S, Williams LJ, Roguski A, . Mortality and morbidity in obstructive sleep apnoea–hypopnoea syndrome: results from a 30-year prospective cohort study. ERJ Open Research. 2020;6(3):1–10. doi: 10.1183/23120541.00057-2020. Exclusion Code: X8.
237 Dohi T, Kasai T, Endo H, . CPAP effects on atherosclerotic plaques in patients with sleep-disordered breathing and coronary artery disease: The ENTERPRISE trial. J Cardiol. 2019 Jan;73(1):89–93. doi: 10.1016/j.jjcc.2018.07.002. PMID: 30177302. Exclusion Code: X6.30177302
238 Dong R, Dong Z, Liu H, . Prevalence, risk factors, outcomes, and treatment of obstructive sleep apnea in patients with cerebrovascular disease: a systematic review. J Stroke Cerebrovasc Dis. 2018 Jun;27(6):1471–80. doi: 10.1016/j.jstrokecerebrovasdis.2017.12.048. PMID: 29555400. Exclusion Code: X2.29555400
239 Dongol EM, Drakatos P, Muza R, . Predictors of residual sleepiness in patients with obstructive sleep apnea syndrome on continuous positive airway pressure. Egyptian Journal of Chest Diseases and Tuberculosis. 2021;70(2):267–71. doi: 10.4103/ejcdt.ejcdt_163_18. Exclusion Code: X8.
240 Donnellan E, Chung MK, Rajesh Patel D, . B-PO04-112 IMPACT OF SLEEP APNEA DIAGNOSIS AND TREATMENT IN MORBIDLY OBESE PATIENTS ON AF RECURRENCE AFTER ABLATION. Heart Rhythm. 2021;18(8):S324–S5. doi: 10.1016/j.hrthm.2021.06.806. Exclusion Code: X8.
241 Dontsos VK, Chatzigianni A, Papadopoulos MA, . Upper airway volumetric changes of obstructive sleep apnoea patients treated with oral appliances: a systematic review and meta-analysis. Eur J Orthod. 2020 Jun 11doi: 10.1093/ejo/cjaa035. PMID: 32524148. Exclusion Code: X6.32524148
242 Dontsos VK, Chatzigianni A, Papadopoulos MA, . Upper airway volumetric changes of obstructive sleep apnoea patients treated with oral appliances: a systematic review and meta-analysis. Eur J Orthod. 2021 Aug 3;43(4):399–407. doi: 10.1093/ejo/cjaa035. PMID: 32524148. Exclusion Code: X8.32524148
243 D’Ortho MP, Attali V, Collet JM, . 2-years follow-up (FU) Results of ORCADES study: Long-term mandibular repositioning device (MRD) therapy in patients treated for Obstructive Sleep Apnea (OSA). Journal of Sleep Research. 2016;25:257. doi: 10.1111/jsr.12446. Exclusion Code: X5.26825702
244 Dostálová V, Kolečkárová S, Kuška M, . Effects of continuous positive airway pressure on neurocognitive and neuropsychiatric function in obstructive sleep apnea. J Sleep Res. 2019 Oct;28(5):e12761. doi: 10.1111/jsr.12761. PMID: 30238529. Exclusion Code: X5.30238529
245 Doumit J, Belvitch P, Rubinstein I. Decreased cpap adherence in non-obese OSA patients with reversible upper airway obstruction. Journal of Investigative Medicine. 2016;64(4):970. doi: 10.1136/jim-2016-000120.123. Exclusion Code: X8.
246 Dreval AV, Misnikova IV, Gubkina VA, . Incidence of sleep apnea in patients with various types of glycemic disturbances. Diabetes Mellitus. 2013;16(1):71–7. doi: 10.14341/2072-0351-3600. Exclusion Code: X1.
247 Driver H, Carleton E, Fitzpatrick M, . Therapy for obstructive sleep apnea (OSA) improved ratings of refreshing sleep, leading to less daytime sleepiness, reduced cognitive difficulties and work-related burnout. Sleep Medicine. 2019;64:S97. doi: 10.1016/j.sleep.2019.11.267. Exclusion Code: X5.
248 Duarte RLM, Magalhães-da-Silveira FJ, Gozal D. Nocturnal oximetry in bariatric surgery patients referred to overnight in-lab polysomnography. Obesity. 2021doi: 10.1002/oby.23231. Exclusion Code: X3.
249 Duarte RLM, Rabahi MF, Magalhães-da-Silveira FJ, . Simplifying the screening of obstructive sleep apnea with a 2-item model, no-apnea: a cross-sectional study. J Clin Sleep Med. 2018 Jul 15;14(7):1097–107. doi: 10.5664/jcsm.7202. PMID: 29991419. Exclusion Code: X10.29991419
250 Duarte RLM, Silveira F, Sá T, . Using the No-Apnea score to screen for obstructive sleep apnea in adults referred to a sleep laboratory: comparative study of the performance of the instrument by gender. J Bras Pneumol. 2020;46(5):e20190297. doi: 10.36416/1806-3756/e20190297. PMID: 33027467. Exclusion Code: X2.33027467
251 Dubey A, Kant S, Mahdi AA, . The potential impact of family history of loud snoring and risk of obstructive sleep apnea in overweight subjects. Journal of Cardiovascular Disease Research. 2014;5(4):3–8. doi: 10.5530/jcdr.2014.4.2. Exclusion Code: X3.
252 Dunet V, Rey-Bataillard V, Allenbach G, . Effects of continuous positive airway pressure treatment on coronary vasoreactivity measured by (82)Rb cardiac PET/CT in obstructive sleep apnea patients. Sleep Breath. 2016 May;20(2):673–9. doi: 10.1007/s11325-015-1272-1. PMID: 26449551. Exclusion Code: X5.26449551
253 Düring K. Mechanical splinting of the nasal and velopharyngeal airway for patency of the upper airway in OSA. Sleep and Breathing. 2018;22(3):881–2. doi: 10.1007/s11325-018-1692-9. Exclusion Code: X12.
254 Dursun M, Selimoğlu Şen H, Yılmaz S, . Serum bicarbonate level improves specificity of Berlin Sleep Questionnaire for obstructive sleep apnea. Aging Male. 2020 Aug 5:1–7. doi: 10.1080/13685538.2020.1801623. PMID: 32752912. Exclusion Code: X2.29912660
255 Dutta R, Delaney G, Jordan A, . A model to evaluate the contribution of pathophysiological phenotypes to OSA severity and develop simplified approaches to estimate the key phenotypic traits that contribute to OSA. Sleep. 2019;42:A177–A8. doi: 10.1093/sleep/zsz067.439. Exclusion Code: X3.
256 Dzierzewski JM, Dautovich ND, Rybarczyk B, . Is a single night sleep study sufficient for the accurate diagnosis of sleep apnea” an exploration of multi-night sleep studies. Sleep. 2018;41:A185. Exclusion Code: X6.
257 Edwards BA, Andara C, Landry S, . Upper-airway collapsibility and loop gain predict the response to oral appliance therapy in patients with obstructive sleep apnea. Am J Respir Crit Care Med. 2016 Dec 1;194(11):1413–22. doi: 10.1164/rccm.201601-0099OC. PMID: 27181367. Exclusion Code: X5.27181367
258 Eijsvogel MM, Wiegersma S, Randerath W, . Obstructive sleep apnea syndrome in company workers: development of a two-step screening strategy with a new questionnaire. J Clin Sleep Med. 2016 Apr 15;12(4):555–64. doi: 10.5664/jcsm.5690. PMID: 26518703. Exclusion Code: X7.26518703
259 El Shayeb M, Topfer LA, Stafinski T, . Diagnostic accuracy of level 3 portable sleep tests versus level 1 polysomnography for sleep-disordered breathing: a systematic review and meta-analysis. CMAJ. 2014 Jan 7;186(1):E25–51. doi: 10.1503/cmaj.130952. PMID: 24218531. Exclusion Code: X8.24218531
260 Elfimova E, Litvin A, Chazova I. Effect of continuous positive airway pressure therapy on blood pressure and arterial stiffness in patients with severe obstructive sleep apnea and controlled arterial hypertension. Journal of Hypertension. 2017;35:e319–e20. doi: 10.1097/01.hjh.0000523945.27611.a3. Exclusion Code: X6.
261 Elfimova E, Mikhailova O, Litvin A, . Effect of CPAP-therapy on psychological and cognitive status in patients with arterial hypertension, obesity and asymptomatic obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2020;201(1). Exclusion Code: X12.
262 Eliasson A, Parmar R, Muir S, . Outcomes of oral appliance therapy from five dental sleep medicine practices. Sleep. 2017;40:A220–A1. Exclusion Code: X8.
263 Ensrud KE, Blackwell TL, Ancoli-Israel S, . Sleep disturbances and risk of frailty and mortality in older men. Sleep Med. 2012 Dec;13(10):1217–25. doi: 10.1016/j.sleep.2012.04.010. PMID: 22705247. Exclusion Code: X8.22705247
264 Erdinc O, Ger F, Algin D, . Cognitive functions in patients with obstructive sleep apnea. Journal of Sleep Research. 2016;25:171. doi: 10.1111/jsr.12446. Exclusion Code: X3.
265 Ernst G, Bosio M, Salvado A, . Comparative study between sequential automatic and manual home respiratory polygraphy scoring using a three-channel device: impact of the manual editing of events to identify severe obstructive sleep apnea. Sleep Disorders. 2015;2015doi: 10.1155/2015/314534. Exclusion Code: X5.
266 Escourrou P, Durand-Zaleski I, Agostini H, . RESPIR@DOM - A randomized controlled trial of telemedicine in sleep apnea patients. Sleep. 2015;38:A175. Exclusion Code: X4.
267 Eysenck W, Sulke N, Furniss S, . The prevalence of sleep-disordered breathing in patients more than 65 years with persistent atrial fibrillation. Journal of Interventional Cardiac Electrophysiology. 2017;48:S99. doi: 10.1007/s10840-017-0231-0. Exclusion Code: X6.
268 Fabius TM, Benistant JR, Pleijhuis RG, . The use of oximetry and a questionnaire in primary care enables exclusion of a subsequent obstructive sleep apnea diagnosis. Sleep Breath. 2020 Mar;24(1):151–8. doi: 10.1007/s11325-019-01834-2. PMID: 30953234. Exclusion Code: X2.30953234
269 Fadaei R, Koushki M, Sharafkhaneh A, . The impact of continuous positive airway pressure therapy on circulating levels of malondialdehyde: a systematic review and meta-analysis. Sleep Med. 2020 Nov;75:27–36. doi: 10.1016/j.sleep.2020.02.014. PMID: 32853915. Exclusion Code: X6.32853915
270 Faheem N, Stevens S. Systematic review and meta-analysis of randomized control trials examining efficacy of CPAP for prevention of stroke in patients with moderate to severe obstructive sleep apnea. Neurology. 2018;90(15). Exclusion Code: X8.
271 Faisal M, Thompson N, Mehra R, . Positive airway pressure abates drowsy driving in patients with sleep disordered breathing in a large clinic based cohort. Sleep. 2017;40:A199. Exclusion Code: X8.
272 Farghaly S, Shaaban LH. Efficacy of split night CPAP titration in moderate and severe obstructive sleep apnea syndrome patients. Egyptian Journal of Chest Diseases and Tuberculosis. 2016;65(1):251–7. doi: 10.1016/j.ejcdt.2015.08.017. Exclusion Code: X5.
273 Faria AC, da Costa CH, Rufino R. Sleep apnea clinical score, Berlin questionnaire, or Epworth Sleepiness Scale: which is the best obstructive sleep apnea predictor in patients with COPD? International Journal of General Medicine. 2015;8:275–81. doi: 10.2147/IJGM.S86479. Exclusion Code: X10.26345497
274 Fatureto-Borges F, Lorenzi-Filho G, Drager LF. Effectiveness of continuous positive airway pressure in lowering blood pressure in patients with obstructive sleep apnea: a critical review of the literature. Integr Blood Press Control. 2016;9:43–7. doi: 10.2147/ibpc.s70402. PMID: 27051313. Exclusion Code: X8.27051313
275 Fawale MB, Ibigbami O, Ismail I, . Risk of obstructive sleep apnea, excessive daytime sleepiness and depressive symptoms in a Nigerian elderly population. Sleep Science. 2016;9(2):106–11. doi: 10.1016/j.slsci.2016.05.005. Exclusion Code: X5.27656275
276 Feldstein CA. Blood pressure effects of CPAP in nonresistant and resistant hypertension associated with OSA: a systematic review of randomized clinical trials. Clin Exp Hypertens. 2016;38(4):337–46. doi: 10.3109/10641963.2016.1148156. PMID: 27159803. Exclusion Code: X2.27159803
277 Felfeli T, Alon R, Al Adel F, . Screening for obstructive sleep apnea amongst patients with retinal vein occlusion. Can J Ophthalmol. 2020 Aug;55(4):310–6. doi: 10.1016/j.jcjo.2020.03.004. PMID: 32317117. Exclusion Code: X2.32317117
278 Feres MC, Fonseca FA, Cintra FD, . An assessment of oxidized LDL in the lipid profiles of patients with obstructive sleep apnea and its association with both hypertension and dyslipidemia, and the impact of treatment with CPAP. Atherosclerosis. 2015 Aug;241(2):342–9. doi: 10.1016/j.atherosclerosis.2015.05.008. PMID: 26071656. Exclusion Code: X9.26071656
279 Ferguson KA, Heighway K, Ruby RR. A randomized trial of laser-assisted uvulopalatoplasty in the treatment of mild obstructive sleep apnea. Am J Respir Crit Care Med. 2003 Jan 1;167(1):15–9. doi: 10.1164/rccm.2108050. PMID: 12502473. Exclusion Code: X4.12502473
280 Ferre A, Sampol G, Jurado MJ, . Neurophysiological two-channel polysomnographic device in the diagnosis of sleep apnea. J Clin Sleep Med. 2012 Apr 15;8(2):163–8. doi: 10.5664/jcsm.1770. PMID: 22505861. Exclusion Code: X3.22505861
281 Foster GD, Borradaile KE, Sanders MH, . A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: the Sleep AHEAD study. Arch Intern Med. 2009 Sep 28;169(17):1619–26. doi: 10.1001/archinternmed.2009.266. PMID: 19786682. Exclusion Code: X4.19786682
282 Fox R, O’Malley E, Dunlevy C, . Screening for obstructive sleep apnoea in women in a level 3 weight management service-do the epworth sleep scale and the STOPBANG questionnaires have predictive validity? Obesity Facts. 2021;14(SUPPL 1):63. doi: 10.1159/000515911. Exclusion Code: X5.
283 Frangopoulos F, Nicolaou I, Zannetos S, . Association between respiratory sleep indices and cardiovascular disease in sleep apnea—a community-based study in Cyprus. Journal of Clinical Medicine. 2020;9(8):1–8. doi: 10.3390/jcm9082475. Exclusion Code: X6.
284 Franke K, Loffler KA, Nicholls SJ, . Effects of CPAP treatment on cardiac structure and function in individuals with obstructive sleep apnea and cardiovascular disease: A prospective 6-month randomised control trial. European Heart Journal. 2020;41(SUPPL 2):2889. doi: 10.1093/ehjci/ehaa946.2889. Exclusion Code: X6.
285 Gagnadoux F, Pepin JL, Vielle B, . Impact of mandibular advancement therapy on endothelial function in severe obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.B98. Exclusion Code: X9.
286 Gaisl T, Protazy R, Thiel S, . Effects of suboptimal use of CPAP-therapy on symptoms of obstructive sleep apnea: A randomized, double-blind, controlled trial. Respiration. 2019;97(6):596. doi: 10.1159/000499887. Exclusion Code: X2.
287 Gaisl T, Rejmer P, Thiel S, . Effects of suboptimal adherence of CPAP therapy on symptoms of obstructive sleep apnoea: a randomised, double-blind, controlled trial. Eur Respir J. 2020 Mar;55(3)doi: 10.1183/13993003.01526-2019. PMID: 31862764. Exclusion Code: X2.31862764
288 Gan E, Goh C, Lau M, . Real world experiences and clinical outcomes of patients on continuous positive airway pressure or chronic noninvasive ventilation. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X12.
289 Gan WL, Ban YLA, Faisal AHM. Prospective randomised controlled trial to compare fixed pressure CPAP and auto adjusting pressure CPAP among symptomatic obstructive sleep apnoea subjects in a tertiary care centre Malaysia. Sleep Medicine. 2019;64:S124. doi: 10.1016/j.sleep.2019.11.340. Exclusion Code: X5.
290 Gao YN, Wu YC, Lin SY, . Short-term efficacy of minimally invasive treatments for adult obstructive sleep apnea: a systematic review and network meta-analysis of randomized controlled trials. J Formos Med Assoc. 2019 Apr;118(4):750–65. doi: 10.1016/j.jfma.2018.02.008. PMID: 29523457. Exclusion Code: X5.29523457
291 Garcia LR, Padilla DL, Lajas AC, . CPAP in the elderly with non-severe obstructive sleep apnea: effect on cardiovascular events and somnolence. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA2276. Exclusion Code: X12.
292 Garg N, Rolle AJ, Lee TA, . Home-based diagnosis of obstructive sleep apnea in an urban population. J Clin Sleep Med. 2014 Aug 15;10(8):879–85. doi: 10.5664/jcsm.3960. PMID: 25126034. Exclusion Code: X3.25126034
293 Garland SN, Chakravorty S, Morales K, . A randomized placebo controlled trial of CBT-I +/− armodafinil in patients with insomnia comorbid with sleep apnea. Sleep. 2016;39:A216–A7. Exclusion Code: X4.
294 Gawrysiak MJ, Baime M, King TS, . Intervention Design and Trial Protocol: Mindfulness-based Exposure for PAP-associated Claustrophobia. West J Nurs Res. 2021 Mar;43(3):261–72. doi: 10.1177/0193945920924608. PMID: 32443950. Exclusion Code: X4.32443950
295 Gemici Yİ, Ozturk L, Celebi C. Evaluation of cognitive functions in patients with obstructive sleep apnea before and after continuous positive airway pressure treatment. Neurology Asia. 2018;23(3):253–8. Exclusion Code: X5.
296 George J, Wang L, Nawabit R, . Impact of CPAP versus supplemental oxygen on cardiac electrophysiological indices in obstructive sleep apnea: The heartbeat study. Sleep. 2018;41:A168. Exclusion Code: X12.
297 Georgiou H, Kee K, Goldin J. Use of cloud based technology to optimise CPAP initiation in OSA. Respirology. 2018;23:64. doi: 10.1111/resp.13267. Exclusion Code: X12.
298 Giorgiana Dediu G, Balaceanu A, Iancu A, . Continuous positive airway pressure (CPAP) effect on blood pressure in patients with obstructive sleep apnea syndrome (OSAS). European Journal of Heart Failure. 2017;19:256. doi: 10.1002/ejhf.833. Exclusion Code: X8.
299 Giulietti F, Spannella F, Di Pentima C, . Blood pressure and metabolic evaluation in overweight/obese patients with obstructive sleep apnea before and after 3-month continuous positive airway pressure therapy. Italian Journal of Medicine. 2018;12(2):65. doi: 10.4081/itjm.2018.s2. Exclusion Code: X8.
300 Glantz H, Johansson MC, Thunström E, . Effect of CPAP on diastolic function in coronary artery disease patients with nonsleepy obstructive sleep apnea: A randomized controlled trial. Int J Cardiol. 2017 Aug 15;241:12–8. doi: 10.1016/j.ijcard.2017.03.100. PMID: 28408103. Exclusion Code: X9.28408103
301 Glos M, Fietze I, Schöbel C, . Therapy of OSA by mandibular advancement device therapy-effects of a crossover trial of SomnoDent® and CPAP on respiration and daytime cardiac autonomic function. Journal of Sleep Research. 2016;25:168. doi: 10.1111/jsr.12446. Exclusion Code: X5.
302 Godoroja DD, Cioc DA. Identification of significant obstructive sleep apnoea in the obese patient: development of the novel DX-OSA score. Rom J Anaesth Intensive Care. 2016 Oct;23(2):111–21. doi: 10.21454/rjaic.7518/232.dxo. PMID: 28913484. Exclusion Code: X7.28913484
303 Godoy LB, Sousa KM, Palombini LO, . Long term oral appliance therapy decreases stress symptoms in upper airway resistance syndrome patients. Sleep. 2020;43(SUPPL 1):A244. doi: 10.1093/sleep/zsaa056.635. Exclusion Code: X2.
304 Godoy LBM, Palombini L, Poyares D, . Long-term oral appliance therapy improves daytime function and mood in upper airway resistance syndrome patients. Sleep. 2017 Dec 1;40(12)doi: 10.1093/sleep/zsx175. PMID: 29045745. Exclusion Code: X2.29045745
305 Goel AK, Talwar D, Jain SK. Evaluation of short-term use of nocturnal nasal continuous positive airway pressure for a clinical profile and exercise capacity in adult patients with obstructive sleep apnea-hypopnea syndrome. Lung India. 2015;32(3):225–32. doi: 10.4103/0970-2113.156226. Exclusion Code: X8.25983407
306 Goldman O, Rector T, Wetherbee EE, . Overnight oximetry has high positive predictive value for OSA in an unattended sleep study referral program. American Journal of Respiratory and Critical Care Medicine. 2014;189. Exclusion Code: X12.
307 Golish J, Sleeper G, Bastani B, . Sleep-repositioning is a required component in making nasal EPAP effective in controlling OSA. Sleep. 2017;40:A213. Exclusion Code: X8.
308 Gong F, Chen X, Wu Y, . Nurse vs. physician-led care for obstructive sleep apnoea: a systematic review and meta-analysis of randomized trials. J Adv Nurs. 2018 Mar;74(3):501–6. doi: 10.1111/jan.13346. PMID: 28543355. Exclusion Code: X6.28543355
309 Gooneratne NS, Richards KC, Joffe M, . Sleep disordered breathing with excessive daytime sleepiness is a risk factor for mortality in older adults. Sleep. 2011 Apr 1;34(4):435–42. doi: 10.1093/sleep/34.4.435. PMID: 21461321. Exclusion Code: X8.21461321
310 Gota CE, Jhala N, Kaouk S, . Sleep apnea and fibromyalgia: data from the Cleveland clinic fibromyalgia registry. Arthritis and Rheumatology. 2018;70:2038–9. doi: 10.1002/art.40700. Exclusion Code: X8.
311 Gottlieb DJ, Yenokyan G, Newman AB, . Prospective study of obstructive sleep apnea and incident coronary heart disease and heart failure: the sleep heart health study. Circulation. 2010 Jul 27;122(4):352–60. doi: 10.1161/CIRCULATIONAHA.109.901801. PMID: 20625114. Exclusion Code: X8.20625114
312 Green M, Ken-Dror G, Fluck D, . Meta-analysis of changes in the levels of catecholamines and blood pressure with continuous positive airway pressure therapy in obstructive sleep apnea. J Clin Hypertens (Greenwich). 2020 Sep 24doi: 10.1111/jch.14061. PMID: 32970922. Exclusion Code: X9.32970922
313 Green M, Ken-Dror G, Fluck D, . Meta-analysis of changes in the levels of catecholamines and blood pressure with continuous positive airway pressure therapy in obstructive sleep apnea. J Clin Hypertens (Greenwich). 2021 Jan;23(1):12–20. doi: 10.1111/jch.14061. PMID: 32970922. Exclusion Code: X15.32970922
314 Gregori Pla C, Durduran T, Fortuna Gutiérrez A. Cerebral hemodynamic response to an orthostatic challenge in severe obstructive sleep apnea patients before and after 2 years of continuous positive air pressure therapy. Journal of Neurosurgical Anesthesiology. 2016;28(2):S36. doi: 10.1097/ANA.0000000000000287. Exclusion Code: X6.
315 Grinek S, Sanchez De La Torre M, Nadkarni G, . Heterogeneous effects of continuous positive airway pressure (CPAP) treatment on cardiovascular outcomes in obstructive sleep apnea (OSA): Application of machine learning in the ISAACC trial. American Journal of Respiratory and Critical Care Medicine. 2021;203(9)doi: 10.1164/ajrccm-conference.2021.203.1_MeetingAbstracts.A1104. Exclusion Code: X5.
316 Grover M, Mookadam M, Chang YH, . Validating the diagnostic accuracy of the sleep apnea clinical score for use in primary care populations. Mayo Clin Proc. 2016 Apr;91(4):469–76. doi: 10.1016/j.mayocp.2016.01.022. PMID: 26961270. Exclusion Code: X5.26961270
317 Grozev L, Terziyski K, Draganova A, . Effects of individually constructed oral appliance on the polysomnographic parameters in patients with obstructive sleep apnea. Journal of IMAB - Annual Proceeding (Scientific Papers). 2018;24(2):1978–84. doi: 10.5272/jimab.2018242.1978. Exclusion Code: X8.
318 Guan L, Wu W, Huo Y, . Efficacy of bilevel positive airway pressure and continuous positive airway pressure therapy in patients with obesity hypoventilation syndrome: protocol for systematic review and meta-analysis. BMJ Open. 2018 May 3;8(5):e020832. doi: 10.1136/bmjopen-2017-020832. PMID: 29724743. Exclusion Code: X8.29724743
319 Guerrero A, Embid C, Isetta V, . Management of sleep apnea without high pretest probability or with comorbidities by three nights of portable sleep monitoring. Sleep. 2014 Aug 1;37(8):1363–73. doi: 10.5665/sleep.3932. PMID: 25083017. Exclusion Code: X3.25083017
320 Guimarães TM, Poyares D, Oliveira ESL, . The treatment of mild OSA with CPAP or mandibular advancement device and the effect on blood pressure and endothelial function after one year of treatment. J Clin Sleep Med. 2021 Feb 1;17(2):149–58. doi: 10.5664/jcsm.8822. PMID: 32964829. Exclusion Code: X10.32964829
321 Gulati A, Oscroft N, Chadwick R, . The impact of changing people with sleep apnea using CPAP less than 4 h per night to a Bi-level device. Respir Med. 2015 Jun;109(6):778–83. doi: 10.1016/j.rmed.2015.01.020. PMID: 25933913. Exclusion Code: X5.25933913
322 Gulay DI, Hakan C. The effect of positive airway pressure therapy on sexual life and quality of life in women with moderate or severe obstructive sleep apnea syndrome. Signa Vitae. 2021;17(1):128–32. doi: 10.22514/sv.2020.16.0069. Exclusion Code: X5.
323 Guleria R, Tiwari P, Madan K, . Utility of fractional exhaled nitric oxide in OSA. Chest. 2017;152(4):A1058. doi: 10.1016/j.chest.2017.08.1093. Exclusion Code: X3.
324 Gunbatar H, Bulut MD, Ekin S, . A silent pre-stroke damage: obstructive sleep apnea syndrome. International Journal of Clinical and Experimental Medicine. 2016;9(2):3481–8. Exclusion Code: X8.
325 Gunduz C, Basoglu OK, Schiza S, . The effect of positive airway pressure on cholesterol in patients with sleep apnea: Data from the European Sleep Apnea Network (ESADA). European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA2005. Exclusion Code: X6.
326 Guo J, Sun Y, Xue LJ, . Effect of CPAP therapy on cardiovascular events and mortality in patients with obstructive sleep apnea: a meta-analysis. Sleep Breath. 2016 Sep;20(3):965–74. doi: 10.1007/s11325-016-1319-y. PMID: 26873722. Exclusion Code: X8.26873722
327 Guo Q, Song WD, Li W, . Weighted Epworth sleepiness scale predicted the apnea-hypopnea index better. Respir Res. 2020 Jun 12;21(1):147. doi: 10.1186/s12931-020-01417-w. PMID: 32532260. Exclusion Code: X10.32532260
328 Gupta A, Shukla G, Afsar M, . Prevention of new vascular events in patients with obstructive sleep apnea and stroke, using CPAP: a randomized controlled trial. Sleep Medicine. 2015;16:S26. doi: 10.1016/j.sleep.2015.02.064. Exclusion Code: X2.
329 Gupta MA, Simpson FC, Lyons DC. The effect of treating obstructive sleep apnea with positive airway pressure on depression and other subjective symptoms: A systematic review and meta-analysis. Sleep Med Rev. 2016 Aug;28:55–68. doi: 10.1016/j.smrv.2015.07.002. PMID: 26454823. Exclusion Code: X8.26454823
330 Gupta R, Ali R, Dhyani M, . Hindi translation of Berlin questionnaire and its validation as a screening instrument for obstructive sleep apnea. Journal of Neurosciences in Rural Practice. 2016;7(2):244–7. doi: 10.4103/0976-3147.176187. Exclusion Code: X10.27114656
331 Gutierrez A, Fallucca E, Sanchez-Gonzalez MA, . Cpap positively impacts aortic hemodynamics nocturnal variability in patients with obstructive sleep apnea. Psychosomatic Medicine. 2019;81(4):A79. doi: 10.1097/PSY.0000000000000699. Exclusion Code: X6.
332 Hamaoka T, Murai H, Sugimoto H, . Prognostic differences between severe and very severe obstructive sleep apnea patients treated with continuous positive airway pressure; five years outcome. Circulation. 2018;138. Exclusion Code: X12.
333 Hamaoka T, Murai H, Takata S, . Different prognosis between severe and very severe obstructive sleep apnea patients; Five year outcomes. J Cardiol. 2020 Dec;76(6):573–9. doi: 10.1016/j.jjcc.2020.06.010. PMID: 32620307. Exclusion Code: X5.32620307
334 Hamoda MM, Peres B, Kohzuka Y, . Continuous positive airway pressure versus mandibular advancement splints in obstructive sleep apnea patients: a randomized trial. Sleep Medicine. 2019;64:S145–S6. doi: 10.1016/j.sleep.2019.11.398. Exclusion Code: X5.
335 Han YY, Meng FH, Zhang JS, . Efficacy of continuous positive airway pressure for resistant hypertension patients with obstructive sleep apnea: a meta-analysis. Chinese Journal of Evidence-Based Medicine. 2016;16(4):427–34. doi: 10.7507/1672-2531.20160066. Exclusion Code: X1.
336 Hao K, Zhang X. Intraocular pressure during continuous positive airway pressure. Med Princ Pract. 2017;26(1):93. doi: 10.1159/000450647. PMID: 27607463. Exclusion Code: X8.27607463
337 Harańczyk M, Konieczyńska M, Płazak W. Continuous positive airway pressure treatment in sleep apnea: patient compliance and impact on the right heart. Sleep and Biological Rhythms. 2021doi: 10.1007/s41105-021-00340-x. Exclusion Code: X5.
338 Hardy Tabet C, Lopez-Bushnell K. Sleep, snoring, and surgery: OSA screening matters. J Perianesth Nurs. 2018 Dec;33(6):790–800. doi: 10.1016/j.jopan.2017.01.009. PMID: 29397339. Exclusion Code: X8.29397339
339 Harmell AL, Neikrug AB, Palmer BW, . Obstructive sleep apnea and cognition in Parkinson’s disease. Sleep Med. 2016 May;21:28–34. doi: 10.1016/j.sleep.2016.01.001. PMID: 27448468. Exclusion Code: X6.27448468
340 Hedberg P, Nohlert E, Tegelberg Å. Effects of oral appliance treatment on inflammatory biomarkers in obstructive sleep apnea: a randomised controlled trial. J Sleep Res. 2020 Dec 9:e13253. doi: 10.1111/jsr.13253. PMID: 33300239. Exclusion Code: X6.33300239
341 Hedberg P, Nohlert E, Tegelberg Å. Effects of oral appliance treatment on inflammatory biomarkers in obstructive sleep apnea: A randomised controlled trial. J Sleep Res. 2021 Aug;30(4):e13253. doi: 10.1111/jsr.13253. PMID: 33300239. Exclusion Code: X6.33300239
342 Heeley E, Billot L, Anderson CS, . Statistical analysis plan for the Sleep Apnea cardioVascular Endpoints study: An international randomised controlled trial to determine whether continuous positive airways pressure treatment for obstructive sleep apnea in patients with CV disease prevents secondary cardiovascular events. Int J Stroke. 2016 Jan;11(1):148–50. doi: 10.1177/1747493015607504. PMID: 26763030. Exclusion Code: X6.26763030
343 Henderson LA, Fatouleh RH, Lundblad LC, . Effects of 12 months continuous positive airway pressure on sympathetic activity related brainstem function and structure in obstructive sleep apnea. Frontiers in Neuroscience. 2016;10(MAR)doi: 10.3389/fnins.2016.00090. Exclusion Code: X5.
344 Herrera Y, Poon J, Ho KS, . Cardiovascular outcomes in patients with sleep apnea treated with positive airway pressure: meta-analysis of randomized controlled trials. Chest. 2020;158(4):A2350. doi: 10.1016/j.chest.2020.08.1994. Exclusion Code: X8.
345 Hetzenecker A, Escourrou P, Kuna ST, . Treatment of sleep apnea in chronic heart failure patients with auto-servo ventilation improves sleep fragmentation: a randomized controlled trial. Sleep Med. 2016 Jan;17:25–31. doi: 10.1016/j.sleep.2015.08.020. PMID: 26847970. Exclusion Code: X6.26847970
346 Hilmisson H, Magnusdottir S. Beyond the apnea hypopnea index (AHI): importance of sleep quality management of obstructive sleep apnea (OSA) and related mortality in patients with cardiovascular disease. Sleep Medicine. 2019;64:S155. doi: 10.1016/j.sleep.2019.11.424. Exclusion Code: X6.
347 Hirono H, Watanabe K, Hasegawa K, . Impact of continuous positive airway pressure therapy for nonalcoholic fatty liver disease in patients with obstructive sleep apnea. World Journal of Clinical Cases. 2021;9(19):5112–25. doi: 10.12998/wjcc.v9.i19.5112. Exclusion Code: X5.34307562
348 Hirotsu C, Haba-Rubio J, Andries D, . Effect of three hypopnea scoring criteria on OSA prevalence and associated comorbidities in the general population. J Clin Sleep Med. 2019 Feb 15;15(2):183–94. doi: 10.5664/jcsm.7612. PMID: 30736872. Exclusion Code: X3.30736872
349 Hisata J, Ono Y, Sekizuka H, . Evaluation of CPAP adherence in most severe OSAS. Therapeutic Research. 2017;38(5):519–26. Exclusion Code: X1.
350 Hobzova M, Hubackova L, Prasko J, . Cognitive function and depressivity in patients with obstructive sleep apnea before and after CPAP treatment. European Psychiatry. 2018;48:S295. doi: 10.1016/j.eurpsy.2017.12.016. Exclusion Code: X12.
351 Holley A, Shaha D, Costan-Toth C, . A randomized, placebo-controlled trial using a novel PAP delivery platform to treat patients with OSA and comorbid PTSD. Sleep Breath. 2020 Sep;24(3):1001–9. doi: 10.1007/s11325-019-01936-x. PMID: 31691105. Exclusion Code: X5.31691105
352 Holley A, Sheikh K, Robertson B, . Using a novel CPAP delivery platform to improve compliance in patients diagnosed with OSA and co-morbid PTSD. Chest. 2016;150(4):1260A. doi: 10.1016/j.chest.2016.08.1374. Exclusion Code: X8.27316558
353 Holmes TH, Kushida CA. Adherence to continuous positive airway pressure improves attention/psychomotor function and sleepiness: a bias-reduction method with further assessment of APPLES. Sleep Med. 2017 Sep;37:130–4. doi: 10.1016/j.sleep.2017.06.022. PMID: 28899524. Exclusion Code: X5.28899524
354 Hooper R, Compton-Price T. CPAP therapy improves depressive symptoms in OSA patients, including those using antidepressant medication. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA4143. Exclusion Code: X8.
355 Horvath CM, Jossen J, Kröll D, . Prevalence and prediction of obstructive sleep apnea prior to bariatric surgery-gender-specific performance of four sleep questionnaires. Obes Surg. 2018 Sep;28(9):2720–6. doi: 10.1007/s11695-018-3222-z. PMID: 29616468. Exclusion Code: X7.29616468
356 Howard J, Slee AE, Skene S, . Overnight auto-adjusting continuous airway pressure + standard care compared with standard care alone in the prevention of morbidity in sickle cell disease phase II (POMS2b): study protocol for a randomised controlled trial. Trials. 2018 Jan 22;19(1):55. doi: 10.1186/s13063-017-2419-0. PMID: 29357947. Exclusion Code: X2.29357947
357 Hoyos CM, Murugan SM, Melehan KL, . Dose-dependent effects of continuous positive airway pressure for sleep apnea on weight or metabolic function: Individual patient-level clinical trial meta-analysis. J Sleep Res. 2019 Oct;28(5):e12788. doi: 10.1111/jsr.12788. PMID: 30450787. Exclusion Code: X6.30450787
358 Hoyos CM, Yee BJ, Wong KK, . Treatment of sleep apnea with CPAP lowers central and peripheral blood pressure independent of the time-of-day: a randomized controlled study. Am J Hypertens. 2015 Oct;28(10):1222–8. doi: 10.1093/ajh/hpv023. PMID: 25820243. Exclusion Code: X9.25820243
359 Hu XY, Perri R, Ting T, . Outcomes in patients with REM-related obstructive sleep apnoea (REM-OSA) treated with continuous positive airway pressure (CPAP). European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA4147. Exclusion Code: X2.
360 Huang F, Goldman M, Lotz G. MT3 outcomes and hospital utilization of sleep apnea patients treated with positive airway pressure during and after onset of heart failure. Value in Health. 2019;22:S411. doi: 10.1016/j.jval.2019.09.075. Exclusion Code: X5.
361 Huang Z, Liu Z, Zhao Z, . Effects of continuous positive airway pressure on lipidaemia and high-sensitivity C-reactive protein levels in non-obese patients with coronary artery disease and obstructive sleep apnoea. Heart Lung Circ. 2016 Jun;25(6):576–83. doi: 10.1016/j.hlc.2015.10.021. PMID: 26804247. Exclusion Code: X10.26804247
362 Hui DS, Ng S, Wong G, . Obstructive sleep apnea and CPAP treatment response in patients with non alcoholic fatty liver disease. American Journal of Respiratory and Critical Care Medicine. 2020;201(1). Exclusion Code: X12.
363 Hunt TE, Traaen GM, Aakeroy L, . Effect of continuous positive airway pressure therapy on recurrence of atrial fibrillation after catheter ablation in patients with obstructive sleep apnea: A randomized controlled trial. Europace. 2021;23(SUPPL 3):iii193. doi: 10.1093/europace/euab116.174. Exclusion Code: X12.
364 Ibrahim MIS, Mohamad H, Mohamad A, . Association between neck circumference and the severity of obstructive sleep apnea. Polish Annals of Medicine. 2020;27(1):1–6. doi: 10.29089/2020.20.00097. Exclusion Code: X2.
365 Iftikhar I, Khan M, Das A, . Meta-analysis: Continuous positive airway pressure therapy improves insulin resistance in patients with obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2012;185. Exclusion Code: X8.
366 Iftikhar IH, Bittencourt L, Youngstedt SD, . Comparative efficacy of CPAP, MADs, exercise-training, and dietary weight loss for sleep apnea: a network meta-analysis. Sleep Med. 2017 Feb;30:7–14. doi: 10.1016/j.sleep.2016.06.001. PMID: 28215266. Exclusion Code: X5.28215266
367 Iftikhar IH, Greer M, Wigger GW, . A network meta-analysis of different positive airway pressure interventions in obesity hypoventilation syndrome. J Sleep Res. 2020 Aug 12:e13158. doi: 10.1111/jsr.13158. PMID: 32789956. Exclusion Code: X2.32789956
368 Iftikhar IH, Valentine C, Bittencourt L, . Effects of continuous positive airway pressure on blood pressure in patients with resistant hypertension and obstructive sleep apnea: A meta-analysis. American Journal of Respiratory and Critical Care Medicine. 2014;189. Exclusion Code: X8.
369 Ilea A, Timuș D, Höpken J, . Oral appliance therapy in obstructive sleep apnea and snoring - systematic review and new directions of development. Cranio. 2019 Oct 5:1–12. doi: 10.1080/08869634.2019.1673285. PMID: 31588866. Exclusion Code: X15.31033422
370 Imayama I, Doumit J, Hussain J, . Effectiveness of positive airway pressure treatment in veterans with moderate to severe obstructive sleep apnea. Sleep. 2018;41:A193–A4. Exclusion Code: X5.
371 Inalkac Gemici Y, Celik Y, Sut N, . Cognitive evaluation with Montreal cognitive assessment (MOCA) test of patients with obstructive sleep apnea syndrome. Journal of Sleep Research. 2016;25:131. doi: 10.1111/jsr.12446. Exclusion Code: X5.26762182
372 Incerti Parenti S, Aroni E, Laffranchi L, . The effectiveness of mandibular advancement devices in the treatment of obstructive sleep apnoea in adults: a methodological quality assessment of systematic reviews. Eur J Orthod. 2020 Nov 3;42(5):483–93. doi: 10.1093/ejo/cjz065. PMID: 31504379. Exclusion Code: X8.31504379
373 Ip M, Yam L, Lam C, . Randomised controlled study of treatment for mild and moderate sleep apnoea. Hong Kong Medical Journal. 2007;13(3):44–6. Exclusion Code: X10.
374 Ip MS, Tse HF, Lam B, . Endothelial function in obstructive sleep apnea and response to treatment. Am J Respir Crit Care Med. 2004 Feb 1;169(3):348–53. doi: 10.1164/rccm.200306-767OC. PMID: 14551167. Exclusion Code: X9.14551167
375 İrer B, Çelikhisar A, Çelikhisar H, . Evaluation of sexual dysfunction, lower urinary tract symptoms and quality of life in men with obstructive sleep apnea syndrome and the efficacy of continuous positive airway pressure therapy. Urology. 2018 Nov;121:86–92. doi: 10.1016/j.urology.2018.08.001. PMID: 30118776. Exclusion Code: X5.30118776
376 Isaac BTJ, Clarke SE, Islam MS, . Screening for obstructive sleep apnoea using the STOPBANG questionnaire and the Epworth sleepiness score in patients admitted on the unselected acute medical take in a UK hospital. Clin Med (Lond). 2017 Dec;17(6):499–503. doi: 10.7861/clinmedicine.17-6-499. PMID: 29196349. Exclusion Code: X5.29196349
377 Isara AR, Aigbokhaode AQ. Obstructive sleep apnoea risk and excessive daytime sleepiness among intercity commercial drivers in Benin City, Nigeria. African Journal of Respiratory Medicine. 2017;12(2):12–6. Exclusion Code: X8.
378 Isetta V, León C, Embid C, . Telemedicine-based strategy for sleep apnea management: a multicenter randomized controlled trial. European Respiratory Journal. 2014;44. Exclusion Code: X4.
379 Isetta V, Villanueva J, Navajas D, . Bench assessment of a new portable automatic positive airway pressure device for sleep apnea. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA2300. Exclusion Code: X8.
380 Ish P. A retrospective comparison of Epworth sleepiness scale and STOP-BANG questionnaire for diagnosing obstructive sleep apnea in North India. Lung India. 2019;36(9):S113. doi: 10.4103/0970-2113.271103. Exclusion Code: X10.
381 Ishiyama H, Hasebe D, Sato K, . The efficacy of device designs (mono-block or bi-block) in oral appliance therapy for obstructive sleep apnea patients: a systematic review and meta-analysis. Int J Environ Res Public Health. 2019 Aug 31;16(17)doi: 10.3390/ijerph16173182. PMID: 31480465. Exclusion Code: X5.31480465
382 Ishiyama H, Inukai S, Nishiyama A, . Effect of jaw-opening exercise on prevention of temporomandibular disorders pain associated with oral appliance therapy in obstructive sleep apnea patients: A randomized, double-blind, placebo-controlled trial. J Prosthodont Res. 2017 Jul;61(3):259–67. doi: 10.1016/j.jpor.2016.12.001. PMID: 28063976. Exclusion Code: X4.28063976
383 Jackson M, Collins A, Berlowitz D, . Efficacy of sleep position modification to treat positional obstructive sleep apnea. Sleep Med. 2015 Apr;16(4):545–52. doi: 10.1016/j.sleep.2015.01.008. PMID: 25771294. Exclusion Code: X4.25771294
384 Jaimes Beltrán R, Ramírez Figueroa J, Skupin Rueda NA. Comorbidity of sleep apnoea syndrome in patients with fibromyalgia in a sleep clinic. Revista Colombiana de Reumatologia. 2021doi: 10.1016/j.rcreu.2021.02.007. Exclusion Code: X1.
385 Jain S, Gurubhagavatula I, Townsend R, . Effect of CPAP, weight loss, or CPAP plus weight loss on central hemodynamics and arterial stiffness. Hypertension. 2017 Dec;70(6):1283–90. doi: 10.1161/hypertensionaha.117.09392. PMID: 29038203. Exclusion Code: X6.29038203
386 Janovsky CCPS, Rolim LCSP, Sá JR, . Cardiovascular autonomic neuropathy contributes to sleep apnea in young and lean type 1 diabetes mellitus patients. Frontiers in Endocrinology. 2014;5(AUG)doi: 10.3389/fendo.2014.00119. Exclusion Code: X3.
387 Japie C, Badila E, Bunea M, . Effect of continuous positive airway pressure therapy on blood pressure in patients with moderate-severe obstructive sleep apnea and difficult-to-control arterial hypertension. Journal of Hypertension. 2016;34:e212. doi: 10.1097/01.hjh.0000491940.80686.79. Exclusion Code: X5.
388 Jarrah MI, Yassin AM, Ibdah RK, . Screening for obstructive sleep apnea among patients undergoing coronary catheterization in Jordan. Vasc Health Risk Manag. 2019;15:109–13. doi: 10.2147/vhrm.s203307. PMID: 31118652. Exclusion Code: X7.31118652
389 Javaheri S, Gottlieb DJ, Quan SF. Effects of continuous positive airway pressure on blood pressure in obstructive sleep apnea. Sleep. 2019;42:A216. doi: 10.1093/sleep/zsz067.539. Exclusion Code: X9.
390 Javaheri S, Gottlieb DJ, Quan SF. Effects of continuous positive airway pressure on blood pressure in obstructive sleep apnea patients: The Apnea Positive Pressure Long-term Efficacy Study (APPLES). J Sleep Res. 2020 Apr;29(2):e12943. doi: 10.1111/jsr.12943. PMID: 31726485. Exclusion Code: X9.31726485
391 Javaheri S, Martinez-Garcia MA, Campos-Rodriguez F, . Continuous positive airway pressure adherence for prevention of major adverse cerebrovascular and cardiovascular events in obstructive sleep apnea. Am J Respir Crit Care Med. 2020 Mar 1;201(5):607–10. doi: 10.1164/rccm.201908-1593LE. PMID: 31644880. Exclusion Code: X8.31644880
392 Jim AS, Weber SAT, Figueiredo DB. Inflammatory profile and oxidative stress level in patients with obstructive sleep apnea syndrome before and after use of continuous positive airway pressure: A randomized double-blind clinical trial. International Archives of Otorhinolaryngology. 2016;20:S3. Exclusion Code: X12.
393 Jin A, Castilho GL, Weber SAT, . CPAP treatment and inflammatory profile. Otolaryngology - Head and Neck Surgery (United States). 2016;155:P278. doi: 10.1177/0194599816655337k. Exclusion Code: X5.
394 Johal A, Agha B. Ready-made versus custom-made mandibular advancement appliances in obstructive sleep apnea: a systematic review and meta-analysis. J Sleep Res. 2018 Dec;27(6):e12660. doi: 10.1111/jsr.12660. PMID: 29405512. Exclusion Code: X5.29405512
395 Johansson K, Neovius M, Lagerros YT, . Effect of a very low energy diet on moderate and severe obstructive sleep apnoea in obese men: a randomised controlled trial. BMJ. 2009 Dec 3;339:b4609. doi: 10.1136/bmj.b4609. PMID: 19959590. Exclusion Code: X4.19959590
396 Jonas DE, Amick HR, Feltner C, . Screening for Obstructive Sleep Apnea in Adults: An Evidence Review for the US Preventive Services Task Force Agency for Healthcare Research and Quality. Rockville, MD: Agency for Healthcare Research and Quality; 2017. Exclusion Code: X8.
397 Jonasson D, Starkey S, Irvine S, . Screening for obstructive sleep apnea (OSA) in atrial fibrillation (AF): what’s the best test? Sleep Medicine. 2017;40:e7–e8. Exclusion Code: X12.
398 Joseph N, Shirali A, Shenoy AB, . Risk assessment of obstructive sleep apnea and its association with fatigue and sleepiness among hospital inpatients. Current Respiratory Medicine Reviews. 2017;13(4):221–30. doi: 10.2174/1573398X14666180327114958. Exclusion Code: X2.
399 Joyeux-Faure M, Baguet JP, Barone-Rochette G, . Effect of the continuous positive airway pressure in apneic patients with resistant hypertension: Results from the randomized controlled RHOOSAS study. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA4719. Exclusion Code: X12.
400 Joyeux-Faure M, Baguet JP, Barone-Rochette G, . Continuous positive airway pressure reduces night-time blood pressure and heart rate in patients with obstructive sleep apnea and resistant hypertension: The RHOOSAS randomized controlled trial. Frontiers in Neurology. 2018;9(MAY)doi: 10.3389/fneur.2018.00318. Exclusion Code: X9.
401 Joyeux-Faure M, Naegelé B, Pépin JL, . Continuous positive airway pressure treatment impact on memory processes in obstructive sleep apnea patients: a randomized sham-controlled trial. Sleep Med. 2016 Aug;24:44–50. doi: 10.1016/j.sleep.2016.06.023. PMID: 27810185. Exclusion Code: X6.27810185
402 Jullian-Desayes I, Tamisier R, Zarski JP, . Impact of continuous positive airway pressure on liver injury induced by obstructive sleep apnea: data from randomized controlled trials. European Respiratory Journal. 2015;46doi: 10.1183/13993003.congress2015.OA299. Exclusion Code: X8.
403 Jullian-Desayes I, Tamisier R, Zarski JP, . Impact of effective versus sham continuous positive airway pressure on liver injury in obstructive sleep apnoea: data from randomized trials. Respirology. 2016 Feb;21(2):378–85. doi: 10.1111/resp.12672. PMID: 26567858. Exclusion Code: X6.26567858
404 Jurado-Gámez B, Guglielmi O, Gude F, . Workplace accidents, absenteeism and productivity in patients with sleep apnea. Archivos de Bronconeumologia. 2015;51(5):213–8. doi: 10.1016/j.arbr.2014.12.002. Exclusion Code: X8.25129165
405 Jyothi RK, Mathangi DC, Chellaiyan VG. Is Mallampati scoring and PPNC an easier and better predictor for Obstructive Sleep Apnea (OSA)? Annals of Tropical Medicine and Public Health. 2020;23(20)doi: 10.36295/ASRO.2020.232210. Exclusion Code: X3.
406 Kainulainen S, Duce B, Korkalainen H, . Increased nocturnal arterial pulsation frequencies of obstructive sleep apnoea patients is associated with an increased number of lapses in a psychomotor vigilance task. ERJ Open Research. 2020;6(4):1–13. doi: 10.1183/23120541.00277-2020. Exclusion Code: X6.
407 Kanbay A, Kaya E, Büyükoglan H, . Correlation between pentraxin-3 and endothelial dysfunction in obstructive sleep apnea syndrome. Annals of Thoracic Medicine. 2015;10(3):199–203. doi: 10.4103/1817-1737.160840. Exclusion Code: X6.26229563
408 Kang HH, Lim CH, Oh JH, . On daytime sleepiness and depressive symptom in patients with obstructive sleep apnea. Journal of Neurogastroenterology and Motility. 2020;27(2):215–22. doi: 10.5056/JNM20071. Exclusion Code: X8.
409 Karhu T, Myllymaa S, Nikkonen S, . Diabetes and cardiovascular diseases are associated with the worsening of intermittent hypoxaemia. Journal of Sleep Research. 2021doi: 10.1111/jsr.13441. Exclusion Code: X8.
410 Kashaninasab F, Alavi K, Farhadi M, . A comparative study of four Persian versions of sleep questionnaires for screening obstructive sleep apnea syndrome (OSAS). Med J Islam Repub Iran. 2017;31:122. doi: 10.14196/mjiri.31.122. PMID: 29951423. Exclusion Code: X10.29951423
411 Kastoer C, Dieltjens M, Oorts E, . The use of remotely controlled mandibular positioner as a predictive screening tool for mandibular advancement device therapy in patients with obstructive sleep apnea through single-night progressive titration of the mandible: a systematic review. J Clin Sleep Med. 2016 Oct 15;12(10):1411–21. doi: 10.5664/jcsm.6202. PMID: 27568892. Exclusion Code: X4.27568892
412 Kaur S, Wang L, Walia H, . Effect of continuous positive airway pressure on quality of life measures in moderate to severe obstructive sleep apnea: Sleep apnea stress study randomized controlled trial. Sleep. 2018;41:A215. Exclusion Code: X12.
413 Kee K, Dixon J, Shaw J, . Comparison of commonly used questionnaires to identify obstructive sleep apnea in a high-risk population. J Clin Sleep Med. 2018 Dec 15;14(12):2057–64. doi: 10.5664/jcsm.7536. PMID: 30518441. Exclusion Code: X5.30518441
414 Kelly J, Wimms A, Turnbull C, . The effect of CPAP on quality of life in patients with Very’ mild Obstructive Sleep Apnoea (OSA): Results from a subset of the MERGE Randomised Trial. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.4736. Exclusion Code: X12.
415 Kelly JL, Wimms AJ, Turnbull CD, . The merge randomized controlled trial: effect of continuous positive airway pressure (CPAP) on vitality in mild obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2020;201(1). Exclusion Code: X12.
416 Ken-Dror G, Fry CH, Murray P, . Changes in cortisol levels by continuous positive airway pressure in patients with obstructive sleep apnoea: Meta-analysis of 637 individuals. Clin Endocrinol (Oxf). 2021 Jul 29doi: 10.1111/cen.14573. PMID: 34323304. Exclusion Code: X6.34323304
417 Kendzerska T, Grewal M, Ryan CM. Utility of acoustic pharyngometry for the diagnosis of obstructive sleep apnea. Ann Am Thorac Soc. 2016 Nov;13(11):2019–26. doi: 10.1513/AnnalsATS.201601-056OC. PMID: 27529798. Exclusion Code: X3.27529798
418 Kerns ES, Kim ED, Meoni LA, . Obstructive sleep apnea increases sudden cardiac death in incident hemodialysis patients. Am J Nephrol. 2018;48(2):147–56. doi: 10.1159/000489963. PMID: 30110675. Exclusion Code: X4.30110675
419 Kesireddy N, Khokher W, Mudiyansselage P, . CPAP Effects on Recurrent Atrial Fibrillation after Ablation. American Journal of Respiratory and Critical Care Medicine. 2021;203(9)doi: 10.1164/ajrccm-conference.2021.TP127. Exclusion Code: X6.
420 Khadadah S, Kimoff RJ, Duquette P, . Effect of continuous positive airway pressure treatment of obstructive sleep apnea-hypopnea in multiple sclerosis: A randomized, double-blind, placebo-controlled trial (SAMS-PAP study). Mult Scler. 2021 Apr 23:13524585211010390. doi: 10.1177/13524585211010390. PMID: 33890515. Exclusion Code: X2.33890515
421 Khadadah SM, Trojan D, Duquette P, . Positive predictive value of the SAMSPAP (Sleep Apnea in Multiple Sclerosis Positive Airway Pressure) trial eligibility criteria for sleep apnea diagnosis. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X2.
422 Khalil W, Mansour W, Awad Allah M. Early variations in augmentation index and pulsed wave velocity in patients with obstructive sleep apnoea and arterial hypertension post CPAP treatment. Journal of Hypertension. 2017;35:e238. doi: 10.1097/01.hjh.0000523689.25064.88. Exclusion Code: X6.
423 Khalyfa A, Marin JM, Qiao Z, . Plasma exosomes in OSA patients promote endothelial senescence: effect of long-term adherent continuous positive airway pressure. Sleep. 2020;43(2)doi: 10.1093/sleep/zsz217. Exclusion Code: X6.
424 Khan SU, Duran CA, Rahman H, . A meta-analysis of continuous positive airway pressure therapy in prevention of cardiovascular events in patients with obstructive sleep apnoea. Eur Heart J. 2018 Jun 21;39(24):2291–7. doi: 10.1093/eurheartj/ehx597. PMID: 29069399. Exclusion Code: X8.29069399
425 Khazaie H, Jalali A, Cheraghi K, . Sleep problems among intravenous and non-intravenous opioid-dependent patients: the role of modality of use. Heroin Addiction and Related Clinical Problems. 2018;20(6):27–34. Exclusion Code: X2.
426 Khot SP, Barnett H, Siv J, . An intensive multidisciplinary protocol for improving adherence to CPAP therapy during inpatient rehabilitation may improve recovery in stroke patients. Stroke. 2018;49. Exclusion Code: X2.
427 Kim D, Shim CY, Cho IJ, . Effects of continuous positive airway pressure therapy on right ventricular function in patients with severe obstructive sleep apnea: Data from CPAP-oasis, a randomized, sham-controlled clinical trial. Circulation. 2017;136. Exclusion Code: X6.
428 Kim D, Shim CY, Cho YJ, . Continuous positive airway pressure therapy restores cardiac mechanical function in patients with severe obstructive sleep apnea: a randomized, sham-controlled study. J Am Soc Echocardiogr. 2019 Jul;32(7):826–35. doi: 10.1016/j.echo.2019.03.020. PMID: 31272592. Exclusion Code: X6.31272592
429 Kim D, Shim CY, Park S, . Effect of continuous positive airway pressure therapy on left ventricular diastolic function in patients with severe obstructive sleep apnea (CPAP-OASIS) assessed by tissue doppler, 2d speckle tracking and exercise hemodynamics: A randomized sham controlled clinical trial. Journal of the American Society of Echocardiography. 2017;30(6):B4. doi: 10.1016/j.echo.2017.04.007. Exclusion Code: X12.
430 Kim J, Mohler ER, Keenan BT, . Carotid artery wall thickness in obese and non-obese with obstructive sleep apnea before and following positive airway pressure treatment. Sleep. 2017;40:A193. Exclusion Code: X5.
431 Kim Y, Koo Y, Kim D, . Does treatment of SDB with CPAP have a protective effect on stroke? A systemic review. Sleep Medicine. 2015;16:S189. doi: 10.1016/j.sleep.2015.02.493. Exclusion Code: X8.
432 Kitamura T, Miyazaki S, Sulaiman HB, . Insomnia and obstructive sleep apnea as potential triggers of dementia: is personalized prediction and prevention of the pathological cascade applicable? EPMA J. 2020 Sep;11(3):355–65. doi: 10.1007/s13167-020-00219-w. PMID: 32849926. Exclusion Code: X6.32849926
433 Kline CE, Crowley EP, Ewing GB, . Blunted heart rate recovery is improved following exercise training in overweight adults with obstructive sleep apnea. Int J Cardiol. 2013 Aug 20;167(4):1610–5. doi: 10.1016/j.ijcard.2012.04.108. PMID: 22572632. Exclusion Code: X4.22572632
434 Kline CE, Ewing GB, Burch JB, . Exercise training improves selected aspects of daytime functioning in adults with obstructive sleep apnea. J Clin Sleep Med. 2012 Aug 15;8(4):357–65. doi: 10.5664/jcsm.2022. PMID: 22893765. Exclusion Code: X4.22893765
435 Korostovtseva LS, Zvartau NE, Rotar OP, . Predictors of heart rhythm disturbances in hypertensive obese patients with obstructive sleep apnea. Journal of Geriatric Cardiology. 2017;14(9):553–62. doi: 10.11909/j.issn.1671-5411.2017.09.010. Exclusion Code: X8.29144513
436 Kosky C, Ling I, McArdle N, . Which CPAP side effects are associated with CPAP non-acceptance? Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12765. Exclusion Code: X6.
437 Koutsourelakis I, Georgoulopoulos G, Perraki E, . Randomised trial of nasal surgery for fixed nasal obstruction in obstructive sleep apnoea. Eur Respir J. 2008 Jan;31(1):110–7. doi: 10.1183/09031936.00087607. PMID: 17898015. Exclusion Code: X4.17898015
438 Krakow B, McIver N, Ulibarri V. Positive airway pressure to treat co-morbid insomnia and sleep-disordered breathing: A rationale for advanced auto-adjusting dual pressure technology. Journal of Sleep Research. 2016;25:44. doi: 10.1111/jsr.12446. Exclusion Code: X5.
439 Kritikou I, Basta M, Vgontzas AN, . Sleep apnoea and the hypothalamic-pituitary-adrenal axis in men and women: effects of continuous positive airway pressure. Eur Respir J. 2016 Feb;47(2):531–40. doi: 10.1183/13993003.00319-2015. PMID: 26541531. Exclusion Code: X9.26541531
440 Krogager C, Banghøj A, Poulsen PL, . Effect of 12 weeks continuous positive airway pressure on day and night arterial stiffness in patients with type 2 diabetes and obstructive sleep apnoea, a randomised trial. Diabetologia. 2018;61:S556. doi: 10.1007/s00125-018-4693-0. Exclusion Code: X9.
441 Krogager C, Banghøj AM, Poulsen PL, . Effect of 12 weeks continuous positive airway pressure on day and night arterial stiffness and blood pressure in patients with type 2 diabetes and obstructive sleep apnea: A randomized controlled trial. J Sleep Res. 2020 Aug;29(4):e12978. doi: 10.1111/jsr.12978. PMID: 32166837. Exclusion Code: X9.32166837
442 Küchler G, Patzak A. Blood pressure behavior in OSA patients analysed before and during CPAP therapy using a continuous, non-invasive and cuff-less method. Journal of Sleep Research. 2016;25:356. doi: 10.1111/jsr.12446. Exclusion Code: X5.26809504
443 Kuhn E, Schwarz EI, Bratton DJ, . Effects of CPAP and mandibular advancement devices on health-related quality of life in OSA: a systematic review and meta-analysis. Chest. 2017 Apr;151(4):786–94. doi: 10.1016/j.chest.2017.01.020. PMID: 28130044. Exclusion Code: X8.28130044
444 Kuna ST, Reboussin DM, Borradaile KE, . Long-term effect of weight loss on obstructive sleep apnea severity in obese patients with type 2 diabetes. Sleep. 2013 May 1;36(5):641–9A. doi: 10.5665/sleep.2618. PMID: 23633746. Exclusion Code: X4.23633746
445 Kuna ST, Shuttleworth D, Chi L, . Web-based access to positive airway pressure usage with or without an initial financial incentive improves treatment use in patients with obstructive sleep apnea. Sleep. 2015 Aug 1;38(8):1229–36. doi: 10.5665/sleep.4898. PMID: 25581921. Exclusion Code: X4.25581921
446 Kuna ST, Townsend RR, Keenan B, . Blood pressure effects of positive airway pressure treatment in obese and non-obese adults with obstructive sleep apnea. Sleep. 2018;41:A195. Exclusion Code: X5.
447 Kundel V, Sahota A, Fayad Z, . Measuring carotid plaque inflammation in moderate to severe sleep apnea using hybrid positron emission tomography/magnetic resonance imaging (PET/MRI). American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X6.
448 Kunisaki KM, Bohn OA, Wetherbee EE, . High-resolution wrist-worn overnight oximetry has high positive predictive value for obstructive sleep apnea in a sleep study referral population. Sleep Breath. 2016 May;20(2):583–7. doi: 10.1007/s11325-015-1251-6. PMID: 26354105. Exclusion Code: X2.26354105
449 La Mantia I, Grillo C, Narelli S, . Monoblock and twinblock mandibular advancement devices in the treatment of obstructive sleep apnea. Journal of Clinical and Analytical Medicine. 2018;9(3)doi: 10.4328/JCAM.5659. Exclusion Code: X5.
450 Labarca G, Cruz R, Jorquera J. Continuous positive airway pressure in patients with obstructive sleep apnea and non-alcoholic steatohepatitis: a systematic review and meta-analysis. J Clin Sleep Med. 2018 Jan 15;14(1):133–9. doi: 10.5664/jcsm.6900. PMID: 29151428. Exclusion Code: X6.29151428
451 Labarca G, Dreyse J, Drake L, . Efficacy of continuous positive airway pressure (CPAP) in the prevention of cardiovascular events in patients with obstructive sleep apnea: systematic review and meta-analysis. Sleep Med Rev. 2020 Aug;52:101312. doi: 10.1016/j.smrv.2020.101312. PMID: 32248026. Exclusion Code: X8.32248026
452 Labarca G, Reyes T, Jorquera J, . CPAP in patients with obstructive sleep apnea and type 2 diabetes mellitus: systematic review and meta-analysis. Clin Respir J. 2018 Aug;12(8):2361–8. doi: 10.1111/crj.12915. PMID: 30073792. Exclusion Code: X6.30073792
453 Labarca G, Saavedra D, Dreyse J, . Efficacy of CPAP for Improvements in Sleepiness, Cognition, Mood, and Quality of Life in Elderly Patients With OSA: Systematic Review and Meta-analysis of Randomized Controlled Trials. Chest. 2020 Aug;158(2):751–64. doi: 10.1016/j.chest.2020.03.049. PMID: 32289311. Exclusion Code: X8.32289311
454 Labarca G, Valdivia G, Oñate A, . Prevalence of STOP BANG questionnaire and association with major cardiovascular events in hospitalized population: is it enough with currently used cardiovascular risk measurements? Sleep Med. 2019 Sep;61:82–7. doi: 10.1016/j.sleep.2019.02.019. PMID: 31416696. Exclusion Code: X6.31416696
455 Lai A, Fong D, Lam J, . Long-term efficacy of an education programme in improving adherence with continuous positive airway pressure treatment for obstructive sleep apnoea. Hong Kong Med J. 2017 Jun;23 Suppl 2(3):24–7. PMID: 29938667. Exclusion Code: X4.29938667
456 Lai A, Lam J, Fong D, . Long-term efficacy of motivational interviewing on improving continuous positive airway pressure adherence in obstructive sleep apnea: A randomized controlled trial. European Respiratory Journal. 2013;42. Exclusion Code: X4.
457 Lai S, Mordenti M, Mangiulli M, . Resistant hypertension and obstructive sleep apnea syndrome in therapy with continuous positive airway pressure: evaluation of blood pressure, cardiovascular risk markers and exercise tolerance. Eur Rev Med Pharmacol Sci. 2019 Nov;23(21):9612–24. doi: 10.26355/eurrev_201911_19455. PMID: 31773712. Exclusion Code: X5.31773712
458 Lajoie AC, Privé A, Roy-Hallé A, . Diagnosis and management of sleep apnea by a clinical nurse: a non-inferiority randomized clinical trial. J Clin Sleep Med. 2021 Jun 23doi: 10.5664/jcsm.9502. PMID: 34170235. Exclusion Code: X4.34170235
459 Lam JCM, Lai AYK, Tam TCC, . CPAP therapy for patients with sleep apnea and type 2 diabetes mellitus improves control of blood pressure. Sleep Breath. 2017 May;21(2):377–86. doi: 10.1007/s11325-016-1428-7. PMID: 27817148. Exclusion Code: X9.27817148
460 Lankford A, Muehlbach M, Donikyan M, . Automated graduated CPAP (AGPAP) for improved adherence in newly diagnosed OSA patients - Multicenter trial. Sleep. 2015;38:A178–A9. Exclusion Code: X5.
461 Larrateguy L, Pais C, Larrateguy S. New test to evaluate treatment of sleep apnea syndrome. Sleep Science. 2019;12:19–20. Exclusion Code: X4.
462 Larrateguy LD, Pais CM, Larrateguy LI, . Simplified sleep resistance test for daytime sleepiness detection. Sleep Science. 2021;14(2):164–8. doi: 10.5935/1984-0063.20200046. Exclusion Code: X3.34381580
463 Lee CF, Chen YJ, Huang WC, . CPAP pressure is associated with effect of mandibular advancement device for treating treatment-naïve patients with OSA. Respirology. 2018;23:37–8. doi: 10.1111/resp.13419_85. Exclusion Code: X5.
464 Lee EM, Lee TH, Park OL, . Effective continuous positive airway pressure changes related to sleep stage and body position in obstructive sleep apnea during upward and downward titration: An experimental study. Journal of Clinical Neurology (Korea). 2020;16(1):90–5. doi: 10.3988/jcn.2020.16.1.90. Exclusion Code: X6.
465 Lee P, Yu CW, Lin MT, . CPAP effects on leptin and visceral fat in patients with sleep apnea: double-blind, randomized, controlled trial. European Respiratory Journal. 2011;38. Exclusion Code: X6.
466 Lei Q, Lv Y, Li K, . Effects of continuous positive airway pressure on blood pressure in patients with resistant hypertension and obstructive sleep apnea: a systematic review and meta-analysis of six randomized controlled trials. J Bras Pneumol. 2017 Sep–Oct;43(5):373–9. doi: 10.1590/s1806-37562016000000190. PMID: 28767770. Exclusion Code: X2.28767770
467 Leigh R, Hamon SM, McWeeney M, . Male Pituitary-Gonadal Axis Function in Obstructive Sleep Apnoea Syndrome: The Effect of Continuous Positive Airway Pressure. Irish Journal of Medical Science. 2021;190(SUPPL 3):S108. doi: 10.1007/s11845-021-02557-8. Exclusion Code: X6.
468 Le-Ngoc A, Davidyock T, Mery V, . Effect of fixed versus auto-titrating continuous positive airway pressure on blood pressure and arterial stiffness in patients with resistant hypertension and obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2012;185. Exclusion Code: X5.
469 León Román F, Barbero E, Mañas E, . Mandibular advancement device for treatment of obstructive sleep apnea. Could it be an alternative in patients with CPAP intolerance? American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X5.
470 Li C, Wu ZH, Pan XL, . Effect of continuous positive airway pressure on gastroesophageal reflux in patients with obstructive sleep apnea: a meta-analysis. Sleep Breath. 2020 Oct 28doi: 10.1007/s11325-020-02224-9. PMID: 33118054. Exclusion Code: X8.33118054
471 Li WY, Series F, Tang X, . Differences in predicted therapeutic outcome and optimal protrusion position of oral appliance determined during remotely controlled mandibular position between Canadian and Chinese OSA patients. Respirology. 2017;22:148-. doi: 10.1111/resp.13207_173. Exclusion Code: X8.
472 Li X, Zhou X, Xu X, . Effects of continuous positive airway pressure treatment in obstructive sleep apnea patients with atrial fibrillation: A meta-analysis. Medicine (Baltimore). 2021 Apr 16;100(15):e25438. doi: 10.1097/md.0000000000025438. PMID: 33847645. Exclusion Code: X8.33847645
473 Liamsombut S, Kaw R, Wang L, . Predictive value of sleep apnea screenings in cardiac surgery patients. Sleep Med. 2021 Aug;84:20–5. doi: 10.1016/j.sleep.2021.05.007. PMID: 34090009. Exclusion Code: X7.34090009
474 Liao LJ, Cho TY, Cheng PW, . Submental ultrasonography in diagnosing severe obstructive sleep apnea syndrome. Journal of Medical Ultrasound. 2016;24(3):107–11. doi: 10.1016/j.jmu.2016.06.002. Exclusion Code: X3.
475 Libman E, Fichten C, Creti L, . Refreshing sleep and sleep continuity determine perceived sleep quality. Sleep Disorders. 2016;2016doi: 10.1155/2016/7170610. Exclusion Code: X6.
476 Lin G, Chen Q, Huang J, . Effect of continuous positive airway pressure on endothelin-1 in patients with obstructive sleep apnea: a meta-analysis. Eur Arch Otorhinolaryngol. 2019 Mar;276(3):623–30. doi: 10.1007/s00405-018-5225-8. PMID: 30511103. Exclusion Code: X6.30511103
477 Lin HJ, Yeh JH, Hsieh MT, . Continuous positive airway pressure with good adherence can reduce risk of stroke in patients with moderate to severe obstructive sleep apnea: An updated systematic review and meta-analysis. Sleep Med Rev. 2020 Dec;54:101354. doi: 10.1016/j.smrv.2020.101354. PMID: 32755811. Exclusion Code: X8.32755811
478 Lin MT, Lee PL, Yu CW, . The effect of continuous positive airway pressure treatment on abdominal adiposity in severe obstructive sleep apnea: Evidence from randomized, active controlled trials. Sleep. 2019;42:A215–A6. doi: 10.1093/sleep/zsz067.537. Exclusion Code: X6.
479 Lindley R. The sleep apnea cardiovascular endpoints (SAVE) study results-a trial of CPAP versus usual care in 2717 high cardiovascular risk patients with moderate-severe obstructive sleep apnea (OSA). International Journal of Stroke. 2016;11:20. doi: 10.1177/1747493016670567. Exclusion Code: X6.
480 Linssen B, Bergman E, Klarenbeek P, . Prevalence of obstructive sleep apnea at an outpatient memory clinic. Health Science Reports. 2021;4(1)doi: 10.1002/hsr2.228. Exclusion Code: X8.
481 Linz D, Kadhim K, Brooks AG, . Diagnostic accuracy of overnight oximetry for the diagnosis of sleep-disordered breathing in atrial fibrillation patients. Int J Cardiol. 2018 Dec 1;272:155–61. doi: 10.1016/j.ijcard.2018.07.124. PMID: 30057161. Exclusion Code: X3.30057161
482 Linz D, Loffler K, Sanders P, . Prognostic value of novel nocturnal oxygen saturation metrics in patients with obstructive sleep apnoea and high cardiovascular event risk. European Heart Journal. 2019;40:2637. doi: 10.1093/eurheartj/ehz745.0809. Exclusion Code: X5.
483 Linz D, Loffler KA, Sanders P, . Low Prognostic Value of Novel Nocturnal Metrics in Patients With OSA and High Cardiovascular Event Risk: Post Hoc Analyses of the SAVE Study. Chest. 2020 Dec;158(6):2621–31. doi: 10.1016/j.chest.2020.06.072. PMID: 32679239. Exclusion Code: X5.32679239
484 Liu H, Luo H, Wei J, . Continuous positive airway pressure and cardiovascular outcomes in obstructive sleep apnoea patients: A systematic review and meta-analysis of randomized controlled trials. International Journal of Clinical and Experimental Medicine. 2019;12(1):581–8. Exclusion Code: X8.
485 Liu L, Cao Q, Guo Z, . Continuous positive airway pressure in patients with obstructive sleep apnea and resistant hypertension: a meta-analysis of randomized controlled trials. J Clin Hypertens (Greenwich). 2016 Feb;18(2):153–8. doi: 10.1111/jch.12639. PMID: 26278919. Exclusion Code: X8.26278919
486 Liu T, Li W, Zhou H, . Verifying the relative efficacy between continuous positive airway pressure therapy and its alternatives for obstructive sleep apnea: a network meta-analysis. Front Neurol. 2017;8:289. doi: 10.3389/fneur.2017.00289. PMID: 28701992. Exclusion Code: X10.28701992
487 Loffler K, Heeley E, Freed R, . Effect of obstructive sleep apnea treatment on renal function in patients with cardiovascular disease. Journal of Sleep Research. 2017;26:17–8. doi: 10.1111/jsr.12618. Exclusion Code: X12.
488 Loffler K, McEvoy RD, Anderson C, . Long-term CPAP, weight and BMI in patients with OSA and cardiovascular disease: Data from save. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12765. Exclusion Code: X12.
489 Loffler KA, Heeley E, Freed R, . Effect of obstructive sleep apnea treatment on renal function in patients with cardiovascular disease. Am J Respir Crit Care Med. 2017 Dec 1;196(11):1456–62. doi: 10.1164/rccm.201703-0603OC. PMID: 28743190. Exclusion Code: X6.28743190
490 Loffler KA, Heeley E, Freed R, . Continuous positive airway pressure treatment, glycemia, and diabetes risk in obstructive sleep apnea and comorbid cardiovascular disease. Diabetes Care. 2020;43(8):1859–67. doi: 10.2337/dc19-1398. Exclusion Code: X9.32291275
491 Loffler KA, Heeley E, Freed R, . Continuous Positive Airway Pressure Treatment, Glycemia, and Diabetes Risk in Obstructive Sleep Apnea and Comorbid Cardiovascular Disease. Diabetes Care. 2020 Aug;43(8):1859–67. doi: 10.2337/dc19-2006. PMID: 32291275. Exclusion Code: X6.32291275
492 Long W, Zhao X, Yuan X, . Effect of continuous positive airway pressure on oxidative stress reaction and neurological function in patients of acute cerebral infarction combined with obstructive sleep apnea syndrome. Chinese Journal of Cerebrovascular Diseases. 2016;13(5):234–9. doi: 10.3969/j.issn.l672-5921.2016.05.003. Exclusion Code: X2.
493 López-López L, Torres-Sánchez I, Cabrera-Martos I, . Nursing interventions improve continuous positive airway pressure adherence in obstructive sleep apnea with excessive daytime sleepiness: a systematic review. Rehabil Nurs. 2020 May/Jun;45(3):140–6. doi: 10.1097/rnj.0000000000000190. PMID: 30461507. Exclusion Code: X4.30461507
494 Lopez-Padilla D, Cerezo Lajas A, Ramirez Garcia L, . Non-severe obstructive sleep apnea and cardiovascular events in the elderly: Is there a beneficial effect of long-term continuous positive airway pressure? American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.B98. Exclusion Code: X12.
495 Loredo JS, Ancoli-Israel S, Dimsdale JE. Effect of continuous positive airway pressure vs placebo continuous positive airway pressure on sleep quality in obstructive sleep apnea. Chest. 1999 Dec;116(6):1545–9. doi: 10.1378/chest.116.6.1545. PMID: 10593774. Exclusion Code: X9.10593774
496 Lu H, Fu C, Li W, . Screening for obstructive sleep apnea syndrome in asthma patients: a prospective study based on Berlin and STOP-Bang questionnaires. Journal of Thoracic Disease. 2017;9(7):1945–58. doi: 10.21037/jtd.2017.06.03. Exclusion Code: X10.28839993
497 Lu X, Wang X, Xu T, . Circulating C3 and glucose metabolism abnormalities in patients with OSAHS. Sleep Breath. 2018 May;22(2):345–51. doi: 10.1007/s11325-017-1564-8. PMID: 28884388. Exclusion Code: X3.28884388
498 Luangphiphat W, Aramsareewong T, Jeamanukoolkit A, . Prevalence of obstructive sleep apnea in thai patients with severe symptomatic aortic stenosis. Journal of the Medical Association of Thailand. 2021;104(7):S9–S14. doi: 10.35755/jmedassocthai.2021.S02.12571. Exclusion Code: X8.
499 Luyster F, Shi X, Atwood C, . Daytime sleepiness and physical activity in adults with type 2 diabetes and OSA treated with CPAP. Sleep. 2019;42:A214. doi: 10.1093/sleep/zsz067.534. Exclusion Code: X5.
500 Lyons MM, Kraemer JF, Dhingra R, . Screening for obstructive sleep apnea in commercial drivers using EKG-derived respiratory power index. J Clin Sleep Med. 2019 Jan 15;15(1):23–32. doi: 10.5664/jcsm.7562. PMID: 30621825. Exclusion Code: X5.30621825
501 Ma Z, Hyde P, Drinnan M, . Custom three-dimensional-printed CPAP mask development, preliminary comfort and fit evaluation. Journal of Medical Devices, Transactions of the ASME. 2021;15(2)doi: 10.1115/1.4050201. Exclusion Code: X8.
502 Magalhães MGS, Santos AMB, Teixeira JB, . Cardiovascular responses to six-minute walking and step tests in subjects with obstructive sleep apnea treated with continuous positive airway pressure. Sleep Science. 2019;12:43. Exclusion Code: X5.31105894
503 Magnusdottir S, Hilmisson H, Thomas RJ. Cardiopulmonary coupling-derived sleep quality is associated with improvements in blood pressure in patients with obstructive sleep apnea at high-cardiovascular risk. J Hypertens. 2020 Nov;38(11):2287–94. doi: 10.1097/hjh.0000000000002553. PMID: 32649638. Exclusion Code: X6.32649638
504 Mañas E, Barbero E, Chiluiza D, . Impact of obstructive sleep apnea on cardiovascular outcomes in patients with acute symptomatic pulmonary embolism: Rationale and methodology for the POPE study. Clin Cardiol. 2017 Dec;40(12):1182–8. doi: 10.1002/clc.22834. PMID: 29247523. Exclusion Code: X2.29247523
505 Mann J, Barnes M. Nasal CPAP versus sham CPAP in participants with metabolic syndrome and obstructive sleep apnoea. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12766. Exclusion Code: X12.
506 Manzar MD, Hameed UA, Alqahtani M, . Obstructive sleep apnea screening in young people: psychometric validation of a shortened version of the STOP-BANG questionnaire using categorical data methods. Ann Thorac Med. 2020 Oct–Dec;15(4):215–22. doi: 10.4103/atm.ATM_389_19. PMID: 33381236. Exclusion Code: X6.33381236
507 Marillier M, Gruet M, Baillieul S, . Impaired cerebral oxygenation and exercise tolerance in patients with severe obstructive sleep apnoea syndrome. European Respiratory Journal. 2018;52doi: 10.1183/13993003.congress-2018.OA480. Exclusion Code: X6.
508 Marin JM, Carrizo SJ, Vicente E, . Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lancet. 2005 Mar 19–25;365(9464):1046–53. doi: 10.1016/S0140-6736(05)71141-7. PMID: 15781100. Exclusion Code: X8.15781100
509 Marina M, Ariga P, Ganapathy DM, . Efficacy of two mandibular advancement appliances in the treatment of obstructive sleep apnea-hypopnea syndrome: A systematic review. Drug Invention Today. 2019;11(3):698–702. Exclusion Code: X8.
510 Marinheiro R, Parreira L, Amador P, . Should we also screen for obstructive sleep apnea in patients presenting with excessive supraventricular ectopic activity? European Heart Journal. 2019;40:2386. doi: 10.1093/eurheartj/ehz745.0640. Exclusion Code: X6.
511 Marinheiro R, Parreira LP, Amador P, . Should we also screen for obstructive sleep apnea in patients presenting with excessive supraventricular ectopic activity? Europace. 2019;21:ii414. Exclusion Code: X5.
512 Marshall NS, Wong KK, Cullen SR, . Sleep apnea and 20-year follow-up for all-cause mortality, stroke, and cancer incidence and mortality in the Busselton Health Study cohort. J Clin Sleep Med. 2014 Apr 15;10(4):355–62. doi: 10.5664/jcsm.3600. PMID: 24733978. Exclusion Code: X8.24733978
513 Marshall NS, Wong KK, Liu PY, . Sleep apnea as an independent risk factor for all-cause mortality: the Busselton Health Study. Sleep. 2008 Aug;31(8):1079–85. PMID: 18714779. Exclusion Code: X8.18714779
514 Martelly E, Rana S, Shimada K. Design and fabrication of custom-fit BiPAP and CPAP masks using three-dimensional imaging and three-dimensional printing techniques. Journal of Medical Devices, Transactions of the ASME. 2021;15(2)doi: 10.1115/1.4049981. Exclusion Code: X8.
515 Martinez Hurtado R, Valverde Rivera A, Lopez Martinez V, . Validation of a Spanish version of Karolinska Sleepinees Scale for Mexican population EKS-M. Sleep. 2018;41:A235. Exclusion Code: X2.
516 Martínez-Cerón E, Barquiel B, Bezos AM, . Effect of continuous positive airway pressure on glycemic control in patients with obstructive sleep apnea and type 2 diabetes. A randomized clinical trial. Am J Respir Crit Care Med. 2016 Aug 15;194(4):476–85. doi: 10.1164/rccm.201510-1942OC. PMID: 26910598. Exclusion Code: X6.26910598
517 Martinez-Garcia MA, Valero-Sánchez I, Reyes-Nuñez N, . Continuous positive airway pressure adherence declines with age in elderly obstructive sleep apnoea patients. ERJ Open Research. 2019;5(1)doi: 10.1183/23120541.00178-2018. Exclusion Code: X6.
518 Martins OFM, Chaves Junior CM, Rossi RRP, . Side effects of mandibular advancement splints for the treatment of snoring and obstructive sleep apnea: a systematic review. Dental Press J Orthod. 2018 Aug 1;23(4):45–54. doi: 10.1590/2177-6709.23.4.045-054.oar. PMID: 30304153. Exclusion Code: X6.30304153
519 Masa JF, Benítez ID, Sánchez-Quiroga MÁ, . Effectiveness of CPAP vs. Noninvasive Ventilation Based on Disease Severity in Obesity Hypoventilation Syndrome and Concomitant Severe Obstructive Sleep Apnea. Archivos de Bronconeumologia. 2021doi: 10.1016/j.arbres.2021.05.019. Exclusion Code: X14.
520 Masa JF, Corral J, Alonso M, . Efficacy of different treatment alternatives for obesity hypoventilation syndrome. American Journal of Respiratory and Critical Care Medicine. 2015;191. Exclusion Code: X12.
521 Masa JF, Corral J, Alonso ML, . Efficacy of different treatment alternatives por obesity hypoventilation syndrome. European Respiratory Journal. 2015;46doi: 10.1183/13993003.congress2015.OA1753. Exclusion Code: X12.
522 Masa JF, Corral J, Pereira R, . Effectiveness of home respiratory polygraphy for the diagnosis of sleep apnoea and hypopnoea syndrome. Thorax. 2011 Jul;66(7):567–73. doi: 10.1136/thx.2010.152272. PMID: 21602541. Exclusion Code: X3.21602541
523 Masa JF, Corral J, Pereira R, . Effectiveness of sequential automatic-manual home respiratory polygraphy scoring. Eur Respir J. 2013 Apr;41(4):879–87. doi: 10.1183/09031936.00186811. PMID: 22878873. Exclusion Code: X3.22878873
524 Masa JF, Mokhlesi B, Benítez I, . Long-term clinical effectiveness of continuous positive airway pressure therapy versus non-invasive ventilation therapy in patients with obesity hypoventilation syndrome: a multicentre, open-label, randomised controlled trial. Lancet. 2019 Apr 27;393(10182):1721–32. doi: 10.1016/s0140-6736(18)32978-7. PMID: 30935737. Exclusion Code: X5.30935737
525 Matsumoto H, Kasai T, Suda S, . Randomized controlled trial of an oral appliance (SomnoDent) for sleep-disordered breathing and cardiac function in patients with heart failure. Clin Cardiol. 2018 Aug;41(8):1009–12. doi: 10.1002/clc.23028. PMID: 30014565. Exclusion Code: X6.30014565
526 Matsumura Y, Ueda H, Nagasaki T, . Multislice computed tomography assessment of airway patency changes associated with mandibular advancement appliance therapy in supine patients with obstructive sleep apnea. Sleep Disorders. 2019;2019doi: 10.1155/2019/8509820. Exclusion Code: X5.
527 Matsuo A, Sonehara K. Effects of CPAP on clinic blood pressure in patients with obstructive sleep apnea: 10 years follow-up. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA2271. Exclusion Code: X8.
528 May AM, Gharibeh T, Strohl KP, . Adherence predictors of active and sham continuous positive airway pressure in a randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccmconference.2017.C80E. Exclusion Code: X6.
529 May AM, Gharibeh T, Wang L, . CPAP adherence predictors in a randomized trial of moderate-to-severe OSA enriched with women and minorities. Chest. 2018 Sep;154(3):567–78. doi: 10.1016/j.chest.2018.04.010. PMID: 29684316. Exclusion Code: X6.29684316
530 May AM, Wang L, Kwon DH, . Sleep apnea screening instrument evaluation and novel model development and validation in the paroxysmal atrial fibrillation population. Int J Cardiol Heart Vasc. 2020 Dec;31:100624. doi: 10.1016/j.ijcha.2020.100624. PMID: 33364332. Exclusion Code: X8.33364332
531 May AM, Wang L, Walia HK, . Sex-specific differences in systemic inflammation markers in response to obstructive sleep apnea treatment: The sleep apnea stress study randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X6.
532 McArdle N, King S, Shepherd K, . Study of a novel APAP algorithm for the treatment of obstructive sleep apnea in women. Sleep. 2015 Nov 1;38(11):1775–81. doi: 10.5665/sleep.5162. PMID: 26039968. Exclusion Code: X2.26039968
533 McArdle N, Walsh J, Robey E, . Effect of acute CPAP withdrawal on overnight blood pressure in OSA: a randomised controlled trial. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12766. Exclusion Code: X9.
534 McEvoy RD, Antic N, Heeley E, . The sleep apnea cardiovascular endpoints (SAVE) study results-a trial of CPAP versus usual care in 2717 high cardiovascular risk patients with moderate-severe obstructive sleep apnea (OSA). European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.OA1799. Exclusion Code: X6.
535 McEvoy RD, Antic NA, Heeley E, . CPAP for prevention of cardiovascular events in obstructive sleep apnea. N Engl J Med. 2016 Sep 8;375(10):919–31. doi: 10.1056/NEJMoa1606599. PMID: 27571048. Exclusion Code: X2.27571048
536 McLellan B, Skiba V, Novikova M, . Treatment of obstructive sleep apnea with positive airway pressure to improve cognitive function in mild cognitive impairment. Sleep. 2019;42:A383. doi: 10.1093/sleep/zsz067.951. Exclusion Code: X12.
537 McMillan A, Bratton DJ, Faria R, . A multicentre randomised controlled trial and economic evaluation of continuous positive airway pressure for the treatment of obstructive sleep apnoea syndrome in older people: PREDICT. Health Technol Assess. 2015 Jun;19(40):1–188. doi: 10.3310/hta19400. PMID: 26063688. Exclusion Code: X6.26063688
538 Medarov BI, Pluto LA, Fina L, . Assessing the reliability of obstructive sleep apnea screening instruments in isolation or in combination. Respiratory Medicine: X. 2020;2doi: 10.1016/j.yrmex.2020.100019. Exclusion Code: X2.
539 Mehrtash M, Peres BU, Allen AJH, . The rate of adherence of continuous positive airway pressure in patients with obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X6.
540 Mehta V, Wong J, Phillips B, . Oxygen therapy for OSA patients: a systematic review. Canadian Journal of Anesthesia. 2012;59doi: 10.1007/s12630-012-9785-6. Exclusion Code: X4.
541 Melehan KL, Hoyos CM, Hamilton GS, . Adherent CPAP improves erectile and sexual function and quality of life in men with OSA and erectile dysfunction (ED): A randomised sham controlled study. Endocrine Reviews. 2014;35. Exclusion Code: X12.
542 Mello-Fujita L, Jihe Kim L, Dumas Cintra F, . Safety and efficacy of 6-month use of sham-CPAP in obstructive sleep apnea patients. Sleep Medicine. 2017;40:e220. Exclusion Code: X6.
543 Mendelson M, Vivodtzev I, Taminiser R, . Continuous positive airway pressure (CPAP) supported by telemedicine improves sleepiness and quality of life but not blood pressure in high cardiovascular risk obstructive sleep apnea (OSA): A randomized, controlled trial. European Respiratory Journal. 2013;42. Exclusion Code: X4.
544 Mengar M, Chakrabarti S, Ish P, . A randomized controlled trial to study impact of continuous positive airway pressure on neurocognitive functions in obstructive sleep apnea patients. Lung India. 2019;36(9):S108. doi: 10.4103/0970-2113.271103. Exclusion Code: X12.
545 Mercieca L, Pullicino R, Camilleri K, . Continuous positive airway pressure: is it a route for infection in those with obstructive sleep apnoea? Sleep Science. 2017;10(1):28–34. doi: 10.5935/1984-0063.20170005. Exclusion Code: X8.28966735
546 Meskill GJ, Kincheloe K, Simmons JH, . Simmons Chin Press and Tongue Curl (SCPTC) maneuver is a reproducible objective physical exam finding to screen for obstructive sleep apnea (OSA) associated with cardiovascular morbidities and all-cause mortality. Sleep. 2018;41:A187. Exclusion Code: X3.
547 Meskill GJ, Simmons JH, Hua O, . Are we underselling positive airway pressure (PAP) compliance and confounding sleep research? large multi-center analysis shows PAP compliance data that is much higher than previously reported. Sleep. 2017;40:A197–A8. Exclusion Code: X6.
548 Messineo L, Taranto Montemurro L, Azarbarzin A, . Loop gain in REM versus non-REM sleep using CPAP manipulation. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X5.
549 Metz JE, Attarian HP, Harrison MC, . High-resolution pulse oximetry and titration of a mandibular advancement device for obstructive sleep apnea. Frontiers in Neurology. 2019;10(JUL)doi: 10.3389/fneur.2019.00757. Exclusion Code: X5.
550 Miao BF, Shen N, Xiao JH, . Curative effect of continuous positive airway pressure on treatment of patients with obstructive sleep apnea hypopnea syndrome and hypertension: a meta-analysis. Medical Journal of Chinese People’s Liberation Army. 2016;41(11):925–35. doi: 10.11855/j.issn.0577-7402.2016.11.09. Exclusion Code: X1.
551 Mihaicuta S, Topirceanu A, Udrescu L, . Assessing the predictive potential of neck circumference for diagnostic and CPAP treatment response in OSAS with network medicine. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X8.
552 Mihaicuta S, Udrescu L, Udrescu M, . Analyzing neck circumference as an indicator of CPAP treatment response in obstructive sleep apnea with network medicine. Diagnostics. 2021;11(1)doi: 10.3390/diagnostics11010086. Exclusion Code: X8.
553 Miller JN, Kupzyk KA, Zimmerman L, . Comparisons of measures used to screen for obstructive sleep apnea in patients referred to a sleep clinic. Sleep Med. 2018 Nov;51:15–21. doi: 10.1016/j.sleep.2018.06.007. PMID: 30077956. Exclusion Code: X2.30077956
554 Millington K, Dixon G, Grenville J, . Outcomes of diagnostic and therapeutic CPAP trials in the management of patients with suspected obstructive sleep apnoea. Thorax. 2021;76(SUPPL 1):A215. doi: 10.1136/thorax-2020-BTSabstracts.378. Exclusion Code: X8.
555 Mills PJ, Kennedy BP, Loredo JS, . Effects of nasal continuous positive airway pressure and oxygen supplementation on norepinephrine kinetics and cardiovascular responses in obstructive sleep apnea. J Appl Physiol (1985). 2006 Jan;100(1):343–8. doi: 10.1152/japplphysiol.00494.2005. PMID: 16357087. Exclusion Code: X9.16357087
556 Minami K, Kurobe M, Muto S, . Long-term effects of continuous positive airway pressure on all-cause mortality in patients with moderate to severe obstructive sleep apnoea and acute myocardial infarction. European Heart Journal. 2016;37:766. doi: 10.1093/eurheartj/ehw433. Exclusion Code: X2.
557 Mir S, Wong J, Ryan CM, . Concomitant benzodiazepine and opioids decrease sleep apnoea risk in chronic pain patients. ERJ Open Research. 2020;6(3):1–10. doi: 10.1183/23120541.00093-2020. Exclusion Code: X4.
558 Mittal R, Sen MK, Suri JC. A randomised controlled trial to study effect of continuous positive airway pressure on blood pressure in obstructive sleep apnoea patients. Lung India. 2019;36(9):S116. doi: 10.4103/0970-2113.271103. Exclusion Code: X12.
559 Mohamed Dameer A, Jackson M, Farouque O, . Examining the prevalence of obstructive sleep apnoea in a cardiology outpatient clinic population and towards a better screening tool for obstructive sleep apnoea in cardiology patients. Sleep Medicine. 2019;64:S262. doi: 10.1016/j.sleep.2019.11.733. Exclusion Code: X6.
560 Mohammadien HM, Saleh AEM, Esmaeel HM, . Quality of life, fatigue, anxiety and depression among Egyptian patients with obstructive sleep apnea. Egyptian Journal of Chest Diseases and Tuberculosis. 2019;68(3):296–302. doi: 10.4103/ejcdt.ejcdt_196_18. Exclusion Code: X8.
561 Mok Y, Melehan KL, Phillips CL, . Does CPAP treat depressive symptoms in individuals with OSA? An analysis of two 12-week randomized sham CPAP-controlled trials. Sleep Med. 2020 Sep;73:11–4. doi: 10.1016/j.sleep.2020.04.021. PMID: 32769027. Exclusion Code: X8.32769027
562 Mok Y, Tan A, Hsu PP, . Comparing treatment effects of a convenient vibratory positional device to CPAP in positional OSA: a crossover randomised controlled trial. Thorax. 2020 Apr;75(4):331–7. doi: 10.1136/thoraxjnl-2019-213547. PMID: 31896735. Exclusion Code: X5.31896735
563 Mokhlesi B, Grimaldi D, Beccuti G, . Impact of fully compliant CPAP treatment of obstructive sleep apnea on glycemic control in type 2 diabetes: A proof of concept clinical trial. American Journal of Respiratory and Critical Care Medicine. 2015;191. Exclusion Code: X6.
564 Molina LZ, Garcia MAM, Chiner E, . Obstructive sleep apnea (OSA) in elderly patients. Role of continuous positive airway pressure (CPAP) treatment. A multicenter randomized controlled clinical trial. European Respiratory Journal. 2014;44. Exclusion Code: X12.
565 Monegro AF, Sahota PK, Bollu PC, . Delta power in obstructive sleep apnea with predominant respiratory effort related arousals before and after therapy with continuous positive airway pressure. Sleep. 2019;42:A216–A7. doi: 10.1093/sleep/zsz067.540. Exclusion Code: X8.
566 Morariu EM, Chasens E, Strollo P, . Effect of continuous positive airway pressure (CPAP) on glycemic control and variability in type 2 diabetes (T2D). Diabetes. 2016;65:A235–A6. doi: 10.2337/db16-861-1374. Exclusion Code: X6.
567 Morillo DS, Gross N. Probabilistic neural network approach for the detection of SAHS from overnight pulse oximetry. Med Biol Eng Comput. 2013 Mar;51(3):305–15. doi: 10.1007/s11517-012-0995-4. PMID: 23160897. Exclusion Code: X3.23160897
568 Moss J, Tew GA, Copeland RJ, . Effects of a pragmatic lifestyle intervention for reducing body mass in obese adults with obstructive sleep apnoea: a randomised controlled trial. Biomed Res Int. 2014;2014:102164. doi: 10.1155/2014/102164. PMID: 25136550. Exclusion Code: X4.25136550
569 Mostafavi A, Aliabadi L, Sadeghniyat K, . Comparison of the efficacy of continuous positive airway pressure and oxygen therapy in increasing heart rate variability in patients with obstructive sleep apnea. Iranian Heart Journal. 2017;18(4):34–41. Exclusion Code: X5.
570 Moubarak G, Bouzeman A, de Geyer d’Orth T, . Variability in obstructive sleep apnea: analysis of pacemaker-detected respiratory disturbances. Heart Rhythm. 2017 Mar;14(3):359–64. doi: 10.1016/j.hrthm.2016.11.033. PMID: 27890735. Exclusion Code: X6.27890735
571 Mubashir T, Patra J, Abrahamyan L, . Continuous positive pressure therapy improves depressive symptoms in elderly individuals with obstructive sleep apnea: A systematic review and meta-analysis. Anesthesia and Analgesia. 2018;126(4):700. Exclusion Code: X8.
572 Mubashir T, Patra J, Wong J, . Neurocognitive functioning following CPAP treatment in elderly patients with obstructive sleep apnea: A meta-analysis of randomized controlled trials. Anesthesia and Analgesia. 2018;126(4):706. Exclusion Code: X8.
573 Munafo D, Hevener B, Hevener W, . Computational phenotyping in CPAP therapy: using interpretable physiology based machine learning models to predict therapeutic CPAP pressures. Sleep. 2019;42:A217. doi: 10.1093/sleep/zsz067.541. Exclusion Code: X6.
574 Muxfeldt ES, Margallo V, Costa LM, . Effects of continuous positive airway pressure treatment on clinic and ambulatory blood pressures in patients with obstructive sleep apnea and resistant hypertension: a randomized controlled trial. Hypertension. 2015 Apr;65(4):736–42. doi: 10.1161/hypertensionaha.114.04852. PMID: 25601933. Exclusion Code: X9.25601933
575 Myint WW, Sanda T, Thant YM, . The outcome of nasal stent versus continuous positive airway pressure in the treatment of patients with obstructive sleep apnoea. Respirology. 2019;24:206. doi: 10.1111/resp.13699. Exclusion Code: X5.
576 Myles H, Myles N, Coetzer CLC, . Cognition in schizophrenia improves with treatment of severe obstructive sleep apnoea: a pilot study. Schizophrenia Research: Cognition. 2019;15:14–20. doi: 10.1016/j.scog.2018.09.001. Exclusion Code: X5.30450286
577 Myllyla M, Hammais A, Stepanov M, . Cardiovascular events and mortality in CPAP adherent OSAS patients-a 9-year retrospective study. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA4717. Exclusion Code: X8.
578 Myllylä M, Hammais A, Stepanov M, . Nonfatal and fatal cardiovascular events in continuous positive airway pressure adherent obstructive sleep apnoea syndrome patients-a retrospective observational study. Journal of Sleep Research. 2018;27:43. doi: 10.1111/jsr.12751. Exclusion Code: X8.
579 Mysliwiec V, Matsangas P, Gill J, . A comparative analysis of sleep disordered breathing in active duty service members with and without combat-related posttraumatic stress disorder. J Clin Sleep Med. 2015 Dec 15;11(12):1393–401. doi: 10.5664/jcsm.5272. PMID: 26156954. Exclusion Code: X6.26156954
580 Naghan PA, Hassani S, Sadr M, . Sleep disorders and mental health in menopausal women in Tehran. Tanaffos. 2020;19(1):31–7. Exclusion Code: X8.33101429
581 Nakano H, Hayashi M, Ohshima E, . Relationship between sleep-disordered breathing and hypertension. Sleep and Biological Rhythms. 2003;1(2):115–6. doi: 10.1046/j.1446-9235.2003.00015.x. Exclusion Code: X8.
582 Nalliah C, Wong G, Lee G, . 005 Impact of continuous positive airway pressure on the atrial substrate in patients with obstructive sleep apnoea and atrial fibrillation: the SLEEP-AF Substrate Sub-Study. Heart Lung and Circulation. 2020;29:S39. doi: 10.1016/j.hlc.2020.09.012. Exclusion Code: X6.
583 Naqvi SU, Shahab A, Zia S, . Association of Mallampatti score as a risk factor for obstructive sleep apnea. Rawal Medical Journal. 2018;43(1):18–22. Exclusion Code: X5.
584 Nattusami L, Hadda V, Khilnani GC, . Co-existing obstructive sleep apnea among patients with chronic obstructive pulmonary disease. Lung India. 2021 Jan–Feb;38(1):12–7. doi: 10.4103/lungindia.lungindia_169_20. PMID: 33402632. Exclusion Code: X8.33402632
585 Navailles B, Kerbrat JB, Bonafe I, . Long-term tooth displacement in Obstructive Sleep Apnea (OSA) patients treated with custom-made mandibular repositioning device (MRD): Two year follow-up (FU) results of ORCADES study. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA4728. Exclusion Code: X5.
586 Navarro-Soriano C, Martínez-García MA, Torres G, . Effect of continuous positive airway pressure in patients with true refractory hypertension and sleep apnea: a post-hoc intention-to-treat analysis of the HIPARCO randomized clinical trial. J Hypertens. 2019 Jun;37(6):1269–75. doi: 10.1097/hjh.0000000000002053. PMID: 30676482. Exclusion Code: X6.30676482
587 Nerbass FB, Pedrosa RP, Ferreira Filho JA, . Acute effects of continuous positive airway pressure (CPAP)in hemodynamics and cardiac performance in patients with hypertrophic cardiomyopathy. American Journal of Respiratory and Critical Care Medicine. 2013;187. Exclusion Code: X10.
588 Nesmith BLW, Sherman M, Barak Y, . Treatment of obstructive sleep apnea with continuous positive airway pressure therapy improves functional and anatomical outcomes in exudative age related macular degeneration. Investigative Ophthalmology and Visual Science. 2015;56(7):3153. Exclusion Code: X12.
589 Newitt J, Strollo PJ, Balcan B, . The impact of rem-AHI on revascularized cardiac patients. Sleep. 2019;42:A231. doi: 10.1093/sleep/zsz067.579. Exclusion Code: X12.
590 Ng SS, Chan TO, Ngai J, . Randomised controlled trial of the effect of CPAP in uncontrolled nocturnal asthmatic patients with OSAS. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA4731. Exclusion Code: X2.
591 Ng SS, Chan TO, To KW, . Prevalence of obstructive sleep apnea syndrome and CPAP adherence in the elderly Chinese population. PLoS One. 2015;10(3):e0119829. doi: 10.1371/journal.pone.0119829. PMID: 25774657. Exclusion Code: X5.25774657
592 Ng SS, Liu EK, Ma RC, . Effects of CPAP therapy on visceral fat thickness, carotid intima-media thickness and adipokines in patients with obstructive sleep apnoea. Respirology. 2017 May;22(4):786–92. doi: 10.1111/resp.12963. PMID: 27933703. Exclusion Code: X6.27933703
593 Ng SS, Tam W, Chan TO, . Use of Berlin questionnaire in comparison to polysomnography and home sleep study in patients with obstructive sleep apnea. Respir Res. 2019 Feb 22;20(1):40. doi: 10.1186/s12931-019-1009-y. PMID: 30795760. Exclusion Code: X2.30795760
594 Ng SSS, Wong VWS, Wong GLH, . Continuous positive airway pressure does not improve nonalcoholic fatty liver disease in patients with obstructive sleep apnea. A randomized clinical trial. Am J Respir Crit Care Med. 2021 Feb 15;203(4):493–501. doi: 10.1164/rccm.202005-1868OC. PMID: 32926803. Exclusion Code: X5.32926803
595 Nicholl DD, Hanly P, Zalucky AA, . Sex differences in bioimpedance in humans with obstructive sleep apnea with normal kidney function before and after continuous positive airway pressure therapy. Journal of the American Society of Nephrology. 2019;30:313. Exclusion Code: X6.
596 Nieto FJ, Peppard PE, Young T, . Sleep-disordered breathing and cancer mortality: results from the Wisconsin Sleep Cohort Study. Am J Respir Crit Care Med. 2012 Jul 15;186(2):190–4. doi: 10.1164/rccm.201201-0130OC. PMID: 22610391. Exclusion Code: X8.22610391
597 Nigro CA, Borsini EE, Dibur E, . CPAP indication based on clinical data and oximetry for patients with suspicion of obstructive sleep apnea: A multicenter trial. Sleep Science. 2019;12:249–56. doi: 10.5935/1984-0063.20190089. Exclusion Code: X8.32318245
598 Nigro CA, Dibur E, Malnis S, . Validation of ApneaLink Ox^TM^ for the diagnosis of obstructive sleep apnea. Sleep Breath. 2013 Mar;17(1):259–66. doi: 10.1007/s11325-012-0684-4. PMID: 22447171. Exclusion Code: X3.22447171
599 Nigro CA, Serrano F, Aimaretti S, . Utility of ApneaLink for the diagnosis of sleep apnea-hypopnea syndrome. Medicina (B Aires). 2010;70(1):53–9. PMID: 20228025. Exclusion Code: X3.20228025
600 Nikolopoulou M, Byraki A, Ahlberg J, . Oral appliance therapy versus nasal continuous positive airway pressure in obstructive sleep apnoea syndrome: a randomised, placebo-controlled trial on self-reported symptoms of common sleep disorders and sleep-related problems. J Oral Rehabil. 2017 Jun;44(6):452–60. doi: 10.1111/joor.12505. PMID: 28294380. Exclusion Code: X6.28294380
601 Nilius G, Franke KJ, Domanski U, . Effect of APAP and heated humidification with a heated breathing tube on adherence, quality of life, and nasopharyngeal complaints. Sleep Breath. 2016 Mar;20(1):43–9. doi: 10.1007/s11325-015-1182-2. PMID: 25957615. Exclusion Code: X5.25957615
602 Ning Y, Zhang TS, Wen WW, . Effects of continuous positive airway pressure on cardiovascular biomarkers in patients with obstructive sleep apnea: a meta-analysis of randomized controlled trials. Sleep Breath. 2019 Mar;23(1):77–86. doi: 10.1007/s11325-018-1662-2. PMID: 29682699. Exclusion Code: X6.29682699
603 Norman D, Loredo JS, Nelesen RA, . Effects of continuous positive airway pressure versus supplemental oxygen on 24-hour ambulatory blood pressure. Hypertension. 2006 May;47(5):840–5. doi: 10.1161/01.HYP.0000217128.41284.78. PMID: 16585412. Exclusion Code: X9.16585412
604 Nowak M, Komand A, Ostrówka D, . Utility of polygraphic studies for sleep apnea screening in the setting of tertiary care hypertension outpatient clinic. Nadcisnienie Tetnicze. 2016;20(1):5–10. doi: 10.5603/AH.2016.0002. Exclusion Code: X6.
605 Ntafouli M, Steiropoulos P, Economou NT, . Phenotypes of objective cognitive impairment in patients with obstructive sleep apnea-hypopnea syndrome in the Maastricht attention and memory checklist. Sleep Medicine. 2017;40:e242–e3. Exclusion Code: X5.
606 O’Halloran D, O’Boyle C, Doherty L. Poor Sleep Associated with Clinically Severe Obesity Is Independent of OSA Status. Obesity Surgery. 2021doi: 10.1007/s11695-021-05588-3. Exclusion Code: X8.
607 Oh JH, Cho SJ, Kim WJ, . Insufficient sleep in tension-type headache: a population study. Journal of Clinical Neurology (Korea). 2018;14(4):566–73. doi: 10.3988/jcn.2018.14.4.566. Exclusion Code: X5.
608 Oksenberg A, Goizman V, Eitan E, . Do positional (PP) patients become non positional patients (NPP) over time? Sleep. 2017;40:A211. Exclusion Code: X2.
609 Oksenberg A, Goizman V, Eitan E, . How sleepy patients differ from non-sleepy patients in mild obstructive sleep apnea? Journal of Sleep Research. 2021doi: 10.1111/jsr.13431. Exclusion Code: X8.
610 Okuno K, Pliska BT, Hamoda M, . Prediction of oral appliance treatment outcomes in obstructive sleep apnea: a systematic review. Sleep Med Rev. 2016 Dec;30:25–33. doi: 10.1016/j.smrv.2015.11.007. PMID: 26773412. Exclusion Code: X8.26773412
611 Oldenburg O, Fox H, Wellmann B, . Automatic positive airway pressure for treatment of obstructive sleep apnea in heart failure: Design, rationale, and insights from the APAP randomized controlled trial. Somnologie. 2017;21(4):273–80. doi: 10.1007/s11818-017-0124-6. Exclusion Code: X6.
612 Oleynikov V, Burko N, Salyamova L, . Influence of CPAP therapy on endothelial function in patients with type 2 diabetes according to flow-mediated vasodilation. Journal of Hypertension. 2017;35:e234–e5. doi: 10.1097/01.hjh.0000523676.56451.0a. Exclusion Code: X6.
613 Oleynikov VE, Burko NV, Salyamova LI, . Effect of obstructive sleep apnea syndrome on arterial stiffness in patients at high cardiovascular risk. Rational Pharmacotherapy in Cardiology. 2016;12(3):272–6. doi: 10.20996/1819-6446-2016-12-3-272-276. Exclusion Code: X1.
614 Ong JC, Crawford MR, Dawson SC, . A randomized controlled trial of CBT-I and PAP for obstructive sleep apnea and comorbid insomnia: main outcomes from the MATRICS study. Sleep. 2020 Sep 14;43(9)doi: 10.1093/sleep/zsaa041. PMID: 32170307. Exclusion Code: X5.32170307
615 Ononye T, Nguyen K, Brewer E. Implementing protocol for obstructive sleep apnea screening in the primary care setting. Appl Nurs Res. 2019 Apr;46:67–71. doi: 10.1016/j.apnr.2019.02.005. PMID: 30853078. Exclusion Code: X8.30853078
616 Orbea CAP, Lloyd RM, Faubion SS, . Predictive ability and reliability of the STOP-BANG questionnaire in screening for obstructive sleep apnea in midlife women. Maturitas. 2020 May;135:1–5. doi: 10.1016/j.maturitas.2020.02.004. PMID: 32252960. Exclusion Code: X8.32252960
617 Ornelas C, Carreiro A, Domingos A, . Relationship between obstructive lung diseases and obstructive sleep apnea syndrome. Revista Portuguesa de Imunoalergologia. 2019;27(2):115–25. doi: 10.32932/rpia.2019.03.009. Exclusion Code: X1.
618 Ostrówka D, Nowak M, Komand A, . Impact of short-term CPAP treatment on day-and nighttime activity in obstructive sleep apnea hypertensive patients. Journal of Hypertension. 2017;35:e234. doi: 10.1097/01.hjh.0000523675.79322.46. Exclusion Code: X6.
619 O’Sullivan C, Kendrick A. Comparison of auto-titrating CPAP derived apnoeahypopnoea index (AHI) with pulse oximeter oxygen desaturation index (ODI) in patients with obstructive sleep apnoea (OSA). European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA3626. Exclusion Code: X5.
620 Ou Q, Chen B, Loffler KA, . The effects of long-term CPAP on weight change in patients with comorbid OSA and cardiovascular disease: data from the SAVE Trial. Chest. 2019 Apr;155(4):720–9. doi: 10.1016/j.chest.2018.08.1082. PMID: 30268694. Exclusion Code: X6.30268694
621 Ou Q, Pan M, Chen B. High risk and low treatment response in obstructive sleep apnea: a real-world study in office occupational population. Journal of Sleep Research. 2018;27:152. doi: 10.1111/jsr.12751. Exclusion Code: X5.
622 Özkurt ZG, Demir M, Yıldırım Y, . Evaluation of subclinical papilledema in patients with obstructive sleep apnea syndrome. Eastern Journal of Medicine. 2019;24(1):74–9. doi: 10.5505/ejm.2019.46036. Exclusion Code: X6.
623 Palm A, Berne C, Igelstrom H, . The impact of CPAP on circulating IGF-1 in patients with OSAS. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA3421. Exclusion Code: X6.
624 Pamidi S, Chapotot F, Wroblewski K, . Optimal Continuous Positive Airway Pressure Treatment of Obstructive Sleep Apnea Reduces Daytime Resting Heart Rate in Prediabetes: A Randomized Controlled Study. J Am Heart Assoc. 2020 Oct 20;9(19):e016871. doi: 10.1161/jaha.120.016871. PMID: 32998624. Exclusion Code: X6.32998624
625 Pamidi S, Stepien M, Sharif-Sidi K, . Effective treatment of obstructive sleep apnea improves glucose tolerance in prediabetes: a randomized placebo-controlled study. American Journal of Respiratory and Critical Care Medicine. 2013;187. Exclusion Code: X7.
626 Pamidi S, Wroblewski K, Stepien M, . Eight hours of nightly continuous positive airway pressure treatment of obstructive sleep apnea improves glucose metabolism in patients with prediabetes. A randomized controlled trial. Am J Respir Crit Care Med. 2015 Jul 1;192(1):96–105. doi: 10.1164/rccm.201408-1564OC. PMID: 25897569. Exclusion Code: X9.25897569
627 Pangerc A, Petek Šter M, Dolenc Grošelj L. Translation and validation of the STOP-Bang questionnaire into Slovene. Eur J Med Res. 2021 Apr 7;26(1):32. doi: 10.1186/s40001-021-00503-z. PMID: 33827701. Exclusion Code: X2.33827701
628 Panjapornpon K, Sangsayunh P, Bangpattanasiri K, . Effect of Continuous Positive Airway Pressure (CPAP) on High-Sensitivity C-Reactive Protein levels (hs-CRP) in patients with Obstructive Sleep Apnea (OSA). European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA2274. Exclusion Code: X8.
629 Panza G, Alex R, Hakim H, . Mild intermittent hypoxia and its multipronged effect on obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X4.
630 Parasram M, Segal AZ. Sleep disorders and stroke: Does treatment of obstructive sleep apnea decrease risk of ischemic stroke? Curr Treat Options Neurol. 2019 Jun 24;21(7):29. doi: 10.1007/s11940-019-0575-0. PMID: 31231783. Exclusion Code: X8.31231783
631 Parisot J, Damy T, Gellen B, . Sleep-disordered breathing in chronic heart failure: development and validation of a clinical screening score. Sleep Med. 2015 Sep;16(9):1094–101. doi: 10.1016/j.sleep.2014.11.022. PMID: 26298785. Exclusion Code: X5.26298785
632 Park HJ, Park JH, Park NC. Effects of testosterone therapy on hypogonadal patients with obstructive sleep apnea syndrome: an open label randomized consecutive study. European Urology Open Science. 2020;19:e133. doi: 10.1016/S2666-1683(20)32632-X. Exclusion Code: X6.
633 Park JH, Kang JH, Kim SD, . Comparative analysis of automatic versus fixed positive airway pressure therapy for severe obstructive sleep apnea. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X5.
634 Park KM, Shin KJ, Ha SY, . Risk factors for obstructive sleep apnea in non-obese Korean patients: significance of body weight. Sleep and Biological Rhythms. 2014;12(3):162–8. doi: 10.1111/sbr.12053. Exclusion Code: X8.
635 Parsons C, Allen S, Parish J, . The efficacy of continuous positive airway pressure therapy in reducing cardiovascular events in obstructive sleep apnea: a systematic review. Future Cardiol. 2017 Jul;13(4):397–412. doi: 10.2217/fca-2017-0004. PMID: 28631492. Exclusion Code: X8.28631492
636 Pascual M, de Batlle J, Barbé F, . Erectile dysfunction in obstructive sleep apnea patients: a randomized trial on the effects of Continuous Positive Airway Pressure (CPAP). PLoS One. 2018;13(8):e0201930. doi: 10.1371/journal.pone.0201930. PMID: 30089160. Exclusion Code: X6.30089160
637 Pastore AL, Palleschi G, Silvestri L, . Severe obstructive sleep apnea syndrome and erectile dysfunction: a prospective randomised study to compare sildenafil versus nasal continuous positive airway pressure. Journal of Sexual Medicine. 2015;12:193. Exclusion Code: X5.
638 Pastore AL, Palleschi G, Silvestri L, . Severe obstructive sleep apnoea syndrome and erectile dysfunction: a prospective randomised study to compare sildenafil vs. Nasal continuous positive airway pressure. Journal of Urology. 2015;193(4):e906. Exclusion Code: X5.
639 Pataka A, Kalamaras G, Vlachogianni E, . Combination of oximetry and sleep questionnaires as screening tools for CPAP initiation in patients with obstructive sleep apnea. Pulmonology. 2019 May–Jun;25(3):137–42. doi: 10.1016/j.pulmoe.2018.10.004. PMID: 30477955. Exclusion Code: X2.30477955
640 Pataka A, Kotoulas S, Kalamaras G, . Gender differences in obstructive sleep apnea: the value of sleep questionnaires with a separate analysis of cardiovascular patients. Journal of Clinical Medicine. 2020;9(1)doi: 10.3390/jcm9010130. Exclusion Code: X2.
641 Pataka A, Zarogoulidis P, Hohenforst-Schmidt W, . During economic crisis can sleep questionnaires improve the value of oximetry for assessing sleep apnea? Ann Transl Med. 2016 Nov;4(22):443. doi: 10.21037/atm.2016.11.06. PMID: 27999777. Exclusion Code: X2.27999777
642 Patel S, Kon SSC, Nolan CM, . Minimum clinically important difference of the Epworth Sleepiness Scale. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA330. Exclusion Code: X12.
643 Patel S, Rinchuse D, Zullo T, . Long-term dental and skeletal effects of mandibular advancement devices in adults with obstructive sleep apnoea: A systematic review. Int Orthod. 2019 Mar;17(1):3–11. doi: 10.1016/j.ortho.2019.01.004. PMID: 30770329. Exclusion Code: X8.30770329
644 Patel SI, Vasquez M, Guerra S, . Treatment of sleep disordered breathing with positive airway pressure therapy reduces the number of hospitalizations in a large cohort of patients with heart failure. Circulation. 2019;140doi: 10.1161/circ.140.suppl_1.16472. Exclusion Code: X8.
645 Patel SI, Vasquez M, Huang F, . Positive airway pressure therapy to treat sleep disordered breathing impacts number of hospitalizations in patients with heart failure. Sleep. 2020;43(SUPPL 1):A267. doi: 10.1093/sleep/zsaa056.697. Exclusion Code: X8.
646 Patil SP, Ayappa IA, Caples SM, . Treatment of adult obstructive sleep apnea with positive airway pressure: an American Academy of Sleep Medicine clinical practice guideline. J Clin Sleep Med. 2019 Feb 15;15(2):335–43. doi: 10.5664/jcsm.7640. PMID: 30736887. Exclusion Code: X8.30736887
647 Patil SS. Preferred Mode of Ventilation in OSA Patients. American Journal of Respiratory and Critical Care Medicine. 2021;203(9)doi: 10.1164/ajrccm-conference.2021.TP134. Exclusion Code: X5.
648 Pattison E, Barnes M, Tolson J, . Emotional regulation in obstructive sleep apnoea before and after treatment with continuous positive airway pressure. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12766. Exclusion Code: X5.
649 Paulauskaite E, Vaitukaitiene G, Miliauskas S. The antihypertensive effect of continuous positive airway pressure therapy for patients with obstructive sleep apnea and resistant hypertension: telephone survey. Journal of Sleep Research. 2018;27:338. doi: 10.1111/jsr.12751. Exclusion Code: X8.
650 Pavarangkul T, Jungtrakul T, Chaobangprom P, . The STOP-BANG questionnaire as a screening tool for obstructive sleep apnea-induced hypertension in Asian population. Neurology International. 2016;8(1):9–11. doi: 10.4081/ni.2016.6104. Exclusion Code: X10.
651 Pawar KS, Goyal A, Khurana A, . Correlation of various anthropometric and craniofacial variables with severity of obstructive sleep apnea in Indian population. Sleep and Vigilance. 2018;2(2):127–33. doi: 10.1007/s41782-018-0045-x. Exclusion Code: X8.
652 Paz CP, Fouz-Roson N, Almadana-Pacheco V, . Effects of CPAP treatment on anxiety and depression in patients with OSAS. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA2273. Exclusion Code: X5.
653 Paz YMHL, Hazen SL, Tracy RP, . Effect of continuous positive airway pressure on cardiovascular biomarkers: the Sleep Apnea Stress Randomized Controlled Trial. Chest. 2016 Jul;150(1):80–90. doi: 10.1016/j.chest.2016.03.002. PMID: 26997243. Exclusion Code: X9.26997243
654 Pecotic R, Dodig IP, Valic M, . Effects of CPAP therapy on cognitive and psychomotor performances in patients with severe obstructive sleep apnea: a prospective 1-year study. Sleep Breath. 2019 Mar;23(1):41–8. doi: 10.1007/s11325-018-1642-6. PMID: 29453638. Exclusion Code: X5.29453638
655 Pedrosa RP, Drager LF, De Paula LKG, . Effects of treatment of obstructive sleep apnea with CPAP in patients with resistant hypertension: a randomized trial. American Journal of Respiratory and Critical Care Medicine. 2012;185. Exclusion Code: X12.
656 Peker Y, Balcan B, Thunstrom E. Impact of cpap treatment on depression in patients with coronary artery disease and nonsleepy obstructive sleep apnea: The RICCADSA randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. 2018;197(Meeting Abstracts). Exclusion Code: X12.
657 Peker Y, Balcan B, Yucel-Lindberg T, . Impact of CPAP treatment on leptin and adiponectin in coronary artery disease and nonsleepy obstructive sleep apnea-a secondary analysis of the RICCADSA trial. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X6.
658 Peker Y, Glantz H, Thunstrom E, . Cardiac function in a revascularized coronary artery disease cohort with obstructive sleep apnoea with and without daytime sleepiness in the RICCADSA trial. European Respiratory Journal. 2011;38. Exclusion Code: X6.
659 Peker Y, Glantz H, Thunström E, . Effect of positive airway pressure on diastolic function in coronary artery disease patients with non-sleepy obstructive sleep apnea. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.OA1806. Exclusion Code: X6.
660 Peker Y, Glantz H, Yucel-Lindberg T, . CPAP does not reduce inflammatory biomarkers in coronary artery disease patients with nonsleepy obstructive sleep apnoea: A randomized controlled trial. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA4718. Exclusion Code: X6.
661 Peker Y, Thunström E, Glantz H, . Effect of obstructive sleep apnea and CPAP treatment on cardiovascular outcomes in acute coronary syndrome in the RICCADSA trial. Journal of Clinical Medicine. 2020;9(12):1–12. doi: 10.3390/jcm9124051. Exclusion Code: X2.
662 Peker Y, Thunström E, Glantz H, . Effect of CPAP treatment on cardiovascular outcomes in adults with acute coronary syndrome and nonsleepy obstructive sleep apnoea: A secondary analysis of the RICCADSA trial. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X12.
663 Pencheva V, Manov E, Petrova D, . Risk factors for paroxysmal AF in patients with OSA. General Medicine. 2019;21(2):11–5. Exclusion Code: X8.
664 Peng M, Chen R, Cheng J, . Application value of the NoSAS score for screening sleep-disordered breathing. Journal of Thoracic Disease. 2018;10(8):4774–81. doi: 10.21037/jtd.2018.07.46. Exclusion Code: X8.30233849
665 Pengo M, Soranna D, Giontella A, . Blood pressure effects of obstructive sleep apnea treatment by continuous positive airway pressure: systematic review, metaanalysis and evaluation of phenotypes predicting response. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA4149. Exclusion Code: X12.
666 Pengo M, Soranna D, Giontella A, . Blood pressure effects of obstructive sleep apnea treatment by continuous positive airway pressure: systematic review, metaanalysis and evaluation of phenotypes predicting response. Journal of Hypertension. 2019;37:e40–e1. Exclusion Code: X12.
667 Pengo MF, Soranna D, Giontella A, . Obstructive sleep apnoea treatment and blood pressure: which phenotypes predict a response? A systematic review and meta-analysis. Eur Respir J. 2020 May;55(5)doi: 10.1183/13993003.01945-2019. PMID: 32079643. Exclusion Code: X12.32079643
668 Pepin JL, Baguet JP, Tamisier R, . Fixed pressure (FP) versus auto-adjusting continuous positive airway pressure (autoCPAP): comparison of efficacy in reducing blood pressure, a randomized controlled trial. European Respiratory Journal. 2013;42. Exclusion Code: X5.
669 Pepin JL, Baillieul S, Tamisier R, . Eight weeks of continuous positive airway pressure treatment reverses gait control impairments in severe obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.B80-I. Exclusion Code: X6.
670 Pepin JL, Joyeux-Faure M, Baguet JP, . Continuous positive airway pressure efficiency in apneic patients with resistant hypertension: Results from the randomized controlled RHOOSAS study. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.B80-G. Exclusion Code: X6.
671 Pepin JL, Joyeux-Faure M, Naegele B, . CPAP impact on memory processes in OSA patients, a randomized sham controlled trial. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA3422. Exclusion Code: X6.
672 Pereira EJ, Driver HS, Stewart SC, . Comparing a combination of validated questionnaires and level III portable monitor with polysomnography to diagnose and exclude sleep apnea. J Clin Sleep Med. 2013 Dec 15;9(12):1259–66. doi: 10.5664/jcsm.3264. PMID: 24340287. Exclusion Code: X3.24340287
673 Perez-Cabezas V, Ruiz-Molinero C, Jimenez-Rejano JJ, . Continuous positive airway pressure treatment in patients with Alzheimer’s Disease: a systematic review. J Clin Med. 2020 Jan 9;9(1)doi: 10.3390/jcm9010181. PMID: 31936521. Exclusion Code: X2.31936521
674 Perticone M, Maio R, Scarpino PE, . Continuous Positive Airway Pressure Improves Renal Function in Obese Patients With Obstructive Sleep Apnea Syndrome. Frontiers in Medicine. 2021;8doi: 10.3389/fmed.2021.642086. Exclusion Code: X5.
675 Peto N, Seres T, Szakács Z, . Evaluation of the Brussells Questionnaire as a screening tool for obstructive sleep apnea syndrome. New Medicine. 2017;21(1):3–7. doi: 10.5604/01.3001.0009.7834. Exclusion Code: X2.
676 Petousi N, Turnbull CD, Sen D, . Effects of overnight supplemental oxygen on morning blood pressure in a randomized controlled CPAP withdrawal trial in patients with OSA. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X4.
677 Pevzner AV, Bayrambekov ES, Litvin AY, . Results of continuous positive upper airway pressure treatment in patients with atrial fibrillation and obstructive sleep apnea. Russian Journal of Cardiology. 2017;147(7):111–6. doi: 10.15829/1560-4071-2017-7-111-116. Exclusion Code: X5.
678 Philip P, Bailly S, Benmerad M, . Self-reported sleepiness and not the apnoea hypopnoea index is the best predictor of sleepiness-related accidents in obstructive sleep apnoea. Sci Rep. 2020 Oct 1;10(1):16267. doi: 10.1038/s41598-020-72430-8. PMID: 33004829. Exclusion Code: X2.33004829
679 Pivetta B, Chen L, Nagappa M, . Use and performance of the STOP-Bang Questionnaire for Obstructive Sleep Apnea Screening across geographic regions: a systematic review and meta-analysis. JAMA Netw Open. 2021 Mar 1;4(3):e211009. doi: 10.1001/jamanetworkopen.2021.1009. PMID: 33683333. Exclusion Code: X8.33683333
680 Polesel DN, Nozoe KT, Tufik SB, . Gender differences in the application of anthropometric measures for evaluation of obstructive sleep apnea. Sleep Science. 2019;12(1):2–9. doi: 10.5935/1984-0063.20190048. Exclusion Code: X10.31105888
681 Portela Ferreño I, Gonzalvez Rey J, Piñeiro Lopez A, . Changes in anxiety and depression levels in couples of patients with sleep apnea after one year of CPAP therapy. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X5.
682 Poupard L, Philippe C, Goldman MD, . Novel mathematical processing method of nocturnal oximetry for screening patients with suspected sleep apnoea syndrome. Sleep Breath. 2012 Jun;16(2):419–25. doi: 10.1007/s11325-011-0518-9. PMID: 21494850. Exclusion Code: X3.21494850
683 Prabha N, Bazzaz O, Patel M. Using the “stop-bang” questionnaire in recognition of obstructive sleep apnea in resident continuity clinic. Sleep. 2018;41:A190. Exclusion Code: X12.
684 Pradeepan S, Hensley M, Samuel S, . Fixed versus automatic positive airway pressure therapy for positional obstructive sleep apnoea-a double-blind, randomised trial. Journal of Sleep Research. 2017;26:69–70. doi: 10.1111/jsr.12619. Exclusion Code: X5.
685 Pradeepan S, Yates N, Suthers B, . Fixed versus automatic positive airway pressure therapy for positional obstructive sleep apnoea-a double-blind, randomised trial. Sleep. 2018;41:A209–A10. Exclusion Code: X5.
686 Prasad B, Imayama I, Ahmed K, . Obstructive sleep apnea and positive airway pressure therapy use are not associated with mortality in veterans with lung cancer. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X8.
687 Praveena C, Cruise A, Butt T. Can we improve Epworth Sleepiness Scale with an additional question. Sleep and Breathing. 2018;22(3):872. doi: 10.1007/s11325-018-1692-9. Exclusion Code: X6.
688 Prikladnicki A, Martinez D, Brunetto MG, . Diagnostic performance of cheeks appearance in sleep apnea. Cranio. 2018 Jul;36(4):214–21. doi: 10.1080/08869634.2017.1376426. PMID: 28933667. Exclusion Code: X3.28933667
689 Promislow S, Burwash IG, Leech J, . The effect of continuous positive airway pressure on RV function in patients with CHF and OSA: a randomized control trial. Canadian Journal of Cardiology. 2015;31(10):S203. Exclusion Code: X6.
690 Protas M, Omer D, Omer D, . A review of obstructive sleep apnea in relation to the associated biomarkers and the impact of CPAP treatment on them. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X8.
691 Punjabi NM, Caffo BS, Goodwin JL, . Sleep-disordered breathing and mortality: a prospective cohort study. PLoS Med. 2009 Aug;6(8):e1000132. doi: 10.1371/journal.pmed.1000132. PMID: 19688045. Exclusion Code: X8.19688045
692 Pyun SY, Choi SJ, Jo H, . Gender Differences in Korean Patients with Obstructive Sleep Apnea. Sleep Medicine Research. 2020;11(2):121–8. doi: 10.17241/SMR.2020.00556. Exclusion Code: X8.
693 Qi JC, Zhang L, Li H, . Impact of continuous positive airway pressure on vascular endothelial growth factor in patients with obstructive sleep apnea: a meta-analysis. Sleep Breath. 2019 Mar;23(1):5–12. doi: 10.1007/s11325-018-1660-4. PMID: 29671205. Exclusion Code: X6.29671205
694 Quaranta V, Dragonieri S, Carratù P, . A new approach for the assessment of sleepiness and predictivity of obstructive sleep apnea in drivers: A pilot study. Lung India. 2016;33(1):14–9. doi: 10.4103/0970-2113.173061. Exclusion Code: X2.26933301
695 Quintos A, Mukhtar U, Niroula A, . Screening and evaluation of sleep disordered breathing in hospitalized patients (hosmed registry). American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccmconference.2017.C110. Exclusion Code: X8.
696 Quintos AP, Rives-Sanchez M, Niroula A, . The effect of inpatient screening and treatment for sleep disordered breathing on re-admissions in minority ethnic population: A health disparity project. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X8.
697 Quiroga MAS, Jiménez JFM, Illa FB, . Efficacy and cost-effectiveness of home respiratory polygraphy. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.OA4797. Exclusion Code: X5.
698 Quiroga MAS, Jiménez JFM, Mokhlesi B, . The Pickwick randomized clinical trial: long-term positive airway pressure therapy in obesity hypoventilation syndrome. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA2015. Exclusion Code: X2.
699 Quiroga MAS, Mogollon MV, De Terreros JG, . Echocardiographic changes with positive airway pressure in obesity hypoventilation syndrome. Pickwick study. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA4730. Exclusion Code: X6.
700 Qureshi WT, Nasir UB, Alqalyoobi S, . Meta-analysis of continuous positive airway pressure as a therapy of atrial fibrillation in obstructive sleep apnea. Am J Cardiol. 2015 Dec 1;116(11):1767–73. doi: 10.1016/j.amjcard.2015.08.046. PMID: 26482182. Exclusion Code: X6.26482182
701 Rahnama’i M, Degaillier S, Ewoldt T, . Reduction of nocturia in patients treated with C-pap for obstructive sleep apnea syndrome. Neurourology and Urodynamics. 2016;35:S35–S6. doi: 10.1002/nau.23074. Exclusion Code: X6.
702 Rajabalan A, Shahi D, Paudel SD, . Effects of CPAP on cardiovascular outcomes in patients with obstructive sleep apnea: a pooled meta-analysis of randomized controlled trials. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.B98. Exclusion Code: X8.
703 Rajeswari J, Jagannath M. Screening of obstructive sleep apnea in an urban population in south India. Obesity Medicine. 2020;18doi: 10.1016/j.obmed.2020.100220. Exclusion Code: X5.
704 Randerath WJ. New ventilator support in complex phenotypes: coexisting CSA and OSA. ERS Monograph. 2015;2015(9781849840606):266–77. doi: 10.1183/2312508X.10006514. Exclusion Code: X2.
705 Randerath WJ, Herkenrath S, Treml M, . Evaluation of a multicomponent grading system for obstructive sleep apnoea: The Baveno classification. ERJ Open Research. 2021;7(1)doi: 10.1183/23120541.00928-2020. Exclusion Code: X8.
706 Rebelo-Marques A, Vicente C, Valentim B, . STOP-Bang questionnaire: the validation of a Portuguese version as a screening tool for obstructive sleep apnea (OSA) in primary care. Sleep Breath. 2018 Sep;22(3):757–65. doi: 10.1007/s11325-017-1608-0. PMID: 29285601. Exclusion Code: X2.29285601
707 Recoquillon S, Pépin JL, Vielle B, . Effect of mandibular advancement therapy on inflammatory and metabolic biomarkers in patients with severe obstructive sleep apnoea: a randomised controlled trial. Thorax. 2019 May;74(5):496–9. doi: 10.1136/thoraxjnl-2018-212609. PMID: 30366971. Exclusion Code: X9.30366971
708 Reddy A, Mansuri Z, Vadukapuram R, . Increased Suicidality and Worse Outcomes in MDD Patients With OSA: A Nationwide Inpatient Analysis of 11 Years From 2006 to 2017. Journal of the Academy of Consultation-Liaison Psychiatry. 2021doi: 10.1016/j.jaclp.2021.05.008. Exclusion Code: X4.
709 Redline S, Yenokyan G, Gottlieb DJ, . Obstructive sleep apnea-hypopnea and incident stroke: the sleep heart health study. Am J Respir Crit Care Med. 2010 Jul 15;182(2):269–77. doi: 10.1164/rccm.200911-1746OC. PMID: 20339144. Exclusion Code: X8.20339144
710 Reese EE, Gleason KJ, Wang R, . Increased body mass index following initiation of CPAP use. Sleep. 2015;38:A198–A9. Exclusion Code: X6.
711 Reid ML, Gleason KJ, Bakker JP, . The role of sham continuous positive airway pressure as a placebo in controlled trials: Best Apnea Interventions for Research Trial. Sleep. 2019 Aug 1;42(8)doi: 10.1093/sleep/zsz099. PMID: 31116848. Exclusion Code: X5.31116848
712 Remmers JE, Mosca EV, Topor Z, . Prediction of outcome with oral appliance therapy for obstructive sleep apnea using a feedback controlled mandibular positioner: validation on a new population of obstructive sleep apneics. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X6.
713 Reuter H, Herkenrath S, Treml M, . Sleep-disordered breathing in patients with cardiovascular diseases cannot be detected by ESS, STOP-BANG, and Berlin questionnaires. Clin Res Cardiol. 2018 Nov;107(11):1071–8. doi: 10.1007/s00392-018-1282-7. PMID: 29845331. Exclusion Code: X5.29845331
714 Ribeiro OR, do Carmo I, Paiva T, . Body mass index and neuropsychological and emotional variables: Joint contribution for the screening of sleep apnoea syndrome in obese. Sleep Science. 2021;14(1):19–26. doi: 10.5935/1984-0063.20200030. Exclusion Code: X3.34104333
715 Rietz H, Franklin KA, Carlberg B, . Nocturnal blood pressure is reduced by a mandibular advancement device for sleep apnea in women: findings from secondary analyses of a randomized trial. J Am Heart Assoc. 2018 Jun 21;7(13)doi: 10.1161/jaha.118.008642. PMID: 29929990. Exclusion Code: X9.29929990
716 Rimke AN, Ahmed SB, Turin TC, . Effect of CPAP therapy on kidney function in patients with obstructive sleep apnoea and chronic kidney disease: a protocol for a randomised controlled clinical trial. BMJ Open. 2019 Mar 23;9(3):e024632. doi: 10.1136/bmjopen-2018-024632. PMID: 30904853. Exclusion Code: X6.30904853
717 Rimke AN, Ahmed SB, Turin TC, . Effect of CPAP therapy on kidney function in patients with chronic kidney disease: a pilot randomized controlled trial. Chest. 2020 Dec 13doi: 10.1016/j.chest.2020.11.052. PMID: 33316238. Exclusion Code: X9.33316238
718 Rjabceva S, Karnialiuk V, Makaryna-Kibak L, . Changes of nasal mucosa epithelium after CPAP on patients with obstructive sleep apnea syndrome. Virchows Archiv. 2019;475:S113. doi: 10.1007/s00428-019-02631-8. Exclusion Code: X5.
719 Roca GQ, Redline S, Claggett B, . Sex-specific association of sleep apnea severity with subclinical myocardial injury, ventricular hypertrophy, and heart failure risk in a community-dwelling cohort: the Atherosclerosis Risk in Communities-Sleep Heart Health Study. Circulation. 2015 Oct 6;132(14):1329–37. doi: 10.1161/circulationaha.115.016985. PMID: 26316620. Exclusion Code: X3.26316620
720 Rocha AL, Wagner LE, Paiva DN. Effects of the mandibular advancement device on daytime sleepiness, quality of life and polysomnographic profile of public transport drivers with obstructive sleep apnea syndrome. Sleep Science. 2021;14(2):136–41. doi: 10.5935/1984-0063.20200058. Exclusion Code: X5.34381577
721 Roderjan C, Cavalcanti A, Cortez A, . Patients with resistant hypertension with moderate to severe sleep apnea: Impact of continuous positive airways pressure on arterial stiffness. Journal of Hypertension. 2019;37:e24. Exclusion Code: X9.
722 Rodrigues Filho JC, Neves DD, Araujo-Melo MH. Performance of the STOP-Bang in the detection of OSA, a Brazilian study. Rev Assoc Med Bras (1992). 2019 Aug 5;65(7):995–1000. doi: 10.1590/1806-9282.65.7.995. PMID: 31389512. Exclusion Code: X10.31389512
723 Rodrigues Filho JC, Neves DD, Velasque L, . Diagnostic performance of nocturnal oximetry in the detection of obstructive sleep apnea syndrome: a Brazilian study. Sleep Breath. 2020 Dec;24(4):1487–94. doi: 10.1007/s11325-019-02000-4. PMID: 31916123. Exclusion Code: X3.31916123
724 Rofail LM, Wong KK, Unger G, . Comparison between a single-channel nasal airflow device and oximetry for the diagnosis of obstructive sleep apnea. Sleep. 2010 Aug;33(8):1106–14. doi: 10.1093/sleep/33.8.1106. PMID: 20815194. Exclusion Code: X3.20815194
725 Rooney MR, Aurora RN, Wang D, . Rationale and design of the Hyperglycemic Profiles in Obstructive Sleep Apnea (HYPNOS) trial. Contemp Clin Trials. 2021 Feb;101:106248. doi: 10.1016/j.cct.2020.106248. PMID: 33316455. Exclusion Code: X6.33316455
726 Rossi A, Lo Giudice A, Di Pardo C, . Clinical evidence in the treatment of obstructive sleep apnoea with oral appliances: a systematic review. Int J Dent. 2021;2021:6676158. doi: 10.1155/2021/6676158. PMID: 34035815. Exclusion Code: X15.34035815
727 Rotty MC, Suehs CM, Mallet JP, . Mask side-effects in long-term CPAP-patients impact adherence and sleepiness: the InterfaceVent real-life study. Respir Res. 2021 Jan 15;22(1):17. doi: 10.1186/s12931-021-01618-x. PMID: 33451313. Exclusion Code: X5.33451313
728 Rowland S, Aiyappan V, Hennessy C, . Comparing the efficacy, mask leak, patient adherence, and patient preference of three different CPAP interfaces to treat moderate-severe obstructive sleep apnea. J Clin Sleep Med. 2018 Jan 15;14(1):101–8. doi: 10.5664/jcsm.6892. PMID: 29198305. Exclusion Code: X5.29198305
729 Ruiz A, Sepúlveda MAR, Martínez PH, . Prevalence of sleep complaints in Colombia at different altitudes. Sleep Science. 2016;9(2):100–5. doi: 10.1016/j.slsci.2016.05.008. Exclusion Code: X8.27656274
730 Ruzicka M, Hiremath S, Leenens FH, . Effect of CPAP on blood pressure and central sympathetic outflow in diabetic patients with OSA, resistant HTN, and CKD. Hypertension. 2017;70. Exclusion Code: X6.
731 Ruzicka M, Knoll G, Leenen FHH, . Effects of CPAP on blood pressure and sympathetic activity in patients with diabetes mellitus, chronic kidney disease, and resistant hypertension. CJC Open. 2020 Jul;2(4):258–64. doi: 10.1016/j.cjco.2020.03.010. PMID: 32695977. Exclusion Code: X9.32695977
732 Ryswyk EV, Anderson C, Arima H, . Effect of CPAP on blood pressure variability in obstructive sleep apnea and cardiovascular disease. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12765. Exclusion Code: X9.
733 Ryswyk EV, Anderson C, Barbe F, . Predictors of adherence to continuous positive airway pressure in obstructive sleep apnea and cardiovascular disease. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12765. Exclusion Code: X6.
734 Sadeghniiat-Haghighi K, Montazeri A, Khajeh-Mehrizi A, . The STOP-BANG questionnaire: reliability and validity of the Persian version in sleep clinic population. Qual Life Res. 2015 Aug;24(8):2025–30. doi: 10.1007/s11136-015-0923-9. PMID: 25613199. Exclusion Code: X10.25613199
735 Sahlin C, Blomberg A, Franklin KA. CPAP withdrawal on 24-hour blood pressure and arterial stiffness in women and men with obstructive sleep apnea. A randomized controlled trial. Sleep Medicine. 2017;40:e287–e8. Exclusion Code: X6.
736 Sahni N, Arora K, Bansal S, . Impact of lifestyle modifications on snoring and mild sleep apnoea patients. Journal of Laryngology and Otology. 2021doi: 10.1017/S0022215121002139. Exclusion Code: X4.
737 Saito K, Okada Y, Torimoto K, . Blood glucose dynamics during sleep in patients with obstructive sleep apnea and normal glucose tolerance: effects of CPAP therapy. Sleep and Breathing. 2021doi: 10.1007/s11325-021-02442-9. Exclusion Code: X6.
738 Salas C, Dreyse J, Contreras A, . Differences in patients derived from otolaryngology and other specialties with sleep apnea. J Otolaryngol Head Neck Surg. 2019 Oct 22;48(1):53. doi: 10.1186/s40463-019-0373-4. PMID: 31640800. Exclusion Code: X5.31640800
739 Sampol G, Rodés G, Ríos J, . Acute hypercapnic respiratory failure in patients with sleep apneas. Archivos de Bronconeumologia. 2010;46(9):466–72. doi: 10.1016/S1579-2129(10)70114-2. Exclusion Code: X6.20655644
740 Sanchez De La Torre M, Sánchez-de-la-Torre A, Bertran S, . Effect of sleep apnea and its treatment in the prognosis of patients with acute coronary syndrome: ISAACC study. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X12.
741 Sánchez-de-la-Torre M, Sánchez-de-la-Torre A, Bertran S, . Effect of obstructive sleep apnoea and its treatment with continuous positive airway pressure on the prevalence of cardiovascular events in patients with acute coronary syndrome (ISAACC study): a randomised controlled trial. Lancet Respir Med. 2020 Apr;8(4):359–67. doi: 10.1016/s2213-2600(19)30271-1. PMID: 31839558. Exclusion Code: X2.31839558
742 Sánchez-Quiroga M, Corral J, Gómez-de-Terreros FJ, . Primary care physicians can comprehensively manage patients with sleep apnea. A noninferiority randomized controlled trial. Am J Respir Crit Care Med. 2018 Sep 1;198(5):648–56. doi: 10.1164/rccm.201710-2061OC. PMID: 29664672. Exclusion Code: X5.29664672
743 Sangkum L, Klair I, Limsuwat C, . Incorporating body-type (apple vs. pear) in STOP-BANG questionnaire improves its validity to detect OSA. J Clin Anesth. 2017 Sep;41:126–31. doi: 10.1016/j.jclinane.2016.12.019. PMID: 28077252. Exclusion Code: X2.28077252
744 Santos AMB, Magalhães MGS, Silva TNS, . Six-minute walk test in subjects with obstructive sleep apnea treated with continuous positive airway pressure: A study of reliability. Sleep Science. 2019;12:49–50. Exclusion Code: X5.31105895
745 Santos CI, Thamilis Barbosa Pessoa Ferreira S, Cavalcanti Pinho M, . Influence of the auto-titrating continuous positive airway pressure device adjusted pressures on the evaluation of the residual apnea-hypopnea index and the 90th percentile used for titrating the therapeutic pressure on obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X5.
746 Sapiña-Beltrán E, Torres G, Benítez I, . Differential blood pressure response to continuous positive airway pressure treatment according to the circadian pattern in hypertensive patients with obstructive sleep apnoea. Eur Respir J. 2019 Jul;54(1)doi: 10.1183/13993003.00098-2019. PMID: 31097515. Exclusion Code: X9.31097515
747 Sargento P, Perea V, Ladera V, . Measurement properties of a screening questionnaire of obstructive sleep apnea risk: little information, great prediction? Sleep Science. 2014;7(2):89–95. doi: 10.1016/j.slsci.2014.09.008. Exclusion Code: X5.26483909
748 Sargsyan L, Chowdhury A, Mathew R, . The relationship of hypopnea apnea ratio (HAR) to effective positive airway pressure for obstructive sleep apnea hypopnea syndrome. Sleep. 2017;40:A203. Exclusion Code: X6.
749 Sarıçam E, Yalcinkaya E, Basay N. Bedside approach in the diagnosis obstructive sleep apnea using postprandial oximetry testing: A comparative study with polysomnography. Clin Respir J. 2020 Jan;14(1):35–9. doi: 10.1111/crj.13097. PMID: 31617287. Exclusion Code: X8.31617287
750 Sarkar PD, Kumar A. Plasma cytokines and C-PAP therapy in type II diabetic patients. Biochemical and Cellular Archives. 2020;20(2):4665–8. Exclusion Code: X14.
751 Sasaki N, Ozono R, Edahiro Y, . Short-term blood pressure variability in hypertensive patients with obstructive sleep apnea syndrome. Sleep and Biological Rhythms. 2015;13(2):117–26. doi: 10.1111/sbr.12094. Exclusion Code: X6.
752 Sato K, Nakajima T. Review of systematic reviews on mandibular advancement oral appliance for obstructive sleep apnea: The importance of long-term follow-up. Jpn Dent Sci Rev. 2020 Dec;56(1):32–7. doi: 10.1016/j.jdsr.2019.10.002. PMID: 31871511. Exclusion Code: X8.31871511
753 Scartabelli G, Querci G, Marconi L, . Liver enlargement predicts obstructive sleep apnea-hypopnea syndrome in morbidly obese women. Frontiers in Endocrinology. 2018;9(JUN)doi: 10.3389/fendo.2018.00293. Exclusion Code: X3.
754 Schalek P, Hornáčková Z, Kraus J, . Psychometric properties of the Czech version of epworth sleepiness scale. Ceska a Slovenska Neurologie a Neurochirurgie. 2015;78(6):689–92. doi: 10.14735/amcsnn2015689. Exclusion Code: X1.
755 Schaller L, Arzt M, Jung B, . Association between continuous positive airway pressure, weight change and glycaemic control in patients with type 2 diabetes. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2487. Exclusion Code: X8.
756 Scheel M, Berndt A, Simanski O. Cascaded control environment for a CPAP-device. Biomedizinische Technik. 2016;61:S217. doi: 10.1515/bmt-2016-5018. Exclusion Code: X5.
757 Schiavone M, Ernst G, Blanco M, . Performance of questionnaires aimed at detecting sleep disorders in patients attending a hypertension center. Clin Exp Hypertens. 2019;41(7):687–91. doi: 10.1080/10641963.2018.1539095. PMID: 30497297. Exclusion Code: X5.30497297
758 Schipper SBJ, Van Veen MM, Elders PJM, . Sleep disorders in people with type 2 diabetes and associated health outcomes: a review of the literature. Diabetologia. 2021doi: 10.1007/s00125-021-05541-0. Exclusion Code: X8.
759 Schlatzer C, Bratton DJ, Craig SE, . ECG risk markers for atrial fibrillation and sudden cardiac death in minimally symptomatic obstructive sleep apnoea: the MOSAIC randomised trial. BMJ Open. 2016 Mar 16;6(3):e010150. doi: 10.1136/bmjopen-2015-010150. PMID: 26983946. Exclusion Code: X6.26983946
760 Schlatzer C, Bratton DJ, Schwarz EI, . Effect of continuous positive airway pressure on circadian patterns of cardiac repolarization in obstructive sleep apnoea: Data from a randomized controlled trial. Kardiovaskulare Medizin. 2016;19(5):91S–2S. Exclusion Code: X6.
761 Schlatzer C, Bratton DJ, Schwarz EI, . Effect of continuous positive airway pressure on circadian patterns of cardiac repolarization in obstructive sleep apnoea: Data from a randomized controlled trial. European Heart Journal. 2016;37:87–8. doi: 10.1093/eurheartj/ehw431. Exclusion Code: X6.
762 Schlatzer C, Bratton DJ, Schwarz EI, . Effect of continuous positive airway pressure therapy on circadian patterns of cardiac repolarization in patients with obstructive sleep apnoea: Data from a randomized trial. Journal of Thoracic Disease. 2018;10(8):4940–8. doi: 10.21037/jtd.2018.07.17. Exclusion Code: X6.30233868
763 Schneiderman E, Schramm P, Hui J, . Randomized Trial of 2 Self-Titrated Oral Appliances for Airway Management. J Dent Res. 2021 Feb;100(2):155–62. doi: 10.1177/0022034520956977. PMID: 32942939. Exclusion Code: X5.32942939
764 Schoch OD, Benz G, Baty F, . Telemetrically triggered interventions in the first month of CPAP treatment-a prospective, randomized controlled intervention trial in patients with a new diagnosis of obstructive sleep apnea syndrome. Kardiovaskulare Medizin. 2016;19(5):26S–7S. Exclusion Code: X6.
765 Schulz R, Bischof F, Galetke W, . CPAP therapy improves erectile function in patients with severe obstructive sleep apnea. Sleep Med. 2019 Jan;53:189–94. doi: 10.1016/j.sleep.2018.03.018. PMID: 29773460. Exclusion Code: X6.29773460
766 Schwarz EI, Furian M, Schlatzer C, . OSA results in nocturnal cerebral hypoxia which is prevented by CPAP-Data from a randomised controlled trial. European Respiratory Journal. 2015;46doi: 10.1183/13993003.congress2015.PA2333. Exclusion Code: X6.
767 Schwarz EI, Furian M, Schlatzer C, . Nocturnal cerebral hypoxia in obstructive sleep apnoea: a randomised controlled trial. Eur Respir J. 2018 May;51(5)doi: 10.1183/13993003.00032-2018. PMID: 29700104. Exclusion Code: X13.29700104
768 Schwarz EI, Schlatzer C, Rossi VA, . Effect of CPAP withdrawal on BP in OSA: data from three randomized controlled trials. Chest. 2016 Dec;150(6):1202–10. doi: 10.1016/j.chest.2016.07.012. PMID: 27452767. Exclusion Code: X5.27452767
769 Schwarz EI, Schlatzer C, Stehli J, . The effects of short-term CPAP withdrawal on myocardial perfusion in OSA-A randomised placebo-controlled trial. European Respiratory Journal. 2014;44. Exclusion Code: X4.
770 Schwarz L, Glos M, Pilz C, . Evaluation of the pharyngeal cross section in the diagnostics of obstructive sleep apnea in men with normal weight and pre-obesity. Somnologie. 2014;18(4):231–7. doi: 10.1007/s11818-014-0689-2. Exclusion Code: X1.
771 Scotti C, Porta R, Olivares A, . Nocturnal hypoxemia impacts right ventricle diastolic function in obstructive sleep apnea: a retrospective observational study. Journal of Clinical Medicine. 2020;9(1)doi: 10.3390/jcm9010162. Exclusion Code: X3.
772 Segù M, Cosi A, Santagostini A, . Efficacy of a Trial Oral Appliance in OSAS Management: A New Protocol to Recognize Responder/Nonresponder Patients. International Journal of Dentistry. 2021;2021doi: 10.1155/2021/8811700. Exclusion Code: X5.
773 Senaratna CV, Perret JL, Lowe A, . Detecting sleep apnoea syndrome in primary care with screening questionnaires and the Epworth sleepiness scale. Med J Aust. 2019 Jul;211(2):65–70. doi: 10.5694/mja2.50145. PMID: 31049990. Exclusion Code: X5.31049990
774 Seng M, Frye BC, Vollmer L, . Improvement of patient-reported outcomes in patients with primary Sjögren’s syndrome undergoing CPAP-treatment. Annals of the Rheumatic Diseases. 2020;79(SUPPL 1):1494. doi: 10.1136/annrheumdis-2020-eular.2020. Exclusion Code: X2.
775 Serrano EM, Lopez-Picado A, Etxagibel A, . Derivation and validation of a clinical prediction rule for sleep apnoea syndrome for use in primary care. BJGP Open. 2018;2(2)doi: 10.3399/bjgpopen18X101481. Exclusion Code: X2.
776 Serra-Torres S, Bellot-Arcís C, Montiel-Company JM, . Effectiveness of mandibular advancement appliances in treating obstructive sleep apnea syndrome: a systematic review. Laryngoscope. 2016 Feb;126(2):507–14. doi: 10.1002/lary.25505. PMID: 26228493. Exclusion Code: X8.26228493
777 Servantes DM, Javaheri S, Kravchychyn ACP, . Effects of exercise training and CPAP in patients with heart failure and OSA: a preliminary study. Chest. 2018 Oct;154(4):808–17. doi: 10.1016/j.chest.2018.05.011. PMID: 30213463. Exclusion Code: X10.30213463
778 Sezavar SH, Hajsadeghi S, Hejrati M, . Left ventricular mass index and pulmonary artery pressure in patients with the obstructive sleep apnea syndrome. Journal of Tehran University Heart Center. 2016;11(1):11–4. Exclusion Code: X8.27403184
779 Shaarawy H, Elhawary A. Study of sleep related respiratory disorders in patients with idiopathic pulmonary arterial hypertension. Egyptian Journal of Chest Diseases and Tuberculosis. 2016;65(1):233–7. doi: 10.1016/j.ejcdt.2015.12.011. Exclusion Code: X8.
780 Shaarawy H, Gharraf HS. Comparison between the use of APAP and manual titration during split night polysomnography for diagnosis and treatment of OSA. Egyptian Journal of Chest Diseases and Tuberculosis. 2018;67(2):175–81. doi: 10.4103/ejcdt.ejcdt_20_18. Exclusion Code: X5.
781 Shaf E. The relationship between obstructive sleep apnea and depression. Journal of Sleep Research. 2016;25:258. doi: 10.1111/jsr.12446. Exclusion Code: X5.
782 Shah N, Hanna DB, Teng Y, . Sex-specific prediction models for sleep apnea from the Hispanic Community Health Study/Study of Latinos. Chest. 2016 Jun;149(6):1409–18. doi: 10.1016/j.chest.2016.01.013. PMID: 26836933. Exclusion Code: X5.26836933
783 Shaha D, Costan-Toth C, Terry S, . Improved compliance in patients diagnosed with OSA and co-morbid PTSD through a new CPAP delivery platform. Sleep. 2017;40:A200. Exclusion Code: X6.
784 Shahi D, Rajabalan A, Paudel SD, . Effects of CPAP on sleep quality, stroke and all cause mortality: a pooled meta-analysis of randomized controlled trials. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.B107. Exclusion Code: X8.
785 Shameem M, Khan AS, Khan R, . Correlation of obstructive sleep apnea with disease severity in chronic kidney diseases: a prospective interventional study. Lung India. 2019;36(9):S110. doi: 10.4103/0970-2113.271103. Exclusion Code: X6.
786 Shang W, Zhang Y, Wang G, . Benefits of continuous positive airway pressure on glycaemic control and insulin resistance in patients with type 2 diabetes and obstructive sleep apnoea: A meta-analysis. Diabetes Obes Metab. 2021 Feb;23(2):540–8. doi: 10.1111/dom.14247. PMID: 33146450. Exclusion Code: X6.33146450
787 Shapira-Daniels A, Mohanty S, Contreras-Valdes FM, . Prevalence of Undiagnosed Sleep Apnea in Patients With Atrial Fibrillation and its Impact on Therapy. JACC Clin Electrophysiol. 2020 Nov;6(12):1499–506. doi: 10.1016/j.jacep.2020.05.030. PMID: 33213809. Exclusion Code: X5.33213809
788 Sharma S, Francisco A, Mukhtar U, . Positive airway pressure therapy in patient admitted for acute heart failure with pulmonary hypertension and obstructive sleep apnea significantly reduces pulmonary pressures. Sleep. 2018;41:A194–A5. Exclusion Code: X2.
789 Sharma S, Madoukh B, Palle S, . Pacing therapies for sleep apnea and cardiovascular outcomes. Journal of the American College of Cardiology. 2019;73(9 Supplement 1):1019. doi: 10.1016/S0735-1097(19)31626-2. Exclusion Code: X4.
790 Sharma S, Mather PJ, Chowdhury A, . Sleep overnight monitoring for apnea in patients hospitalized with heart failure (SOMA-HF Study). J Clin Sleep Med. 2017 Oct 15;13(10):1185–90. doi: 10.5664/jcsm.6768. PMID: 28859720. Exclusion Code: X2.28859720
791 Sharma S, Mather PJ, Efird JT, . Obstructive sleep apnea in obese hospitalized patients: a single center experience. J Clin Sleep Med. 2015 Jul 15;11(7):717–23. doi: 10.5664/jcsm.4842. PMID: 25766715. Exclusion Code: X2.25766715
792 Sharples LD, Clutterbuck-James AL, Glover MJ, . Meta-analysis of randomised controlled trials of oral mandibular advancement devices and continuous positive airway pressure for obstructive sleep apnoea-hypopnoea. Sleep Med Rev. 2016 Jun;27:108–24. doi: 10.1016/j.smrv.2015.05.003. PMID: 26163056. Exclusion Code: X8.26163056
793 Shechter A, Kovtun K, St-Onge MP. Effects of continuous positive airway pressure on energy intake in obstructive sleep apnea: a pilot sham-controlled study. Physiol Behav. 2016 Dec 1;167:399–403. doi: 10.1016/j.physbeh.2016.10.011. PMID: 27769851. Exclusion Code: X8.27769851
794 Sheets V, Maerz R, Johnston W, . Increasing adherence to mandibular advancement devices for obstructive sleep apnea. Sleep. 2019;42:A396–A7. doi: 10.1093/sleep/zsz067.982. Exclusion Code: X6.
795 Shehab-Eldin WA, El-Habashy MM. The association of obstructive sleep apnea with insulin resistance in obese Egyptians. Egyptian Journal of Chest Diseases and Tuberculosis. 2019;68(1):80–7. doi: 10.4103/ejcdt.ejcdt-44-18. Exclusion Code: X6.
796 Shen Z, Zhang B. Effect of noninvasive positive pressure ventilation on arrhythmia in patients with coronary heart disease and obstructive sleep apnea hypopnea syndrome. Basic and Clinical Pharmacology and Toxicology. 2020;127(SUPPL 3):296. doi: 10.1111/bcpt.13494. Exclusion Code: X4.
797 Shi H, Xiang S, Huang X, . Development and validation of a nomogram for predicting the risk of obstructive sleep apnea in patients with type 2 diabetes. Annals of Translational Medicine. 2020;8(24)doi: 10.21037/ATM-20-6890. Exclusion Code: X10.
798 Shim CY, Kim D, Lee CJ, . Effects of continuous positive airway pressure therapy on arterial stiffness, 24 hour-ambulatory blood pressure and ventricular-vascular coupling in subjects with hypertension: A randomized, sham-controlled clinical trial. Journal of Hypertension. 2018;36:e240–e1. doi: 10.1097/01.hjh.0000548984.89609.6d. Exclusion Code: X6.
799 Shim CY, Kim D, Park S, . Effects of continuous positive airway pressure therapy on left ventricular diastolic function: a randomised, sham-controlled clinical trial. Eur Respir J. 2018 Feb;51(2)doi: 10.1183/13993003.01774-2017. PMID: 29386335. Exclusion Code: X9.29386335
800 Shimizu Y, Yoshimine H, Nagayoshi M, . Serum triglyceride levels in relation to high-density lipoprotein cholesterol (TG-HDL) ratios as an efficient tool to estimate the risk of sleep apnea syndrome in non-overweight Japanese men. Environ Health Prev Med. 2016 Sep;21(5):321–6. doi: 10.1007/s12199-016-0532-4. PMID: 27095251. Exclusion Code: X3.27095251
801 Shin Y, Byun J, Ahn S, . Efficacy of dental device for treatment for moderate to severe obstructive sleep apnea in Korean: Interim result of prospective multicenter study. Sleep. 2018;41:A207. Exclusion Code: X5.
802 Shoib S, Malik JA, Masoodi S. Depression as a manifestation of obstructive sleep apnea. Journal of Neurosciences in Rural Practice. 2017;8(3):346–51. doi: 10.4103/jnrp.jnrp_462_16. Exclusion Code: X3.28694611
803 Showalter L, O’Keefe C. Implementation of an obstructive sleep apnea screening tool with hypertensive patients in the primary care clinic. J Am Assoc Nurse Pract. 2019 Mar;31(3):184–8. doi: 10.1097/JXX.0000000000000124. PMID: 30589754. Exclusion Code: X8.30589754
804 Shuren D, Luvsan O. A randomized controlled trial of treatment in obstructive sleep apnea in Mongolia. Clinical Neurology. 2019;59:S422. doi: 10.5692/clinicalneurol.59_supplement_S260. Exclusion Code: X10.
805 Silaruks S, Sawanyawisuth K. Numbers of antihypertensive agents to control blood pressure in obstructive sleep apnea caused hypertensive patients. Heart Lung and Circulation. 2016;25:S19. doi: 10.1016/j.hlc.2016.06.042. Exclusion Code: X8.
806 Silva J, Sampaio M. Obstructive sleep apnea risk assessment among hypertensive population in primary care. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X8.
807 Silva KV, Rosa ML, Jorge AJ, . Prevalence of risk for obstructive sleep apnea syndrome and association with risk factors in primary care. Arq Bras Cardiol. 2016 Jun;106(6):474–80. doi: 10.5935/abc.20160061. PMID: 27142651. Exclusion Code: X5.27142651
808 Silva MP, Fontes LES, Pachito DV, . Non-invasive positive airway pressure therapy for improving erectile dysfunction in men with obstructive sleep apnoea. Cochrane Database of Systematic Reviews. 2018;2018(11)doi: 10.1002/14651858.CD013169. Exclusion Code: X6.
809 Sivam S, Witting PK, Hoyos CM, . Effects of 8 weeks of CPAP on plasma markers of oxidative damage in obstructive sleep apnea: a randomised trial. American Journal of Respiratory and Critical Care Medicine. 2014;189. Exclusion Code: X6.
810 Sivam S, Witting PK, Hoyos CM, . Effects of 8 weeks of CPAP on lipid-based oxidative markers in obstructive sleep apnea: a randomized trial. J Sleep Res. 2015 Jun;24(3):339–45. doi: 10.1111/jsr.12271. PMID: 25533591. Exclusion Code: X9.25533591
811 Sivam S, Yee B, Wong K, . Obesity hypoventilation syndrome: early detection of nocturnal-only hypercapnia in an obese population. J Clin Sleep Med. 2018 Sep 15;14(9):1477–84. doi: 10.5664/jcsm.7318. PMID: 30176974. Exclusion Code: X3.30176974
812 Skjodt N, Plattt RS, Sharraf S, . Over diagnosis of sleep apnoea: a comparison of three common ambulatory sleep polygraphs. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA2314. Exclusion Code: X3.
813 Slawson D. Treating sleep apnea with positive airway pressure does not reduce adverse CV outcomes or mortality. Am Fam Physician. 2017 Nov 15;96(10):Online. PMID: 29431393. Exclusion Code: X8.29431393
814 Slouka D, Honnerova M, Hosek P, . Improved prediction of CPAP failure using T90, age and gender. Journal of Applied Biomedicine. 2019;17(1):76–81. doi: 10.32725/jab.2018.008. Exclusion Code: X2.
815 Somboon T, Andrews ND, Bena JF, . Long-term seizure control in epileptic patients with obstructive sleep apnea using positive airway pressure therapy. Sleep. 2017;40:A427–A8. Exclusion Code: X8.
816 Spicuzza L, Campisi R, Nicotra L, . Twenty years compliance with continuous positive air pressure treatment in patients with severe obstructive sleep apnea. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA4155. Exclusion Code: X6.
817 Spießhöfer J, Schmalgemeier H, Schindhelm F, . Inflammation in patients with obstructive sleep apnea and coronary artery disease: robust correlations between inflammation markers and obstructive sleep apnea severity, and the impact of CPAP. Somnologie. 2017;21(4):257–64. doi: 10.1007/s11818-017-0111-y. Exclusion Code: X6.
818 Spörndly-Nees S, Åsenlöf P, Lindberg E, . Effects on obstructive sleep apnea severity following a tailored behavioral sleep medicine intervention aimed at increased physical activity and sound eating: an 18-month follow-up of a randomized controlled trial. J Clin Sleep Med. 2020 May 15;16(5):705–13. doi: 10.5664/jcsm.8322. PMID: 32024584. Exclusion Code: X5.32024584
819 Sprung VS, Kemp GJ, Wilding JP, . Randomised, cOntrolled Multicentre trial of 26 weeks subcutaneous liraglutide (a glucagon-like peptide-1 receptor Agonist), with or without contiNuous positive airway pressure (CPAP), in patients with type 2 diabetes mellitus (T2DM) and obstructive sleep apnoEa (OSA) (ROMANCE): study protocol assessing the effects of weight loss on the apnea-hypnoea index (AHI). BMJ Open. 2020 Jul 22;10(7):e038856. doi: 10.1136/bmjopen-2020-038856. PMID: 32699168. Exclusion Code: X6.32699168
820 Srivali N, Caples SM. The effect of non invasive ventilator for sleep apnea in atrial fibrillation/flutter patients. Sleep. 2017;40:A391. Exclusion Code: X8.
821 Stafford PL, Harmon EK, Patel P, . The Influence of Obesity on the Association of Obstructive Sleep Apnea and Atrial Fibrillation. Sleep Medicine Research. 2021;12(1):50–6. doi: 10.17241/SMR.2021.00857. Exclusion Code: X8.34497733
822 Stanchina ML, Prenda S, Lincoln J, . Negative home sleep testing in patients with high risk obstructive sleep apnea characteristics. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X5.
823 Starkey SY, Jonasson DR, Alexis S, . Screening for Obstructive Sleep Apnea in an Atrial Fibrillation Population: What’s the Best Test? CJC Open. 2021 Apr;3(4):442–9. doi: 10.1016/j.cjco.2020.09.026. PMID: 34027347. Exclusion Code: X5.34027347
824 Stavrou V, Boutou AK, Vavougios GD, . The use of cardiopulmonary exercise testing in identifying the presence of obstructive sleep apnea syndrome in patients with compatible symptomatology. Respir Physiol Neurobiol. 2019 Apr;262:26–31. doi: 10.1016/j.resp.2019.01.010. PMID: 30684645. Exclusion Code: X6.30684645
825 Stavrou VT, Vavougios GD, Astara K, . The 6-minute walk test and anthropometric characteristics as assessment tools in patients with obstructive sleep apnea syndrome. A preliminary report during the pandemic. Journal of Personalized Medicine. 2021;11(6)doi: 10.3390/jpm11060563. Exclusion Code: X3.
826 Stepnowsky C, Sarmiento K, Zamora T, . Sleep apnea management effect sizes: objective vs. subjective measures. Sleep. 2015;38:A190. Exclusion Code: X8.
827 Stern J, Kuhns D. Effectiveness and efficiency of the ProSomnus® [IA] sleep device for the treatment of obstructive sleep apnea-the effects study. Sleep Medicine. 2017;40:e172. Exclusion Code: X5.
828 Storesund A, Johansson A, Lehmann S. Maximum pressures from auto-CPAP devices predict oral appliance treatment success in non-adherent obstructive sleep apnoea patients. European Respiratory Journal. 2016;48doi: 10.1183/13993003.congress-2016.PA2386. Exclusion Code: X2.
829 Suksangeam R, Banhiran W, Keskool P, . Custom-made oral appliances for the treatment of obstructive sleep apnea: Outcomes in Thai patients. Journal of the Medical Association of Thailand. 2021;104(4):571–5. doi: 10.35755/jmedassocthai.2021.04.11696. Exclusion Code: X5.
830 Summerer V, Arzt M, Fox H, . Occurrence of coronary collaterals in acute myocardial infarction and sleep apnea. Journal of the American Heart Association. 2021;10(15)doi: 10.1161/JAHA.120.020340. Exclusion Code: X6.
831 Sun MH, Liao YJ, Lin CC, . Association between obstructive sleep apnea and optic neuropathy: a Taiwanese Population-Based bidirectional cohort Study. Investigative Ophthalmology and Visual Science. 2017;58(8). Exclusion Code: X8.
832 Sun X, Luo J, Wang Y. Comparing the effects of supplemental oxygen therapy and continuous positive airway pressure on patients with obstructive sleep apnea: a meta-analysis of randomized controlled trials. Sleep Breath. 2021 Jan 7doi: 10.1007/s11325-020-02245-4. PMID: 33415654. Exclusion Code: X5.33415654
833 Sun Y, Huang ZY, Sun QR, . CPAP therapy reduces blood pressure for patients with obstructive sleep apnoea: an update meta-analysis of randomized clinical trials. Acta Cardiol. 2016 Jun;71(3):275–80. doi: 10.2143/ac.71.3.3152087. PMID: 27594122. Exclusion Code: X8.27594122
834 Sunadome H, Matsumoto H, Tachikawa R, . Roles of periostin in patients with severe obstructive sleep apnea. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA2978. Exclusion Code: X6.
835 Sundar K, Willis A, Smith S, . Effect of continuous positive airway pressure (CPAP) vs. sham CPAP in chronic unexplained cough: A randomized study (interim analysis). American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X6.
836 Sundar KM, Willis AM, Smith S, . A randomized, controlled, pilot study of CPAP for patients with chronic cough and obstructive sleep apnea. Lung. 2020 Jun;198(3):449–57. doi: 10.1007/s00408-020-00354-1. PMID: 32356074. Exclusion Code: X6.32356074
837 Suneja A, Skiba V, Novikova M, . Treatment of obstructive sleep apnea with positive airway pressure in mild cognitive impairment. Neurology. 2018;90(15). Exclusion Code: X8.
838 Suri TM, Sharma SK, Kumaran SS, . Neurocognitive impairment in patients with obstructive sleep apnea before and after therapy with continuous positive airway pressure. Sleep Medicine. 2017;40:e320. Exclusion Code: X5.
839 Sutherland K, Keenan BT, Bittencourt L, . A global comparison of anatomic risk factors and their relationship to obstructive sleep apnea severity in clinical samples. J Clin Sleep Med. 2019 Apr 15;15(4):629–39. doi: 10.5664/jcsm.7730. PMID: 30952214. Exclusion Code: X3.30952214
840 Svanborg E, Broström A, Ulander M, . Sensory nervous lesions in the palate worsens over time in untreated snorers but not in CPAP-treated OSA-patients. Journal of Sleep Research. 2016;25:256. doi: 10.1111/jsr.12446. Exclusion Code: X6.
841 Svanborg E, Sunnergren O, Ulander M, . Snoring causes OSA: Sensory nervous lesions in the palate worsen over time in untreated snorers but not in CPAP-treated patients. Journal of Sleep Research. 2018;27:399. doi: 10.1111/jsr.12751. Exclusion Code: X6.
842 Svedmyr S, Hedner J, Zou D, . Blood pressure reduction following treatment with positive airway pressure in sleep apnea - data from the ESADA. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2495. Exclusion Code: X5.
843 Sweetman A, Lack L, Catcheside P, . Changes in initial, middle and late insomnia subtypes during CBT-i and cpap therapy in co-morbid insomnia and sleep apnea (COMISA). Sleep Medicine. 2019;64:S370–S1. doi: 10.1016/j.sleep.2019.11.1032. Exclusion Code: X6.
844 Sweetman A, Lack L, Catcheside PG, . Cognitive and behavioral therapy for insomnia increases the use of continuous positive airway pressure therapy in obstructive sleep apnea participants with comorbid insomnia: a randomized clinical trial. Sleep. 2019 Dec 24;42(12)doi: 10.1093/sleep/zsz178. PMID: 31403168. Exclusion Code: X2.31403168
845 Sweetman A, Lack L, McEvoy RD, . Cognitive behavioural therapy for insomnia reduces sleep apnoea severity: a randomised controlled trial. ERJ Open Research. 2020;6(2):1–9. doi: 10.1183/23120541.00161-2020. Exclusion Code: X4.
846 Tallamraju H, Newton JT, Fleming PS, . Factors influencing adherence to oral appliance therapy in adults with obstructive sleep apnea: a systematic review and meta-analysis. J Clin Sleep Med. 2021 Jul 1;17(7):1485–98. doi: 10.5664/jcsm.9184. PMID: 33660611. Exclusion Code: X8.33660611
847 Tamisier R, Damy T, Davy JM, . FACE: Phenotyping analysis of chronic heart failure (CHF) patients with sleep disordered breathing (SDB) indicated for adaptive servoventilation (ASV): 2-year follow-up results. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X6.
848 Tamisier R, Jullian-Desayes I, Zarski JP, . Impact of continuous positive airway pressure on liver injury induced by obstructive sleep apnea: Data from randomized controlled trials. American Journal of Respiratory and Critical Care Medicine. 2015;191. Exclusion Code: X6.
849 Tan L, Li T, Zhou J, . Effect of nocturnal oxygen treatment on obstructive sleep apnea/hypopnea syndrome in highlanders: randomized, placebo-controlled, double-blinded trial. Sleep Medicine. 2019;64:S373–S4. doi: 10.1016/j.sleep.2019.11.1041. Exclusion Code: X4.
850 Tang I, Turnbull CD, Sen D, . Effect of CPAP on cardiovascular events in minimally symptomatic OSA: long-term follow-up of the MOSAIC randomised controlled trial. BMJ Open Respir Res. 2020 Sep;7(1)doi: 10.1136/bmjresp-2020-000742. PMID: 32928788. Exclusion Code: X6.32928788
851 Tang ZJ, Wei ZH, Wu YD, . Analysis of pulmonary function in patients with severe obstructive sleep apnea-hypopnea syndrome. Journal of Shanghai Jiaotong University (Medical Science). 2016;36(12):1817–9. doi: 10.3969/j.issn.1674-8115.2016.12.028. Exclusion Code: X1.
852 Tarraubella N, de Batlle J, Nadal N, . GESAP trial rationale and methodology: management of patients with suspected obstructive sleep apnea in primary care units compared to sleep units. NPJ Prim Care Respir Med. 2017 Feb 7;27(1):8. doi: 10.1038/s41533-016-0010-x. PMID: 28174423. Exclusion Code: X6.28174423
853 Taşbakan MS, Grote L, Hedner J, . Positive airway pressure treatment reduces glycated hemoglobin (HbAic) levels in obstructive sleep apnea patients: Longitudinal data from the ESADA. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.PA2007. Exclusion Code: X8.
854 Tegelberg Å, Nohlert E, Bornefalk-Hermansson A, . Respiratory outcome after one-year treatment of obstructive sleep apnea with bibloc versus monobloc oral appliances: a multicenter, randomized equivalence trial. Sleep Medicine. 2019;64:S378. doi: 10.1016/j.sleep.2019.11.1053. Exclusion Code: X5.
855 Tegelberg Å, Nohlert E, Bornefalk-Hermansson A, . Respiratory outcomes after a 1-year treatment of obstructive sleep apnoea with bibloc versus monobloc oral appliances: a multicentre, randomized equivalence trial. Acta Odontol Scand. 2020 Aug;78(6):401–8. doi: 10.1080/00016357.2020.1730436. PMID: 32125197. Exclusion Code: X5.32125197
856 Teklu M, Gouveia CJ, Yalamanchili A, . Predicting obstructive sleep apnea status with the reflux symptom index in a sleep study population. Laryngoscope. 2020 Dec;130(12):E952–e7. doi: 10.1002/lary.28592. PMID: 32119130. Exclusion Code: X5.32119130
857 Teng Y, Wang S, Wang N, . STOP-Bang questionnaire screening for obstructive sleep apnea among Chinese patients with type 2 diabetes mellitus. Archives of Medical Science. 2018;14(5):971–8. doi: 10.5114/aoms.2018.73984. Exclusion Code: X10.30154877
858 Thakur B, Pathak M, Singh P, . Prevalence of obstructive sleep apnea among patients with rheumatoid arthritis and its association with age and body mass index: A systematic review and meta-analysis. International Journal of Rheumatic Diseases. 2021doi: 10.1111/1756-185X.14178. Exclusion Code: X8.
859 Theorell-Haglöw J, Hoyos CM, Phillips CL, . CPAP therapy, Vitamin D and bone turnover markers - A randomized controlled trial. Sleep. 2016;39:A146. Exclusion Code: X6.
860 Theorell-Haglöw J, Hoyos CM, Phillips CL, . CPAP therapy, vitamin D and bone turnover markers-a randomized controlled trial. Journal of Sleep Research. 2016;25:40. doi: 10.1111/jsr.12446. Exclusion Code: X6.
861 Theorell-Haglöw J, Hoyos CM, Phillips CL, . Changes of vitamin D levels and bone turnover markers after CPAP therapy: a randomized sham-controlled trial. J Sleep Res. 2018 Aug;27(4):e12606. doi: 10.1111/jsr.12606. PMID: 28944524. Exclusion Code: X9.28944524
862 Thiel S, Lettau F, Haile SH, . The effects of CPAP-withdrawal on cerebral vascular reactivity and brain oxygenation in patients with obstructive sleep apnoea: A randomised-controlled trial. Respiration. 2018;95(6):495. doi: 10.1159/000488898. Exclusion Code: X5.
863 Thiel S, Lettau F, Rejmer P, . Effects of short-term continuous positive airway pressure withdrawal on cerebral vascular reactivity measured by blood oxygen level-dependent magnetic resonance imaging in obstructive sleep apnoea: a randomised controlled trial. Eur Respir J. 2019 Feb;53(2)doi: 10.1183/13993003.01854-2018. PMID: 30487209. Exclusion Code: X8.30487209
864 Thornton A, Maijer R, Christie D, . Personalizing treatment for OSA: a pilot study comparing two mobile health technologies. Sleep. 2019;42:A407. doi: 10.1093/sleep/zsz067.1009. Exclusion Code: X8.
865 Thunstrom E, Glantz H, Yucel-Lindberg T, . CPAP does not reduce inflammatory biomarkers in patients with coronary artery disease and nonsleepy obstructive sleep apnea: a randomized controlled trial. Sleep. 2019 Feb 1;42(2)doi: 10.1093/sleep/zsy241. PMID: 30551223. Exclusion Code: X6.30551223
866 Thunström E, Glantz H, Yucel-Lindberg T, . CPAP does not reduce inflammatory biomarkers in patients with coronary artery disease and nonsleepy obstructive sleep apnea: a randomized controlled trial. Sleep. 2017 Nov 1;40(11)doi: 10.1093/sleep/zsx157. PMID: 29029237. Exclusion Code: X6.29029237
867 Thunström E, Manhem K, Rosengren A, . Blood pressure response to losartan and continuous positive airway pressure in hypertension and obstructive sleep apnea. Am J Respir Crit Care Med. 2016 Feb 1;193(3):310–20. doi: 10.1164/rccm.201505-0998OC. PMID: 26414380. Exclusion Code: X5.26414380
868 Thunström E, Manhem K, Yucel-Lindberg T, . Neuroendocrine and inflammatory responses to losartan and continuous positive airway pressure in patients with hypertension and obstructive sleep apnea. A randomized controlled trial. Ann Am Thorac Soc. 2016 Nov;13(11):2002–11. doi: 10.1513/AnnalsATS.201602-126OC. PMID: 27548072. Exclusion Code: X6.27548072
869 Tichanon P, Wilaiwan K, Sopida S, . Effect of continuous positive airway pressure on airway inflammation and oxidative stress in patients with obstructive sleep apnea. Canadian Respiratory Journal. 2016;2016doi: 10.1155/2016/3107324. Exclusion Code: X5.
870 Tien HA. Arrhythmia and sleep apnea syndrome: State of the art. Journal of Arrhythmia. 2019;35:211–2. doi: 10.1002/joa3.12267. Exclusion Code: X8.
871 Timkova V, Nagyova I, Reijneveld SA, . Quality of life of obstructive sleep apnoea patients receiving continuous positive airway pressure treatment: A systematic review and meta-analysis. Heart Lung. 2020 Jan–Feb;49(1):10–24. doi: 10.1016/j.hrtlng.2019.10.004. PMID: 31668362. Exclusion Code: X8.31668362
872 Todea DA, Coman AC. The benefits of Calgary sleep apnea quality of life index in sleep medicine. Clujul Medical. 2015;88:S34. Exclusion Code: X8.
873 Tong B, Tran C, Ricciardiello A, . Postural effects on nasal resistance in obstructive sleep apnoea (OSA) and efficacy of a novel oral appliance. European Respiratory Journal. 2018;52doi: 10.1183/13993003.congress-2018.PA4339. Exclusion Code: X5.
874 Tong BK, Tran C, Ricciardiello A, . CPAP combined with oral appliance therapy reduces CPAP requirements and pharyngeal pressure swings in obstructive sleep apnea. J Appl Physiol (1985). 2020 Nov 1;129(5):1085–91. doi: 10.1152/japplphysiol.00393.2020. PMID: 32909921. Exclusion Code: X6.32909921
875 Torrella M, Castells I, Gimenez-Perez G, . Intermittent hypoxia is an independent marker of poorer glycaemic control in patients with uncontrolled type 2 diabetes. Diabetes Metab. 2015 Sep;41(4):312–8. doi: 10.1016/j.diabet.2015.01.002. PMID: 25662841. Exclusion Code: X6.25662841
876 Toukh M, Pereira EJ, Falcon BJ, . CPAP reduces hypercoagulability, as assessed by thromboelastography, in severe obstructive sleep apnoea. Respir Physiol Neurobiol. 2012 Sep 30;183(3):218–23. doi: 10.1016/j.resp.2012.06.022. PMID: 22771782. Exclusion Code: X9.22771782
877 Traaen GM, Aakerøy L, Hunt TE, . Effect of continuous positive airway pressure in patients with paroxysmal atrial fibrillation and obstructive sleep apnea. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2504. Exclusion Code: X12.
878 Traaen GM, Aakerøy L, Hunt TE, . Effect of continuous positive airway pressure on the burden of arrhythmia in patients with paroxysmal atrial fibrillation and sleep apnea: A randomized controlled trial. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X12.
879 Traaen GM, Aakeroy L, Hunt TE, . Effect of continuous positive airway pressure therapy in patients with paroxysmal atrial fibrillation and obstructive sleep apnea: A randomized controlled trial. European Heart Journal. 2020;41(SUPPL 2):670. doi: 10.1093/ehjci/ehaa946.0670. Exclusion Code: X12.
880 Trakada G, Velentza L, Kostopoulos C, . Cost - effectiveness of nasal continuous positive airways treatment versus the absence of treatment, in patients with obstructive sleep apnea syndrome. Journal of Thoracic Disease. 2012;4doi: 10.3978/j.issn.2072-1439.2012.s110. Exclusion Code: X8.
881 Traxdorf M, Tziridis K, Scherl C, . The Erlangen Questionnaire: a new 5-item screening tool for obstructive sleep apnea in a sleep clinic population - A prospective, double blinded study. Eur Rev Med Pharmacol Sci. 2017 Aug;21(16):3690–8. PMID: 28925472. Exclusion Code: X2.28925472
882 Treml M, Herkenrath SD, Anduleit N, . Efficacy of a FOT-based auto-CPAP device for the treatment of obstructive sleep apnea. European Respiratory Journal. 2018;52doi: 10.1183/13993003.congress-2018.PA2251. Exclusion Code: X8.
883 Truby H, Edwards BA, O’Driscoll DM, . Sleeping Well Trial: Increasing the effectiveness of treatment with continuous positive airway pressure using a weight management program in overweight adults with obstructive sleep apnoea-A stepped wedge randomised trial protocol. Nutr Diet. 2019 Feb;76(1):110–7. doi: 10.1111/1747-0080.12435. PMID: 29797800. Exclusion Code: X5.29797800
884 Trzepizur W, Cistulli PA, Glos M, . Health outcomes of continuous positive airway pressure versus mandibular advancement device for the treatment of severe obstructive sleep apnea: an individual participant data meta-analysis. Sleep. 2021 Jul 9;44(7)doi: 10.1093/sleep/zsab015. PMID: 33493338. Exclusion Code: X5.33493338
885 Trzepizur W, Recoquillon S, Pepin JL, . Mandibular advancement therapy does not reduce inflammatory and metabolic biomarkers in patients with severe OSA: a randomized controlled trial. European Respiratory Journal. 2018;52doi: 10.1183/13993003.congress-2018.OA5372. Exclusion Code: X12.
886 Trzepizur W, Recoquillon S, Vielle B, . Mandibular advancement therapy does not reduce inflammatory and metabolic biomarkers in patients with severe obstructive sleep apnea: A randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X6.
887 Tuomilehto H, Gylling H, Peltonen M, . Sustained improvement in mild obstructive sleep apnea after a diet- and physical activity-based lifestyle intervention: postinterventional follow-up. Am J Clin Nutr. 2010 Oct;92(4):688–96. doi: 10.3945/ajcn.2010.29485. PMID: 20702607. Exclusion Code: X4.20702607
888 Tuomilehto H, Seppa J, Uusitupa M, . Weight reduction and increased physical activity to prevent the progression of obstructive sleep apnea: A 4-year observational postintervention follow-up of a randomized clinical trial. [corrected]. JAMA Intern Med. 2013 May 27;173(10):929–30. doi: 10.1001/jamainternmed.2013.389. PMID: 23589169. Exclusion Code: X4.23589169
889 Tuomilehto HP, Seppa JM, Partinen MM, . Lifestyle intervention with weight reduction: first-line treatment in mild obstructive sleep apnea. Am J Respir Crit Care Med. 2009 Feb 15;179(4):320–7. doi: 10.1164/rccm.200805-669OC. PMID: 19011153. Exclusion Code: X4.19011153
890 Turnbull C, Johar A, Petousi N, . The effects of supplemental oxygen on obstructive sleep apnea during cpap withdrawal: Preliminary data from a randomised control trial. American Journal of Respiratory and Critical Care Medicine. 2017;195doi: 10.1164/ajrccm-conference.2017.A80-A. Exclusion Code: X4.
891 Turnbull C, Tang I, Craig S, . Cardiovascular and metabolic events in the MOSAIC randomised controlled trial: 5-year follow-up data. European Respiratory Journal. 2019;54doi: 10.1183/13993003.congress-2019.OA5176. Exclusion Code: X12.
892 Turner AD, Ong J, Tu A, . Neurocognitive functioning in individuals with comorbid insomnia and sleep apnea: baseline functioning and impact of treatment. Sleep. 2020;43(SUPPL 1):A42–A3. doi: 10.1093/sleep/zsaa056.105. Exclusion Code: X5.
893 ulc P. Using questionnaires to detect obstructive sleep apnoe. Cor et Vasa. 2020;62(1):44–9. doi: 10.33678/cor.2019.086. Exclusion Code: X1.
894 Uniken Venema JA, Hoekema A, Doff M. Dental side effects of long term obstructive sleep apnea therapy. A 10 year follow up study. Sleep. 2017;40:A219–A20. Exclusion Code: X5.
895 Usui K, Bradley TD, Spaak J, . Inhibition of awake sympathetic nerve activity of heart failure patients with obstructive sleep apnea by nocturnal continuous positive airway pressure. J Am Coll Cardiol. 2005 Jun 21;45(12):2008–11. doi: 10.1016/j.jacc.2004.12.080. PMID: 15963401. Exclusion Code: X9.15963401
896 Vaas V, Fisser C, Tafelmeier M, . Interactions between sleep apnea and atrial fibrillation: Pathophysiology and symptoms. Somnologie. 2021;25(1):38–44. doi: 10.1007/s11818-020-00271-8. Exclusion Code: X1.
897 Van Haesendonck G, Dieltjens M, Kastoer C, . Evaluation of the overall clinical effectiveness based on cardiovascular effects of a mandibular advancement splint in the treatment of obstructive sleep apnea. Sleep. 2017;40:A222. Exclusion Code: X5.
898 Van Ryswyk E, Anderson CS, Antic NA, . Predictors of long-term adherence to continuous positive airway pressure in patients with obstructive sleep apnea and cardiovascular disease. Sleep. 2019 Oct 9;42(10)doi: 10.1093/sleep/zsz152. PMID: 31587046. Exclusion Code: X5.31587046
899 Van Ryswyk E, Quan W, Meng R, . Effects of CPAP therapy on blood pressure variability (BPV) in people with comorbid obstructive sleep apnoea (osa) and cardiovascular disease (CVD): Save trial. Sleep Medicine. 2017;40:e334–e5. Exclusion Code: X9.
900 Varikasuvu SR, Dutt N, Sahu D. Obstructive sleep apnea and the effect of CPAP treatment on ischemia-modified albumin levels: a multi effect size meta-analysis with diagnostic test accuracy. Sleep Breath. 2019 Mar;23(1):179–91. doi: 10.1007/s11325-018-1679-6. PMID: 29948857. Exclusion Code: X6.29948857
901 Vaz Fragoso CA, Van Ness PH, Araujo KL, . Age-related differences in sleep-wake symptoms of adults undergoing polysomnography. J Am Geriatr Soc. 2015 Sep;63(9):1845–51. doi: 10.1111/jgs.13632. PMID: 26389988. Exclusion Code: X6.26389988
902 Vecchierini MF, Attali V, Collet JM, . A custom-made mandibular repositioning device for obstructive sleep apnoea-hypopnoea syndrome: the ORCADES study. Sleep Med. 2016 Mar;19:131–40. doi: 10.1016/j.sleep.2015.05.020. PMID: 26364869. Exclusion Code: X5.26364869
903 Vecchierini MF, Attali V, Collet JM, . Gender-specific efficacy of Mandibular Repositioning Device (MRD) therapy in obstructive sleep apnea (OSA) patients. Subgroup analysis of ORCADES study data. Journal of Sleep Research. 2016;25:41. doi: 10.1111/jsr.12446. Exclusion Code: X5.
904 Veitz S, Schumann D, Strobel W, . Peripherial arterial tonometry versus polysomnography in suspected obstructive sleep apnea. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.2511. Exclusion Code: X3.
905 Vena D, Azarbarzin A, Edwards BA, . Simplified OSA phenotyping of respiratory events for predicting oral appliance efficacy. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X12.
906 Vena D, Lyons O, Fernie GR, . Effect of calf muscle electrical stimulation on rostral fluid shift, snoring and obstructive sleep apnea. Sleep Med. 2019 May;57:36–42. doi: 10.1016/j.sleep.2019.01.035. PMID: 30897454. Exclusion Code: X4.30897454
907 Vidhanage TN, Kee K, Perkins A, . Efficacy of the stop-bang questionnaire as a pre-diagnostic screening tool for obstructive sleep apnoea (OSA) in patients awaiting hip or knee replacement. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12766. Exclusion Code: X5.
908 Vincent T, Pepin JL, Raymond N, . Effect of custom made vs thermoplastic heat-molded mandibular advancement devices (MADs) for Obstructive Sleep Apnea (OSA): A randomized non-inferiority trial. European Respiratory Journal. 2017;50doi: 10.1183/1393003.congress-2017.PA322. Exclusion Code: X5.
909 Vizzardi E, Sciatti E, Bonadei I, . Obstructive sleep apnoea-hypopnoea and arrhythmias: new updates. J Cardiovasc Med (Hagerstown). 2017 Jul;18(7):490–500. doi: 10.2459/jcm.0000000000000043. PMID: 25000252. Exclusion Code: X8.25000252
910 Vlachantoni IT, Gerakopoulou P, Amfilochiou A, . Facilitating factors and barriers in the screening and diagnosis process of obstructive sleep apnea in taxi drivers. Pneumon. 2015;28(1):40–7. Exclusion Code: X2.
911 Wago T, Tanaka S. Effects of continuous positive airway pressure therapy on blood pressure and arterial stiffness in obstructive sleep apnea syndrome patients with hypertension and type 2 diabetes. Journal of Sleep Research. 2016;25:164. doi: 10.1111/jsr.12446. Exclusion Code: X5.
912 Waldman LT, Parthasarathy S, Villa KF, . Impacts of excessive sleepiness associated with obstructive sleep apnea on work productivity. Sleep. 2018;41:A175. Exclusion Code: X8.
913 Walker M, Blackwell JN, Stafford P, . Daytime QT by routine 12-lead ECG is prolonged in patients with severe obstructive sleep apnea. Sleep Disorders. 2020;2020doi: 10.1155/2020/3029836. Exclusion Code: X8.
914 Walsh J, Maddison K, Baker V, . Predictors of response to a novel mandibular advancement device (Oventus o2VentT) in patients with OSA. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12766. Exclusion Code: X5.
915 Wang CC, Chuang HC, Hsiao HT, . Applying computational fluid dynamics to optimize adjustments on oral appliance used for the treatment of snoring and obstructive sleep apnea. Sleep Medicine. 2017;40:e136. Exclusion Code: X4.
916 Wang ML, Wang C, Tuo M, . Cognitive effects of treating obstructive sleep apnea: a meta-analysis of randomized controlled trials. J Alzheimers Dis. 2020;75(3):705–15. doi: 10.3233/jad-200088. PMID: 32310179. Exclusion Code: X8.32310179
917 Wang Y, Wang L. Correlation research on obstructive sleep apnea syndrome and leukodystrophy. Acta Medica Mediterranea. 2019;35:645–9. doi: 10.19193/0393-6384_2019_1s_98. Exclusion Code: X8.
918 Waseem R, Chan MTV, Wang CY, . Diagnostic performance of the STOP-Bang questionnaire as a screening tool for obstructive sleep apnea in different ethnic groups. J Clin Sleep Med. 2021 Mar 1;17(3):521–32. doi: 10.5664/jcsm.8940. PMID: 33112227. Exclusion Code: X2.33112227
919 Wei CY, He M, Yan H, . Treatment effects of short-term continuous positive airway pressure on blood glucose control in type 2 diabetic patients with obstructive sleep apnea syndrome. International Journal of General Medicine. 2020;13:1567–73. doi: 10.2147/IJGM.S280837. Exclusion Code: X6.33364818
920 West SD, Hughes J, Prudon B. Baseline data from the rosa trial: a randomised controlled trial of the effect of CPAP on diabetic macular oedema in people with concurrent obstructive sleep apnoea. Thorax. 2016;71:A124. doi: 10.1136/thoraxjnl-2016-209333.215. Exclusion Code: X12.
921 West SD, Prudon B, Hughes J, . Continuous positive airway pressure effect on visual acuity in patients with type 2 diabetes and obstructive sleep apnoea: a multicentre randomised controlled trial. Eur Respir J. 2018 Oct;52(4)doi: 10.1183/13993003.01177-2018. PMID: 30166323. Exclusion Code: X6.30166323
922 West SD, Prudon B, Mohammed SB, . Results of the ROSA trial: a randomised controlled trial of the effect of CPAP on diabetic macular oedema in people with concurrent obstructive sleep apnoea. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X12.
923 Westlake K, Dostalova V, Plihalova A, . The clinical impact of systematic screening for obstructive sleep apnea in a type 2 diabetes population—adherence to the screening-diagnostic process and the acceptance and adherence to the cpap therapy compared to regular sleep clinic patients. Frontiers in Endocrinology. 2018;9doi: 10.3389/fendo.2018.00714. Exclusion Code: X8.
924 Westlake K, Plihalova A, Pretl M, . Screening for obstructive sleep apnea syndrome in patients with type 2 diabetes mellitus: a prospective study on sensitivity of Berlin and STOP-Bang questionnaires. Sleep Med. 2016 Oct;26:71–6. doi: 10.1016/j.sleep.2016.07.009. PMID: 27613528. Exclusion Code: X5.27613528
925 Wheeler NC, Wing JJ, O’Brien LM, . Expiratory positive airway pressure for sleep apnea after stroke: a randomized, crossover trial. J Clin Sleep Med. 2016 Sep 15;12(9):1233–8. doi: 10.5664/jcsm.6120. PMID: 27306393. Exclusion Code: X2.27306393
926 White DE, Bartley J, Campbell AJ, . Preliminary evaluation of second-generation n-cpap machine pilot sleep study data. Sleep. 2018;41:A204. Exclusion Code: X5.
927 Wieczorek T, Lorenc M, Martynowicz H, . Parasomnias and obstructive sleep apnea syndrome: In search for a parasomnia evaluating tool appropriate for osas screening. Family Medicine and Primary Care Review. 2018;20(2):176–81. doi: 10.5114/fmpcr.2018.76464. Exclusion Code: X3.
928 Wimms A, Kelly J, Morrell M. Merge study: the effect of CPAP on energy and vitality in patients with mild OSA. Journal of Sleep Research. 2018;27doi: 10.1111/jsr.12766. Exclusion Code: X12.
929 Wimms A, Kelly JL, Calverley PM, . The MERGE study: The effect of continuous positive airway pressure on energy and vitality in patients with mild obstructive sleep apnea. American Journal of Respiratory and Critical Care Medicine. 2019;199(9). Exclusion Code: X6.
930 Witton A, Earnshaw L, Upson A, . Outcome of Mandibular Advancement Device (MAD) referrals following a clinician led dental assessment in patients with Obstructive Sleep Apnoea Syndrome (OSAS). European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.1348. Exclusion Code: X8.
931 Woehrle H, Oldenburg O, Young P, . Long-term mortality in sleep apnea (SA) patients treated with positive airway pressure (PAP) therapy: Analysis of a large German healthcare database. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X8.
932 Wohlgemuth W, Fins A, Tutek J, . Longitudinal measurement invariance of the insomnia severity index in veterans with sleep apnea. Sleep. 2020;43(SUPPL 1):A211. doi: 10.1093/sleep/zsaa056.548. Exclusion Code: X3.
933 Wons AM, Kohler M. Established vascular effects of continuous positive airway pressure therapy in patients with obstructive sleep apnoea-an update. Journal of Thoracic Disease. 2015;7(5):912–9. doi: 10.3978/j.issn.2072-1439.2015.03.06. Exclusion Code: X8.26101649
934 Woodson BT, Steward DL, Weaver EM, . A randomized trial of temperature-controlled radiofrequency, continuous positive airway pressure, and placebo for obstructive sleep apnea syndrome. Otolaryngol Head Neck Surg. 2003 Jun;128(6):848–61. doi: 10.1016/s0194-5998(03)00461-3. PMID: 12825037. Exclusion Code: X4.12825037
935 Wozniak D, Bourne R, Peretz G, . Obstructive sleep apnea in patients with primary-open angle glaucoma: no role for a screening program. J Glaucoma. 2019 Aug;28(8):668–75. doi: 10.1097/ijg.0000000000001296. PMID: 31162178. Exclusion Code: X8.31162178
936 Wu CH, Lee JH, Kuo TBJ, . Improving the diagnostic ability of the sleep apnea screening system based on oximetry by using physical activity data. Journal of Medical and Biological Engineering. 2020;40(6):858–67. doi: 10.1007/s40846-020-00566-z. Exclusion Code: X3.
937 Wu WT, Tsai SS, Lin YJ, . Utility of overnight pulse oximeter as a screening tool for sleep apnea to assess the 8-year risk of cardiovascular disease: Data from a large-scale bus driver cohort study. Int J Cardiol. 2016 Dec 15;225:206–12. doi: 10.1016/j.ijcard.2016.09.110. PMID: 27728865. Exclusion Code: X2.27728865
938 Wu X, Liu Z, Chang SC, . Screening and managing obstructive sleep apnoea in nocturnal heart block patients: an observational study. Respir Res. 2016 Feb 16;17:16. doi: 10.1186/s12931-016-0333-8. PMID: 26879052. Exclusion Code: X10.26879052
939 Xia M, Liu S, Ji N, . BMI 35 kg/m(2) does not fit everyone: a modified STOP-Bang questionnaire for sleep apnea screening in the Chinese population. Sleep Breath. 2018 Dec;22(4):1075–82. doi: 10.1007/s11325-017-1610-6. PMID: 29322383. Exclusion Code: X7.29322383
940 Xie J, Sert Kuniyoshi FH, Covassin N, . Excessive daytime sleepiness independently predicts increased cardiovascular risk after myocardial infarction. J Am Heart Assoc. 2018 Jan 19;7(2)doi: 10.1161/jaha.117.007221. PMID: 29352093. Exclusion Code: X2.29352093
941 Xie L, Wu Q, Hu W, . Performance of brief ICF-sleep disorders and obesity core set in obstructive sleep apnea patients. Respir Res. 2020 Jun 22;21(1):156. doi: 10.1186/s12931-020-01404-1. PMID: 32571309. Exclusion Code: X10.32571309
942 Xiong M, Hu W, Dong M, . The screening value of ESS, SACS, BQ, and SBQ on obstructive sleep apnea in patients with chronic obstructive pulmonary disease. Int J Chron Obstruct Pulmon Dis. 2019;14:2497–505. doi: 10.2147/copd.s223354. PMID: 32009782. Exclusion Code: X10.32009782
943 Xu H, Wang H, Guan J, . Effects of continuous positive airway pressure on neurocognitive architecture and function in patients with obstructive sleep apnoea: study protocol for a multicentre randomised controlled trial. BMJ Open. 2017 May 25;7(5):e014932. doi: 10.1136/bmjopen-2016-014932. PMID: 28550021. Exclusion Code: X6.28550021
944 Xu H, Zhao X, Shi Y, . Development and validation of a simple-to-use clinical nomogram for predicting obstructive sleep apnea. BMC Pulm Med. 2019 Jan 18;19(1):18. doi: 10.1186/s12890-019-0782-1. PMID: 30658615. Exclusion Code: X3.30658615
945 Xu P, Hui CK, Lui MM, . Long-term continuous positive airway pressure treatment for obstructive sleep apnea reduces incident diabetes risk in a Chinese cohort. American Journal of Respiratory and Critical Care Medicine. 2018;197(MeetingAbstracts). Exclusion Code: X12.
946 Yadollahi A, Giannouli E, Moussavi Z. Sleep apnea monitoring and diagnosis based on pulse oximetry and tracheal sound signals. Med Biol Eng Comput. 2010 Nov;48(11):1087–97. doi: 10.1007/s11517-010-0674-2. PMID: 20734154. Exclusion Code: X8.20734154
947 Yaffe K, Laffan AM, Harrison SL, . Sleep-disordered breathing, hypoxia, and risk of mild cognitive impairment and dementia in older women. JAMA. 2011 Aug 10;306(6):613–9. doi: 10.1001/jama.2011.1115. PMID: 21828324. Exclusion Code: X8.21828324
948 Yagihara F, Lorenzi-Filho G, Santos-Silva R. Nasal dilator strip is an effective placebo intervention for severe obstructive sleep apnea. J Clin Sleep Med. 2017 Feb 15;13(2):215–21. doi: 10.5664/jcsm.6450. PMID: 27707442. Exclusion Code: X10.27707442
949 Yagihara F, Lorenzi-Filho G, Santos-Silva R. Patients with obstructive sleep apnea are perceived as younger after treatment with continuous positive airway pressure. Sleep. 2018;41:A194. Exclusion Code: X6.
950 Yagihara F, Lorenzi-Filho G, Santos-Silva R. Patients with OSA are perceived as younger following treatment with CPAP. Chest. 2019 Sep;156(3):553–61. doi: 10.1016/j.chest.2019.03.015. PMID: 30926396. Exclusion Code: X10.30926396
951 Yalın OÖ, Yılmaz İA, Sungur MA, . Obstructive sleep apnea syndrome, periodic limb movements and related factors. Turk Noroloji Dergisi. 2015;21(3):90–4. doi: 10.4274/tnd.25993. Exclusion Code: X6.
952 Yamakoshi S, Kasai T, Tomita Y, . Comparison of clinical features and polysomnographic findings between men and women with sleep apnea. Journal of Thoracic Disease. 2016;8(1):145–51. doi: 10.3978/j.issn.2072-1439.2016.01.49. Exclusion Code: X3.26904223
953 Yan B, Jin Y, Hu Y, . Effects of continuous positive airway pressure on elderly patients with obstructive sleep apnea: a meta-analysis. Med Sci (Paris). 2018 Oct;34 Focus issue F1:66–73. doi: 10.1051/medsci/201834f112. PMID: 30403178. Exclusion Code: X8.30403178
954 Yang PR, Korownyk C. Continuous positive airway pressure. Can Fam Physician. 2018 Oct;64(10):745. PMID: 30315020. Exclusion Code: X8.30315020
955 Yang Q, Li H, Wu W, . Effect of continuous positive airway pressure on allergic rhinitis in patients with obstructive sleep apnea–hypopnea syndrome. Therapeutics and Clinical Risk Management. 2018;14:1507–13. doi: 10.2147/TCRM.S170548. Exclusion Code: X8.30197520
956 Yang SJ, Jiang XT, Zhang XB, . Does continuous positive airway pressure reduce aldosterone levels in patients with obstructive sleep apnea? Sleep Breath. 2016 Sep;20(3):921–8. doi: 10.1007/s11325-015-1311-y. PMID: 26779900. Exclusion Code: X6.26779900
957 Yang X, Yang J, Yang C, . Continuous positive airway pressure can improve depression in patients with obstructive sleep apnoea syndrome: a meta-analysis based on randomized controlled trials. J Int Med Res. 2020 Mar;48(3):300060519895096. doi: 10.1177/0300060519895096. PMID: 32208858. Exclusion Code: X8.32208858
958 Yang Y, Ning Y, Wen W, . CPAP is associated with decreased risk of AF recurrence in patients with OSA, especially those younger and slimmer: a meta-analysis. J Interv Card Electrophysiol. 2020 Sep;58(3):369–79. doi: 10.1007/s10840-020-00738-6. PMID: 32472281. Exclusion Code: X8.32472281
959 Yilmaz Avci A, Avci S, Lakadamyali H, . Association between hypoxia parameters with white matter hyperintensity and silent cerebral infarcts on brain magnetic resonance images in patients with obstructive sleep apnea. Journal of Neurological Sciences. 2016;33(3):459–72. Exclusion Code: X6.
960 Yoshihisa A, Yokokawa T, Suzuki S, . Positive airway pressure in HFpEF patients with sleep-disordered breathing. Journal of Cardiac Failure. 2016;22(9):S161. Exclusion Code: X8.
961 Yoshioka Y, Yamamoto U, Tsuda H, . The factors that affect to the better compliance of mandibular advancement device when compared with continuous positive airway pressure in the patients with moderate to severe sleep apnea syndrome. Sleep Medicine. 2017;40:e357–e8. Exclusion Code: X6.
962 Yosunkaya S, Kutlu R, Cihan FG. Evaluation of depression and quality of life in patients with obstructive sleep apnea syndrome. Niger J Clin Pract. 2016 Sep–Oct;19(5):573–9. doi: 10.4103/1119-3077.188703. PMID: 27538542. Exclusion Code: X5.27538542
963 Young T, Finn L, Peppard PE, . Sleep disordered breathing and mortality: eighteen-year follow-up of the Wisconsin sleep cohort. Sleep. 2008 Aug;31(8):1071–8. PMID: 18714778. Exclusion Code: X8.18714778
964 Yu J, Zhou Z, McEvoy RD, . Association of positive airway pressure with cardiovascular events and death in adults with sleep apnea: a systematic review and meta-analysis. Jama. 2017 Jul 11;318(2):156–66. doi: 10.1001/jama.2017.7967. PMID: 28697252. Exclusion Code: X8.28697252
965 Zamora T, Deering S, Stepnowsky CJ. The sleep apnea quality of life index as a patient-centered measure. Sleep. 2019;42:A213. doi: 10.1093/sleep/zsz067.531. Exclusion Code: X8.
966 Zamora T, Stepnowsky CJ. Effect of CPAP therapy on depressive symptoms. Sleep. 2018;41:A219. Exclusion Code: X8.
967 Zaremba S, Brueckmann B, Malviya S, . Effects of CPAP treatment on respiratory function in the recovery room following weight loss-surgery: A cross-over design, randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. 2013;187. Exclusion Code: X2.
968 Zhang C, Fang Y. Effect of continuous positive airway pressure therapy on stroke risk and rehabilitation in population with obstructive sleep apnea: A prisma-compliant systematic review and meta-analysis. Neurology Asia. 2021;26(2):243–9. Exclusion Code: X8.
969 Zhang C, Ramsay M, Drakatos P, . The clinical usefulness of a self-administered questionnaire for sleep-disordered breathing in patients with neuromuscular disease. Journal of Thoracic Disease. 2018;10:S153–S9. doi: 10.21037/jtd.2017.06.40. Exclusion Code: X5.29445539
970 Zhang T, Jiang C, Huang QL, . Continuous positive airway pressure and oral appliances on treatment of obstructive sleep apnea hypopnea syndrome: A meta-analysis. Medical Journal of Chinese People’s Liberation Army. 2018;43(7):621–7. doi: 10.11855/j.issn.0577-7402.2018.07.15. Exclusion Code: X1.
971 Zhang XL, Dai HP, Zhang H, . Obstructive sleep apnea in patients with fibrotic interstitial lung disease and COPD. J Clin Sleep Med. 2019 Dec 15;15(12):1807–15. doi: 10.5664/jcsm.8090. PMID: 31855166. Exclusion Code: X10.31855166
972 Zhang Y, Ren R, Yang L, . The effect of treating obstructive sleep apnea with continuous positive airway pressure on posttraumatic stress disorder: A systematic review and meta-analysis with hypothetical model. Neurosci Biobehav Rev. 2019 Jul;102:172–83. doi: 10.1016/j.neubiorev.2019.03.019. PMID: 31042558. Exclusion Code: X8.31042558
973 Zhang Y, Su X, He J, . Effect of continuous positive airway pressure on prothrombotic markers in obstructive sleep apnea and hypopnea syndrome patients: a meta-analysis. Chest. 2016;149(4):A554. doi: 10.1016/j.chest.2016.02.579. Exclusion Code: X6.
974 Zhang Z, Qi M, Hügli G, . Predictors of impaired cerebral perfusion and cerebral desaturation in patients with obstructive sleep apnea syndrome. Journal of Sleep Research. 2020;29(SUPPL 1)doi: 10.1111/jsr.13181. Exclusion Code: X5.
975 Zheng D, Xu Y, You S, . Effects of continuous positive airway pressure on depression and anxiety symptoms in patients with obstructive sleep apnoea: results from the sleep apnoea cardiovascular Endpoint randomised trial and meta-analysis. EClinicalMedicine. 2019 May–Jun;11:89–96. doi: 10.1016/j.eclinm.2019.05.012. PMID: 31312807. Exclusion Code: X6.31312807
976 Zheng W, Chen X, Huang J, . Blood oxygen accumulation distribution area index is associated with erectile dysfunction in patients with sleep apnea—results from a cross-sectional study. Sexual Medicine. 2020;8(1):36–44. doi: 10.1016/j.esxm.2019.11.001. Exclusion Code: X8.32008979
977 Zhou J, Li DH, Zhu PF, . Effect of mandibular advancement device on the stomatognathic system in patients with mild-to-moderate obstructive sleep apnoea-hypopnoea syndrome. J Oral Rehabil. 2020 Jul;47(7):889–901. doi: 10.1111/joor.12982. PMID: 32306424. Exclusion Code: X5.32306424
978 Zhou Y, Shu D, Xu H, . Validation of novel automatic ultra-wideband radar for sleep apnea detection. Journal of Thoracic Disease. 2020;12(4):1286–95. doi: 10.21037/jtd.2020.02.59. Exclusion Code: X3.32395265
979 Zhu B, Ma C, Chaiard J, . Effect of continuous positive airway pressure on glucose metabolism in adults with type 2 diabetes: a systematic review and meta-analysis of randomized controlled trials. Sleep Breath. 2018 May;22(2):287–95. doi: 10.1007/s11325-017-1554-x. PMID: 28812180. Exclusion Code: X6.28812180
980 Zhu D, Wu M, Cao Y, . Heated humidification did not improve compliance of positive airway pressure and subjective daytime sleepiness in obstructive sleep apnea syndrome: A meta-analysis. PLoS One. 2018;13(12):e0207994. doi: 10.1371/journal.pone.0207994. PMID: 30517168. Exclusion Code: X8.30517168
981 Zhu K, Li M, Akbarian S, . Vision-based heart and respiratory rate monitoring during sleep-a validation study for the population at risk of sleep apnea. IEEE Journal of Translational Engineering in Health and Medicine. 2019;7doi: 10.1109/JTEHM.2019.2946147. Exclusion Code: X3.
982 Zota IM, Sascău RA, Stătescu C, . Short-term CPAP improves biventricular function in patients with moderate-severe OSA and cardiometabolic comorbidities. Diagnostics. 2021;11(5)doi: 10.3390/diagnostics11050889. Exclusion Code: X5.
983 Zou B, Guo X, Liu Y, . Randomized controlled trial of continuous positive airway pressure treatment of resistant hypertensive patients combined with obstructive sleep apnea/hypopnea syndrome. International Journal of Clinical and Experimental Medicine. 2018;11(11):11965–72. Exclusion Code: X9.
984 Zou D, Celik Y, Lindberg T, . Effect of CPAP treatment on adhesion molecules in coronary artery disease with nonsleepy obstructive sleep apnoea: The RICCADSA randomized controlled trial. European Respiratory Journal. 2020;56doi: 10.1183/13993003.congress-2020.4740. Exclusion Code: X6.
985 Zulfikar S, Kirisoglu CE, Dincer A, . A multi-centre evaluation of a mouthpiece device for the treatment of obstructive sleep apnea syndrome. Sleep. 2018;41:A205. Exclusion Code: X8.