# Appendix B Additional Methods Information

## Appendix B1 Original Search Strategies

### PubMed, Interventions, 1-3-2021

Search Number | Query | Filters | Results
1 | “Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw] | | 45,620
2 | “Continuous Positive Airway Pressure”[Mesh] OR “Intermittent Positive-Pressure Ventilation”[MeSH] OR “Mandibular Advancement/instrumentation”[Mesh] OR “Mandibular Prosthesis”[MeSH Terms] OR “Positive-Pressure Respiration”[Mesh:NoExp] | | 27,441
3 | “Biphasic Intermittent Positive Airway Pressure”[tw] OR BiPAP[tw] OR “Continuous Positive Airway Pressure”[tw] OR CPAP[tw] OR “IPPV”[tw] OR “Inspiratory Positive-Pressure Ventilation”[tw] OR “Inspiratory Positive Pressure Ventilation”[tw] OR “Intermittent Positive Pressure Ventilation”[tw] OR “mandibular advancement device”[tw] OR “mandibular advancement devices”[tw] OR “oral appliance”[tw] OR “oral appliances”[tw] OR PAP[tiab] | | 39,066
4 | #1 AND (#2 OR #3) | | 10,423
5 | #1 AND (#2 OR #3) | English | 9,124
6 | (#5 AND Humans[Mesh:NOEXP]) OR (#5 NOT Animals[Mesh:NOEXP]) | | 9,097
7 | #6 AND (“2015/04/01”[Date - Publication] : “3000”[Date - Publication]) | | 3,341
8 | #6 AND (“2015/04/01”[Date - Publication] : “3000”[Date - Publication]) | Adult: 19+ years | 1,485
9 | #7 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | | 2,639
10 | #8 OR #9 | | 2,944
11 | (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Periodical Index[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type]) | | 4,306,169
12 | #10 NOT #11 | | 2,469
13 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | | 352,518
14 | #12 AND #13 | | 225
15 | ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | | 808,286
16 | #12 AND #15 | | 373
17 | #16 NOT #14 | | 349

### PubMed, Screening, 1-3-2021

Search Number | Query | Filters | Results
1 | “Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw] | | 45,620
2 | “Body Mass Index”[Mesh] OR “Body Weight”[Mesh] OR “Decision Support Techniques”[Mesh] OR “Obesity”[Mesh] OR Psychometrics[Mesh] OR “Snoring”[Mesh] OR “Surveys and Questionnaires”[Mesh] OR instrument[tiab] OR instruments[tiab] OR questionnaire[tiab] OR questionnaires[tiab] OR scale[tiab] OR scales[tiab] | | 2,680,695
3 | Oximetry[MeSH] OR “Berlin Questionnaire” OR “Clinical prediction tool*” OR “Clinical prediction rule*” OR “Clinical prediction score*” OR “Craniofacial structure*” OR “Epworth Sleepiness Scale” OR Mallampati OR “Multivariable Apnea Prediction Index” OR “Multivariable Apnoea Prediction Index” OR NAMES OR “Neck circumference” OR “Nocturnal choking” OR “Nocturnal gasping” OR oximetry OR oximetries OR “oxygen desaturation” OR photoplethysmography OR “Sleep Apnea Clinical Score” OR snoring OR “Snoring Scale” OR sleepiness OR “STOP-BAG” OR “STOP-Bang” OR “STOP Questionnaire” OR “Wisconsin Sleep Questionnaire” | | 181,693
4 | #1 AND #2 | | 17,390
5 | #1 AND #3 | | 13,398
6 | “Diagnostic Tests, Routine”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “Mass Screening”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Diagnosis”[Mesh] OR “Reproducibility of Results”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR accuracy[tw] OR diagno*[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw] OR “predictive value”[tw] OR reproducib*[tw] OR ROC[tw] OR screen[tw] OR screening[tiab] OR sensitivity[tw] OR specificity[tw] | | 12,030,098
7 | #4 AND #6 | | 15,039
8 | #5 OR #7 | | 21,063
9 | #5 OR #7 | English | 18,780
10 | (#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP]) | | 18,651
11 | #10 AND (“2015/04/01”[Date - Publication] : “3000”[Date - Publication]) | | 6,485
12 | #10 AND (“2015/04/01”[Date - Publication] : “3000”[Date - Publication]) | Adult: 19+ years | 3,458
13 | #11 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | | 4,085
14 | #12 OR #13 | | 5,114
15 | (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Periodical Index[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type]) | | 4,306,169
16 | #14 NOT #15 | | 4,783
17 | ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | | 808,286
18 | #16 AND #17 | | 387
19 | “Prospective Studies”[Mesh] OR “Cross-Sectional Studies”[MeSH] OR (prospective[tw] AND cohort[tw]) OR “cross-section*”[tw] OR “cross section*”[tw] OR prognostic*[tiab] OR prospectively[tiab] | | 1,481,555
20 | #16 AND #19 | | 1,364
21 | #20 NOT #18 | | 1,270

### PubMed, CQ 1 Search (Barriers to Screening), 1-3-2021

Search Number | Query | Filters | Results
1 | “Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw] | | 45,620
2 | “Surveys and Questionnaires”[Mesh] OR (“Mass Screening”[Mesh] OR screening[tiab]) OR “Predictive Value of Tests”[Mesh] OR (“Diagnostic Tests, Routine”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Diagnosis”[Mesh] OR “Reproducibility of Results”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “predictive value”[tw] OR sensitivity[tw] OR specificity[tw] OR accuracy[tw] OR screen[tw] OR diagno*[tw] OR ROC[tw] OR reproducib*[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw]) OR (“Neck circumference”[All Fields] OR Mallampati OR “Nocturnal choking”[All Fields] OR “Nocturnal gasping”[All Fields] OR (“Body Mass Index”[Mesh]) OR “Body Weight”[Mesh] OR “Obesity”[Mesh]) OR “Snoring”[Mesh] OR snoring OR Sleepiness) | | 12,493,985
3 | #1 AND #2 | | 35,821
4 | #1 AND (“Decision Support Techniques”[Mesh] OR “Clinical prediction tool*” OR “Clinical prediction rule*” OR “Clinical prediction score*”) | | 183
5 | “Epworth Sleepiness Scale”[All Fields] OR “STOP Questionnaire”[All Fields] OR “STOP-BAG”[All Fields] OR “STOP-Bang”[All Fields] OR “Berlin Questionnaire”[All Fields] OR “Wisconsin Sleep Questionnaire”[All Fields] OR “Multivariable Apnea Prediction Index”[All Fields] OR “Multivariable Apnoea Prediction Index”[All Fields] OR “Snoring Scale”[All Fields] OR “Sleep Apnea Clinical Score”[All Fields] | | 4,980
6 | Photoplethysmography | | 3,217
7 | #3 OR #4 OR #5 OR #6 | | 41,038
8 | “Focus Groups”[MeSH Terms] OR “Grounded Theory”[MeSH Terms] OR “Interviews as Topic”[MeSH Terms] OR “Qualitative Research”[MeSH Terms] OR “attitudes”[Title/Abstract] OR “barrier*”[Title/Abstract] OR “facilitators”[Title/Abstract] OR “experiences”[Title/Abstract] OR “perceptions”[Title/Abstract] OR “perspectives”[Title/Abstract] OR “preferences”[Title/Abstract] OR “values”[Title/Abstract] OR “viewpoints”[Title/Abstract] OR “views”[Title/Abstract] OR “critical interpretive”[Title/Abstract] OR “critical race”[Title/Abstract] OR “critical realism”[Title/Abstract] OR “critical realist”[Title/Abstract] OR “ethnograph*”[Title/Abstract] OR “Grounded Theory”[Title/Abstract] OR “phenomenolog*”[Title/Abstract] OR “case study”[Title/Abstract] OR “content analysis”[Title/Abstract] OR “descriptive”[Title/Abstract] OR “focus group”[Title/Abstract] OR “Focus Groups”[Title/Abstract] OR “interview*”[Title/Abstract] OR “mixed design”[Title/Abstract] OR “mixed methods”[Title/Abstract] OR “qualitative”[Title/Abstract] | | 2,575,962
9 | #7 AND #8 | | 4,493
10 | #7 AND #8 | Humans | 3,934
11 | #7 AND #8 | Humans, English | 3,588
12 | #7 AND #8 | in the last 10 years, Humans, English | 2,126
13 | barrier*[tiab] | | 312,282
14 | #9 AND #13 | | 156

### PubMed, CQ 2 Search (AHI), 1-3-2021

Search Number | Query | Filters | Results
1 | “Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw] | | 45,620
2 | “Apnea hypopnea Index”[All Fields] OR “Apnea/hypopnea index”[All Fields] OR “Apnoea hypopnea index”[All Fields] OR “Apnoea hypopnoea index”[All Fields] OR “Apnoea/hypopnoea index”[All Fields] | | 9,102
3 | #1 AND #2 | | 8,777
4 | “Cardiovascular Diseases”[Mesh] OR “Cerebrovascular Disorders”[Mesh] OR “Cognition Disorders”[Mesh] OR “Fatal Outcome”[Mesh] OR “Headache”[Mesh] OR “Cognitive Dysfunction”[Mesh] OR “Mortality”[Mesh] OR “mortality” [Subheading] OR “Motor Vehicles”[Mesh] OR “Myocardial Infarction”[Mesh] OR “Patient Outcome Assessment”[Mesh] OR “Outcome Assessment, Health Care”[Mesh] OR “Quality of Life”[Mesh] OR Stroke[Mesh] | | 4,092,611
5 | cardiovascular*[tiab] OR cerebrovasc*[tiab] OR cognit*[tiab] OR headache[tiab] OR “heart failure”[tiab] OR mortality[tiab] OR “motor vehicle”[tiab] OR “motor vehicles”[tiab] OR outcome*[tiab] OR “quality of life”[tiab] | | 3,428,704
6 | #4 OR #5 | | 6,046,109
7 | #3 AND #6 | | 4,738
8 | #3 AND #6 | English | 4,485
9 | (#8 AND Humans[Mesh:NOEXP]) OR (#8 NOT Animals[Mesh:NOEXP]) | | 4,480
10 | #9 AND (“2015/04/01”[Date - Publication] : “3000”[Date - Publication]) | | 2,121
11 | #9 AND (“2015/04/01”[Date - Publication] : “3000”[Date - Publication]) | Adult: 19+ years | 1,322
12 | #10 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | | 1,389
13 | #11 OR #12 | | 1,740
14 | (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Periodical Index[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type]) | | 4,306,169
15 | #13 NOT #14 | | 1,708
16 | ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | | 808,286
17 | #15 AND #16 | | 229

### Cochrane Library, Interventions, 1-11-2021

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] OR [mh “Sleep Apnea, Obstructive”] OR “Obstructive Sleep Apneas” OR “Obstructive Sleep Apnea” OR “Obstructive Sleep Apnoea” OR “Obstructive Sleep Apnoeas” OR OSAHS OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing” | 6,781
#2 | [mh “Continuous Positive Airway Pressure”] OR [mh “Intermittent Positive-Pressure Ventilation”] OR [mh “Mandibular Advancement”/IS] OR [mh “Mandibular Prosthesis”] OR [mh ^“Positive-Pressure Respiration”] OR BiPAP OR “Biphasic Intermittent Positive Airway Pressure” OR “Continuous Positive Airway Pressure” OR CPAP OR “Intermittent Positive Pressure Ventilation” OR “IPPV” OR “Inspiratory Positive-Pressure Ventilation” OR “Inspiratory Positive Pressure Ventilation” OR “mandibular advancement device” OR “mandibular advancement devices” OR “oral appliance” OR “oral appliances” OR PAP:ti,ab | 9,915
#3 | #1 AND #2 | 3,266
#4 | #3 NOT ([mh animals] NOT [mh humans]) | 3,266
#5 | #4 NOT (Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) | 3,147
#6 | MeSH descriptor: [Adult] explode all trees | 462,536
#7 | #5 AND #6 | 888
#8 | #5 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 3,077
#9 | #7 OR #8 | 3,081
#10 | #9 with Cochrane Library publication date Between Apr 2015 and Jan 2021 | 1,971
#11 | “randomized controlled trial”:pt OR “randomized controlled trial as topic”:pt OR “single-blind method”:pt OR “double-blind method”:pt OR “random allocation”:pt | 499,052
#12 | #10 AND #11 | 294

### Cochrane Library, Screening, 1-11-2021

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] OR [mh “Sleep Apnea, Obstructive”] OR “Obstructive Sleep Apneas” OR “Obstructive Sleep Apnea” OR “Obstructive Sleep Apnoea” OR “Obstructive Sleep Apnoeas” OR OSAHS OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing” | 6,781
#2 | [mh “Body Mass Index”] OR [mh “Body Weight”] OR [mh “Decision Support Techniques”] OR [mh “Obesity”] OR [mh Psychometrics] OR [mh “Snoring”] OR [mh “Surveys and Questionnaires”] OR instrument:ti,ab OR instruments:ti,ab OR questionnaire:ti,ab OR questionnaires:ti,ab OR scale:ti,ab OR scales:ti,ab | 317,325
#3 | [mh Oximetry] OR “Berlin Questionnaire” OR “Clinical prediction tool*” OR “Clinical prediction rule*” OR “Clinical prediction score*” OR “Craniofacial structure*” OR “Epworth Sleepiness Scale” OR Mallampati OR “Multivariable Apnea Prediction Index” OR “Multivariable Apnoea Prediction Index” OR NAMES OR “Neck circumference” OR “Nocturnal choking” OR “Nocturnal gasping” OR oximetry OR oximetries OR “oxygen desaturation” OR photoplethysmography OR “Sleep Apnea Clinical Score” OR snoring OR “Snoring Scale” OR sleepiness OR “STOP-BAG” OR “STOP-Bang” OR “STOP Questionnaire” OR “Wisconsin Sleep Questionnaire” | 13,722
#4 | #1 AND #2 | 2,304
#5 | #1 AND #3 | 2,413
#6 | [mh “Diagnosis”] OR [mh “Diagnostic Tests, Routine”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR [mh “Mass Screening”] OR [mh “Predictive Value of Tests”] OR [mh “ROC Curve”] OR [mh “Reproducibility of Results”] OR [mh “Sensitivity and Specificity”] OR accuracy OR diagno* OR “false negative” OR “false positive” OR “likelihood ratio” OR “predictive value” OR ROC OR reproducib* OR screen OR screening OR sensitivity OR specificity | 568,224
#7 | #4 AND #6 | 1,490
#8 | #5 OR #7 | 2,975
#9 | #8 NOT ([mh animals] NOT [mh humans]) | 2,975
#10 | #9 NOT (Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) | 2,831
#11 | MeSH descriptor: [Adult] explode all trees | 462,536
#12 | #10 AND #11 | 1,023
#13 | #12 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 1,010
#14 | #12 OR #13 | 1,023
#15 | #14 with Cochrane Library publication date Between Apr 2015 and Jan 2021 | 338
#16 | #15 AND (“randomized controlled trial”:pt OR “randomized controlled trial as topic”:pt OR “single-blind method”:pt OR “double-blind method”:pt OR “random allocation”:pt) | 312
#17 | #15 AND ([mh “Prospective Studies”] OR [mh “Cross-Sectional Studies”] OR (prospective AND cohort) OR “cross-section*” OR “cross section*” OR prognostic*:ti,ab OR prospectively:ti,ab) | 88
#18 | #17 NOT #16 | 11

### Embase, Interventions, 1-4-2021

Query | Search | Results
#1 | ‘obstructive sleep apneas’ OR ‘obstructive sleep apnea’/exp OR ‘obstructive sleep apnea’ OR ‘obstructive sleep apnea syndrome’/exp OR ‘obstructive sleep apnea syndrome’ OR ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’/exp OR ‘obstructive sleep apnoea’ OR osahs OR ((‘sleep apnea’/exp OR ‘sleep apnea’) AND (‘hypopnea’/exp OR hypopnea)) OR ‘sleep apnea syndromes’/exp OR ‘sleep apnea syndromes’ OR ‘sleep disordered breathing’/exp OR ‘sleep disordered breathing’ | 86,778
#2 | ‘continuous positive airway pressure’/exp OR ‘cpap device’/exp OR ‘intermittent positive pressure ventilation’/exp OR ‘mandible prosthesis’/exp OR ‘positive end expiratory pressure’/exp/mj OR ‘positive pressure ventilation’/exp OR bipap OR ‘biphasic intermittent positive airway pressure’ OR ‘continuous positive airway pressure’ OR cpap OR ‘intermittent positive pressure ventilation’ OR ‘ippv’ OR ‘inspiratory positive-pressure ventilation’ OR ‘inspiratory positive pressure ventilation’ OR ‘mandibular advancement device’ OR ‘mandibular advancement devices’ OR ‘oral appliance’ OR ‘oral appliances’ OR pap:ti,ab | 97,199
#3 | #1 AND #2 | 21,371
#4 | #3 AND [humans]/lim | 20,299
#5 | #4 NOT ([editorial]/lim OR [letter]/lim OR [note]/lim) | 18,156
#6 | #5 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 9,184
#7 | #5 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 16,252
#8 | #6 OR #7 | 16,739
#9 | #8 AND [1-4-2015]/sd NOT [5-1-2021]/sd | 7,768
#10 | ‘systematic review’/exp OR ‘systematic review (topic)’/exp OR ‘meta analysis’/exp OR ‘meta analysis (topic)’/exp OR ‘systematic literature review’:ti,ab OR ‘this systematic review’:ti,ab OR ‘umbrella review’:ti,ab OR ‘meta-analysis’:ti,ab OR ‘meta-analyses’:ti,ab OR ‘meta-synthesis’:ti,ab OR ‘meta-syntheses’:ti,ab | 479,075
#11 | #9 AND #10 | 503
#12 | #9 AND #10 AND ([medline]/lim OR [pubmed-not-medline]/lim) | 309
#13 | #11 NOT #12 | 194
#14 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR ‘controlled trial’/exp OR ‘control trial’ OR ((‘control’:ab,ti OR ‘controlled’:ab,ti) AND ‘trial’:ab,ti) | 8,239,855
#15 | #9 AND #14 | 3,023
#16 | #15 AND ([medline]/lim OR [pubmed-not-medline]/lim) | 1,222
#17 | #15 NOT #16 | 1,801
#18 | #17 NOT #13 | 1,742

### Embase, Screening, 1-4-2021

Query | Search | Results
#1 | ‘sleep disordered breathing’/exp OR ‘obstructive sleep apneas’ OR ‘obstructive sleep apnea’ OR ‘obstructive sleep apnea syndrome’ OR ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’ OR osahs OR (‘sleep apnea’ AND hypopnea) OR ‘sleep apnea syndromes’ OR ‘sleep disordered breathing’ | 86,787
#2 | ‘body mass’/exp OR ‘body weight’/exp OR ‘decision support system’/exp OR ‘obesity’/exp OR ‘psychometry’/exp OR ‘snoring’/exp OR ‘questionnaire’/exp OR instrument:ti,ab OR instruments:ti,ab OR questionnaire:ti,ab OR questionnaires:ti,ab OR scale:ti,ab OR scales:ti,ab | 3,401,355
#3 | ‘pulse oximetry’/exp OR ‘berlin questionnaire’ OR ‘clinical prediction tool*’ OR ‘clinical prediction rule*’ OR ‘clinical prediction score*’ OR ‘craniofacial structure*’ OR ‘epworth sleepiness scale’ OR mallampati OR ‘multivariable apnea prediction index’ OR ‘multivariable apnoea prediction index’ OR names OR ‘neck circumference’ OR ‘nocturnal choking’ OR ‘nocturnal gasping’ OR oximetry OR oximetries OR ‘oxygen desaturation’ OR photoplethysmography OR ‘sleep apnea clinical score’ OR snoring OR ‘snoring scale’ OR sleepiness OR ‘stop-bag’ OR ‘stop-bang’ OR ‘stop questionnaire’ OR ‘wisconsin sleep questionnaire’ | 112,230
#4 | #1 AND #2 | 42,692
#5 | #1 AND #3 | 27,114
#6 | ‘diagnosis’/exp OR ‘diagnostic test’/exp OR ‘false negative result’/exp OR ‘false positive result’/exp OR ‘mass screening’/exp OR ‘predictive value’/exp OR ‘receiver operating characteristic’/exp OR ‘reproducibility’/exp OR ‘sensitivity and specificity’/exp OR accuracy OR diagno* OR ‘false negative’ OR ‘false positive’ OR ‘likelihood ratio’ OR ‘predictive value’ OR roc OR reproducib* OR screen OR screening OR sensitivity OR specificity | 12,134,617
#7 | #4 AND #6 | 24,647
#8 | #5 OR #7 | 39,206
#9 | #8 AND [humans]/lim | 37,067
#10 | #9 NOT ([editorial]/lim OR [letter]/lim OR [note]/lim) | 35,141
#11 | #10 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 19,843
#12 | #10 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 28,894
#13 | #11 OR #12 | 30,435
#14 | #13 AND [1-4-2015]/sd NOT [5-1-2021]/sd | 15,282
#15 | #14 AND ([medline]/lim OR [pubmed-not-medline]/lim) | 6,566
#16 | #14 NOT #15 | 8,716
#17 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR ‘controlled trial’/exp OR ‘control trial’ OR ((‘control’:ab,ti OR ‘controlled’:ab,ti) AND ‘trial’:ab,ti) | 8,239,855
#18 | #16 AND #17 | 4,055
#19 | #18 NOT ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim) | 589
#20 | ‘cohort analysis’/exp OR ‘epidemiological study’ OR (cohort AND (study OR studies)) OR ‘prospective study’/exp OR (prospective* AND cohort) OR ‘cross-section*’ OR ‘cross section*’ OR prognostic*:ti,ab OR prospectively:ti,ab | 2,648,370
#21 | #16 AND #20 | 2,519
#22 | #21 NOT ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim) | 463
#23 | #22 NOT #19 | 237

### EMBASE, Screening Bridge Search to include Emtree term “photoelectric plethysmography”, 1-6-2021

Query | Search | Results
#1 | ‘obstructive sleep apneas’ OR ‘obstructive sleep apnea’/exp OR ‘obstructive sleep apnea’ OR ‘obstructive sleep apnea syndrome’/exp OR ‘obstructive sleep apnea syndrome’ OR ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’/exp OR ‘obstructive sleep apnoea’ OR osahs OR ((‘sleep apnea’/exp OR ‘sleep apnea’) AND (‘hypopnea’/exp OR hypopnea)) OR ‘sleep apnea syndromes’/exp OR ‘sleep apnea syndromes’ OR ‘sleep disordered breathing’/exp OR ‘sleep disordered breathing’ | 87,021
#2 | ‘photoelectric plethysmography’/exp NOT photoplethysmography | 1,706
#3 | #1 AND #2 | 50
#4 | #3 AND [humans]/lim | 49
#5 | #4 NOT ([editorial]/lim OR [letter]/lim OR [note]/lim) | 46
#6 | #5 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 24
#7 | #5 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 33
#8 | #6 OR #7 | 34
#9 | #8 AND [1-4-2015]/sd NOT [5-1-2021]/sd | 22
#10 | #9 AND ([medline]/lim OR [pubmed-not-medline]/lim) | 13
#11 | #9 NOT #10 | 9
#12 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR ‘controlled trial’/exp OR ‘control trial’ OR ((‘control’:ab,ti OR ‘controlled’:ab,ti) AND ‘trial’:ab,ti) | 8,245,186
#13 | #11 AND #12 | 2
#14 | #13 NOT ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim) | 2
#15 | ‘cohort analysis’/exp OR ‘epidemiological study’ OR (cohort AND (study OR studies)) OR ‘prospective study’/exp OR (prospective* AND cohort) OR ‘cross-section*’ OR ‘cross section*’ OR prognostic*:ti,ab OR prospectively:ti,ab | 2,650,467
#16 | #11 AND #15 | 2
#17 | #16 NOT ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim) | 2
#18 | #17 NOT #14 | 1

### PubMed, Interventions, 8-22-2021

Search Number | Query | Filters | Results
1 | “Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw] | | 47,885
2 | “Continuous Positive Airway Pressure”[Mesh] OR “Intermittent Positive-Pressure Ventilation”[MeSH] OR “Mandibular Advancement/instrumentation”[Mesh] OR “Mandibular Prosthesis”[MeSH Terms] OR “Positive-Pressure Respiration”[Mesh:NoExp] | | 28,331
3 | “Biphasic Intermittent Positive Airway Pressure”[tw] OR BiPAP[tw] OR “Continuous Positive Airway Pressure”[tw] OR CPAP[tw] OR “IPPV”[tw] OR “Inspiratory Positive-Pressure Ventilation”[tw] OR “Inspiratory Positive Pressure Ventilation”[tw] OR “Intermittent Positive Pressure Ventilation”[tw] OR “mandibular advancement device”[tw] OR “mandibular advancement devices”[tw] OR “oral appliance”[tw] OR “oral appliances”[tw] OR PAP[tiab] | | 40,452
4 | #1 AND (#2 OR #3) | | 10,915
5 | #1 AND (#2 OR #3) | English | 9,602
6 | (#5 AND Humans[Mesh:NOEXP]) OR (#5 NOT Animals[Mesh:NOEXP]) | | 9,572
7 | #6 AND (“2020/07/03”[Date - Publication] : “3000”[Date - Publication]) | | 829
8 | #6 AND (“2020/07/03”[Date - Publication] : “3000”[Date - Publication]) | Adult: 19+ years | 163
9 | #7 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | | 632
10 | #8 OR #9 | | 684
11 | (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Periodical Index[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type]) | | 4,441,214
12 | #10 NOT #11 | | 623
13 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | | 389,192
14 | #12 AND #13 | | 59
15 | ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | | 836,623
16 | #12 AND #15 | | 64
17 | #16 NOT #14 | | 58

### PubMed, Screening, 8-22-2021

Search Number | Query | Filters | Results
1 | “Sleep Apnea Syndromes”[MeSH] OR “Sleep Apnea, Obstructive”[MeSH] OR “Obstructive Sleep Apneas”[tw] OR “Obstructive Sleep Apnea”[tw] OR “Obstructive Sleep Apnea Syndrome”[tw] OR “Obstructive Sleep Apnoeas”[tw] OR “Obstructive Sleep Apnoea”[tw] OR OSAHS[tw] OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing”[tw] | | 47,885
2 | “Body Mass Index”[Mesh] OR “Body Weight”[Mesh] OR “Decision Support Techniques”[Mesh] OR “Obesity”[Mesh] OR Psychometrics[Mesh] OR “Snoring”[Mesh] OR “Surveys and Questionnaires”[Mesh] OR instrument[tiab] OR instruments[tiab] OR questionnaire[tiab] OR questionnaires[tiab] OR scale[tiab] OR scales[tiab] | | 2,818,571
3 | Oximetry[MeSH] OR “Berlin Questionnaire” OR “Clinical prediction tool*” OR “Clinical prediction rule*” OR “Clinical prediction score*” OR “Craniofacial structure*” OR “Epworth Sleepiness Scale” OR Mallampati OR “Multivariable Apnea Prediction Index” OR “Multivariable Apnoea Prediction Index” OR NAMES OR “Neck circumference” OR “Nocturnal choking” OR “Nocturnal gasping” OR oximetry OR oximetries OR “oxygen desaturation” OR photoplethysmography OR “Sleep Apnea Clinical Score” OR snoring OR “Snoring Scale” OR sleepiness OR “STOP-BAG” OR “STOP-Bang” OR “STOP Questionnaire” OR “Wisconsin Sleep Questionnaire” | | 191,735
4 | #1 AND #2 | | 18,243
5 | #1 AND #3 | | 14,026
6 | “Diagnostic Tests, Routine”[Mesh] OR “False Negative Reactions”[Mesh] OR “False Positive Reactions”[Mesh] OR “Mass Screening”[Mesh] OR “Predictive Value of Tests”[Mesh] OR “ROC Curve”[Mesh] OR “Diagnosis”[Mesh] OR “Reproducibility of Results”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR accuracy[tw] OR diagno*[tw] OR “false positive”[tw] OR “false negative”[tw] OR “likelihood ratio”[tw] OR “predictive value”[tw] OR reproducib*[tw] OR ROC[tw] OR screen[tw] OR screening[tiab] OR sensitivity[tw] OR specificity[tw] | | 12,455,932
7 | #4 AND #6 | | 15,792
8 | #5 OR #7 | | 22,077
9 | #5 OR #7 | English | 19,772
10 | (#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP]) | | 19,640
11 | #10 AND (“2020/07/03”[Date - Publication] : “3000”[Date - Publication]) | | 1,479
12 | #10 AND (“2020/07/03”[Date - Publication] : “3000”[Date - Publication]) | Adult: 19+ years | 353
13 | #11 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | | 943
14 | #12 OR #13 | | 1,068
15 | (Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Periodical Index[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type]) | | 4,441,245
16 | #14 NOT #15 | | 1,009
17 | ((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]) | | 836,623
18 | #16 AND #17 | | 63
19 | “Prospective Studies”[Mesh] OR “Cross-Sectional Studies”[MeSH] OR (prospective[tw] AND cohort[tw]) OR “cross-section*”[tw] OR “cross section*”[tw] OR prognostic*[tiab] OR prospectively[tiab] | | 1,578,546
20 | #16 AND #19 | | 239
21 | #20 NOT #18 | | 223

### Cochrane Library, Interventions, 8-22-2021

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] OR [mh “Sleep Apnea, Obstructive”] OR “Obstructive Sleep Apneas” OR “Obstructive Sleep Apnea” OR “Obstructive Sleep Apnoea” OR “Obstructive Sleep Apnoeas” OR OSAHS OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing” | 7,109
#2 | [mh “Continuous Positive Airway Pressure”] OR [mh “Intermittent Positive-Pressure Ventilation”] OR [mh “Mandibular Advancement”/IS] OR [mh “Mandibular Prosthesis”] OR [mh ^“Positive-Pressure Respiration”] OR BiPAP OR “Biphasic Intermittent Positive Airway Pressure” OR “Continuous Positive Airway Pressure” OR CPAP OR “Intermittent Positive Pressure Ventilation” OR “IPPV” OR “Inspiratory Positive-Pressure Ventilation” OR “Inspiratory Positive Pressure Ventilation” OR “mandibular advancement device” OR “mandibular advancement devices” OR “oral appliance” OR “oral appliances” OR PAP:ti,ab | 10,302
#3 | #1 AND #2 | 3,398
#4 | #3 NOT ([mh animals] NOT [mh humans]) | 3,398
#5 | #4 NOT (Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) | 3,267
#6 | [mh Adult] | 476,600
#7 | #5 AND #6 | 919
#8 | #5 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 3,195
#9 | #7 OR #8 | 3,199
#10 | #9 with Cochrane Library publication date Between Jul 2020 and Dec 2021 | 238
#11 | “randomized controlled trial”:pt OR “randomized controlled trial as topic”:pt OR “single-blind method”:pt OR “double-blind method”:pt OR “random allocation”:pt | 518,722
#12 | #10 AND #11 | 29
#13 | #12 with Publication Year from 2020 to 2021, in Trials | 25

### Cochrane Library, Screening, 8-22-2021

ID | Search | Hits
#1 | [mh “Sleep Apnea Syndromes”] OR [mh “Sleep Apnea, Obstructive”] OR “Obstructive Sleep Apneas” OR “Obstructive Sleep Apnea” OR “Obstructive Sleep Apnoea” OR “Obstructive Sleep Apnoeas” OR OSAHS OR (“sleep apnea” AND hypopnea) OR “sleep disordered breathing” | 7,109
#2 | [mh “Body Mass Index”] OR [mh “Body Weight”] OR [mh “Decision Support Techniques”] OR [mh “Obesity”] OR [mh Psychometrics] OR [mh “Snoring”] OR [mh “Surveys and Questionnaires”] OR instrument:ti,ab OR instruments:ti,ab OR questionnaire:ti,ab OR questionnaires:ti,ab OR scale:ti,ab OR scales:ti,ab | 336,819
#3 | [mh Oximetry] OR “Berlin Questionnaire” OR “Clinical prediction tool*” OR “Clinical prediction rule*” OR “Clinical prediction score*” OR “Craniofacial structure*” OR “Epworth Sleepiness Scale” OR Mallampati OR “Multivariable Apnea Prediction Index” OR “Multivariable Apnoea Prediction Index” OR NAMES OR “Neck circumference” OR “Nocturnal choking” OR “Nocturnal gasping” OR oximetry OR oximetries OR “oxygen desaturation” OR photoplethysmography OR “Sleep Apnea Clinical Score” OR snoring OR “Snoring Scale” OR sleepiness OR “STOP-BAG” OR “STOP-Bang” OR “STOP Questionnaire” OR “Wisconsin Sleep Questionnaire” | 14,409
#4 | #1 AND #2 | 2,430
#5 | #1 AND #3 | 2,541
#6 | [mh “Diagnosis”] OR [mh “Diagnostic Tests, Routine”] OR [mh “False Negative Reactions”] OR [mh “False Positive Reactions”] OR [mh “Mass Screening”] OR [mh “Predictive Value of Tests”] OR [mh “ROC Curve”] OR [mh “Reproducibility of Results”] OR [mh “Sensitivity and Specificity”] OR accuracy OR diagno* OR “false negative” OR “false positive” OR “likelihood ratio” OR “predictive value” OR ROC OR reproducib* OR screen OR screening OR sensitivity OR specificity | 593,628
#7 | #4 AND #6 | 1,565
#8 | #5 OR #7 | 3,137
#9 | #8 NOT ([mh animals] NOT [mh humans]) | 3,137
#10 | #9 NOT (Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) | 2,979
#11 | [mh Adult] | 476,600
#12 | #10 AND #11 | 1,064
#13 | #12 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 1,051
#14 | #12 OR #13 | 1,064
#15 | #14 with Cochrane Library publication date Between Jul 2020 and Dec 2021 | 32
#16 | #15 AND (“randomized controlled trial”:pt OR “randomized controlled trial as topic”:pt OR “single-blind method”:pt OR “double-blind method”:pt OR “random allocation”:pt) | 32
#17 | #16 with Publication Year from 2020 to 2021, in Trials | 29

### Embase, Interventions, 8-23-2021

Query | Results | No.
#1 | ‘obstructive sleep apneas’ OR ‘obstructive sleep apnea’/exp OR ‘obstructive sleep apnea’ OR ‘obstructive sleep apnea syndrome’/exp OR ‘obstructive sleep apnea syndrome’ OR ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’/exp OR ‘obstructive sleep apnoea’ OR osahs OR ((‘sleep apnea’/exp OR ‘sleep apnea’) AND (‘hypopnea’/exp OR hypopnea)) OR ‘sleep apnea syndromes’/exp OR ‘sleep apnea syndromes’ OR ‘sleep disordered breathing’/exp OR ‘sleep disordered breathing’ | 91,410
#2 | ‘continuous positive airway pressure’/exp OR ‘cpap device’/exp OR ‘intermittent positive pressure ventilation’/exp OR ‘mandible prosthesis’/exp OR ‘positive end expiratory pressure’/exp/mj OR ‘positive pressure ventilation’/exp OR bipap OR ‘biphasic intermittent positive airway pressure’ OR ‘continuous positive airway pressure’ OR cpap OR ‘intermittent positive pressure ventilation’ OR ‘ippv’ OR ‘inspiratory positive-pressure ventilation’ OR ‘inspiratory positive pressure ventilation’ OR ‘mandibular advancement device’ OR ‘mandibular advancement devices’ OR ‘oral appliance’ OR ‘oral appliances’ OR pap:ti,ab | 101,880
#3 | #1 AND #2 | 22,401
#4 | #3 AND [humans]/lim | 21,321
#5 | #4 NOT ([editorial]/lim OR [letter]/lim OR [note]/lim) | 19,095
#6 | #5 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 9,881
#7 | #5 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 17,066
#8 | #6 OR #7 | 17,594
#9 | #8 AND [3-7-2020]/sd AND [2020-2021]/py | 1,570
#10 | ‘systematic review’/exp OR ‘systematic review (topic)’/exp OR ‘meta analysis’/exp OR ‘meta analysis (topic)’/exp OR ‘systematic literature review’:ti,ab OR ‘this systematic review’:ti,ab OR ‘umbrella review’:ti,ab OR ‘meta-analysis’:ti,ab OR ‘meta-analyses’:ti,ab OR ‘meta-synthesis’:ti,ab OR ‘meta-syntheses’:ti,ab | 525,233
#11 | #9 AND #10 | 121
#12 | #11 AND ([medline]/lim OR [pubmed-not-medline]/lim) | 82
#13 | #11 NOT #12 | 39
#14 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR ‘controlled trial’/exp OR ‘control trial’ OR ((‘control’:ab,ti OR ‘controlled’:ab,ti) AND ‘trial’:ab,ti) | 8,715,214
#15 | #9 AND #14 | 821
#16 | #15 AND ([medline]/lim OR [pubmed-not-medline]/lim) | 379
#17 | #15 NOT #16 | 442
#18 | #17 NOT #13 | 425

### Embase, Screening, 8-23-2021

Query | Results | No.
#1 | ‘sleep disordered breathing’/exp OR ‘obstructive sleep apneas’ OR ‘obstructive sleep apnea’ OR ‘obstructive sleep apnea syndrome’ OR ‘obstructive sleep apnoeas’ OR ‘obstructive sleep apnoea’ OR osahs OR (‘sleep apnea’ AND hypopnea) OR ‘sleep apnea syndromes’ OR ‘sleep disordered breathing’ | 91,410
#2 | ‘body mass’/exp OR ‘body weight’/exp OR ‘decision support system’/exp OR ‘obesity’/exp OR ‘psychometry’/exp OR ‘snoring’/exp OR ‘questionnaire’/exp OR instrument:ti,ab OR instruments:ti,ab OR questionnaire:ti,ab OR questionnaires:ti,ab OR scale:ti,ab OR scales:ti,ab | 3,595,457
#3 | ‘photoelectric plethysmography’/exp OR ‘pulse oximetry’/exp OR ‘berlin questionnaire’ OR ‘clinical prediction tool*’ OR ‘clinical prediction rule*’ OR ‘clinical prediction score*’ OR ‘craniofacial structure*’ OR ‘epworth sleepiness scale’ OR mallampati OR ‘multivariable apnea prediction index’ OR ‘multivariable apnoea prediction index’ OR names OR ‘neck circumference’ OR ‘nocturnal choking’ OR ‘nocturnal gasping’ OR oximetry OR oximetries OR ‘oxygen desaturation’ OR photoplethysmography OR ‘sleep apnea clinical score’ OR snoring OR ‘snoring scale’ OR sleepiness OR ‘stop-bag’ OR ‘stop-bang’ OR ‘stop questionnaire’ OR ‘wisconsin sleep questionnaire’ | 119,739
#4 | #1 AND #2 | 45,189
#5 | #1 AND #3 | 28,514
#6 | ‘diagnosis’/exp OR ‘diagnostic test’/exp OR ‘false negative result’/exp OR ‘false positive result’/exp OR ‘mass screening’/exp OR ‘predictive value’/exp OR ‘receiver operating characteristic’/exp OR ‘reproducibility’/exp OR ‘sensitivity and specificity’/exp OR accuracy OR diagno* OR ‘false negative’ OR ‘false positive’ OR ‘likelihood ratio’ OR ‘predictive value’ OR roc OR reproducib* OR screen OR screening OR sensitivity OR specificity | 12,622,950
#7 | #4 AND #6 | 26,226
#8 | #5 OR #7 | 41,450
#9 | #8 AND [humans]/lim | 39,286
#10 | #9 NOT ([editorial]/lim OR [letter]/lim OR [note]/lim) | 37,235
#11 | #10 AND ([adult]/lim OR [middle aged]/lim OR [aged]/lim OR [very elderly]/lim) | 21,467
#12 | #10 NOT (child* OR pediatric OR paediatric* OR boys OR girls OR youth OR youths) | 30,579
#13 | #11 OR #12 | 32,261
#14 | #13 AND [3-7-2020]/sd AND [2020-2021]/py | 3,233
#15 | #14 AND ([medline]/lim OR [pubmed-not-medline]/lim) | 1,631
#16 | #14 NOT #15 | 1,602
#17 | ‘randomized controlled trial’/exp OR ‘single blind procedure’/exp OR ‘double blind procedure’/exp OR ‘random allocation’/exp OR ‘controlled trial’/exp OR ‘control trial’ OR ((‘control’:ab,ti OR ‘controlled’:ab,ti) AND ‘trial’:ab,ti) | 8,715,214
#18 | #16 AND #17 | 1,054
#19 | #18 NOT ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim) | 286
#20 | ‘cohort analysis’/exp OR ‘epidemiological study’ OR (cohort AND (study OR studies)) OR ‘prospective study’/exp OR (prospective* AND cohort) OR ‘cross-section*’ OR ‘cross section*’ OR prognostic*:ti,ab OR prospectively:ti,ab | 2,856,050
#21 | #16 AND #20 | 596
#22 | #21 NOT ([conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim) | 224
#23 | #22 NOT #19 | 90

### Gray Literature

ClinicalTrials.gov , OSA in Adults, 8-23-2021

656 studies for Screening, 656 imported

Expert search:

(“Ambulatory monitoring” OR Polysomnograph* OR oximetr* OR diagnos* OR “sleep monitoring” OR PSG OR polygraphy OR Actigraphy OR Apnoescreen OR home monitor* OR Monitoring system* OR “portable respiratory monitoring” OR Portable monitor* OR screen* OR psychometrics OR instrument* OR questionnaire* OR scale* OR “oxygen desaturation” OR photoplethysmography OR diagno* OR sensitivity OR specificity OR accuracy OR reliab* OR valid* OR reproducib* OR “false positive” OR “false negative”) AND AREA[ConditionSearch] “Apnea, Obstructive” AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] ( “Adult” OR “Older Adult” ) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[10/01/2015, 08/23/2021]

406 studies for Treatment and Harms combined search, 210 imported

Expert search:

AREA[StudyType] EXPAND[Term] COVER[FullMatch] “Interventional” AND AREA[ConditionSearch] EXPAND[Concept] “Apnea, Obstructive” AND AREA[InterventionSearch] ( “Positive-Pressure Respiration” OR “Continuous Positive Airway Pressure” OR CPAP OR PAP OR “Intermittent Positive Pressure Ventilation” OR IPPV OR “Inspiratory Positive-Pressure Ventilation” OR “Inspiratory Positive Pressure Ventilation” OR “Biphasic Intermittent Positive Airway Pressure” OR BiPAP OR “Mandibular Prosthesis” OR “Mandibular Advancement” ) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] ( “Adult” OR “Older Adult” ) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[10/01/2015, 08/23/2021]

## Appendix B2 Eligibility Criteria

Category | Include | Exclude
Populations | KQs 1–3: Adults age 18 years or older who are asymptomatic or have unrecognized symptoms of OSA; KQs 4–6: Persons with a confirmed diagnosis of OSA; population may include asymptomatic or symptomatic adults; All KQs: A priori subgroups of interest include those defined by age, sex, BMI category, and OSA severity^*^ | All KQs: Children and adolescents; pregnant women; studies of adults with acute stroke or other acute conditions that can trigger onset of OSA; Studies focused on screening, diagnosis, or treatment of OSA among persons with a rare condition (e.g., acromegaly); KQs 4–6: Studies of persons with suspected but unconfirmed OSA
Setting | Studies conducted in countries categorized as “Very High” on the Human Development Index, as defined by the United Nations Development Programme | KQs 1–3: Populations screened for OSA in perioperative settings or screened in the context of occupational health examination to determine fitness for duty; KQs 4–6: Interventions studied only in laboratories (e.g., studies of PAP conducted in sleep laboratories)
Screening | Externally validated questionnaires, including the ESS, STOP Questionnaire, Berlin Questionnaire, Wisconsin Sleep Questionnaire, or STOP-BANG Questionnaire; externally validated risk stratification or clinical prediction tools that include multiple factors (e.g., the Multivariable Apnea Prediction Index); may include findings from physical examination (e.g., neck circumference, Mallampati classification); combined screening approaches are also eligible, which may use a questionnaire or clinical prediction tool followed by home-based oximetry testing for persons who score above a defined threshold on the questionnaire or clinical prediction tool | Studies assessing single patient characteristics or risk factors
Treatment | Interventions appropriate for screen-detected or newly detected OSA, including PAP and MADs; variations of PAP are eligible, including continuous, auto-titrating, and bilevel with different device interfaces (e.g., nasal and oronasal masks) and accessory features such as humidification | All other interventions for OSA, including surgery, atrial overdrive pacing, medications, palatal implants, oropharyngeal exercises, tongue-retaining devices, positional alarms, nasal dilator strips, acupuncture, and auricular plaster; medications to treat sleepiness, sleep quality, or bruxism (rather than used to treat OSA), such as eszopiclone and modafinil; nasal steroids for treatment of allergic rhinitis or similar treatments that might secondarily improve OSA by treating another condition
Comparisons | KQs 1, 3: Screened vs. nonscreened groups or groups undergoing screening and/or diagnostic testing vs. groups not undergoing screening and/or diagnostic testing; KQ 2: Studies on accuracy of screening must include a comparison with overnight PSG conducted in a sleep laboratory; studies may also determine or compare persons at increased, average, or decreased risk or persons at higher and lower risk for OSA; KQs 4–6: PAP vs. control or sham PAP; MADs vs. no treatment or inactive MADs | All KQs: No comparison; nonconcordant historical controls; comparative studies of various interventions (e.g., comparing PAP with MADs or comparing different types of PAP); KQ 2: Studies with verification bias in which only a subgroup had PSG as the comparator
Outcomes | KQs 1, 5: Mortality, quality of life (both disease-specific measures, such as the Functional Outcomes of Sleep Questionnaire, and general measures, such as the 36-Item Short-Form Health Survey), measures of sleepiness, motor vehicle crashes, cardiovascular events (including ischemic events and rhythm disturbances, such as incident atrial fibrillation), cerebrovascular events, incidence of heart failure, headaches, and cognitive impairment; KQ 2: Sensitivity, specificity, discrimination, calibration; KQ 3: False-positive results leading to unnecessary treatment, anxiety, condition-specific distress, or stigma; KQ 4: Change in AHI, blood pressure; KQ 6: Rash, irritation, need for additional sleep medications (e.g., to tolerate PAP), claustrophobia, oral or nasal dryness, epistaxis, pain, excess salivation, and tooth damage or loosening | All other outcomes; KQ 2: Acceptability of screening
Study Designs | KQs 1, 5–6: RCTs; KQ 2: Prospective cohort studies and cross-sectional studies that develop or evaluate screening questionnaires, clinical prediction tools, or combined screening approaches; KQ 3: Studies eligible for KQ 1 or KQ 2 that report harms of screening or diagnostic tests; KQ 4: Good-quality, recent (within last 5 years) systematic reviews reporting on change in AHI or blood pressure in studies comparing PAP or MAD with an eligible control | All other designs; KQ 2: Questionnaires, tools, and tests not validated in a group of participants separate from the sample used to develop the test
Language | English | Languages other than English
Study Quality | Good or fair | Poor (according to design-specific USPSTF criteria)

* OSA severity will be defined as mild if the AHI (or RDI) is ≥5 to <15, moderate if the AHI (or RDI) is ≥15 to ≤30, and severe if the AHI (or RDI) is ≥30.

Abbreviations: AHI=apnea-hypopnea index; BMI=body mass index; ESS=Epworth Sleepiness Scale; KQ=key question; MAD=mandibular advancement device; OSA=obstructive sleep apnea; PAP=positive airway pressure; PSG=polysomnography; RCT=randomized, controlled trial; RDI=Respiratory Disturbance Index; STOP=Snoring, Tiredness, Observed apnea, blood Pressure; STOP-BANG=Snoring, Tiredness, Observed apnea, blood Pressure, Body mass index, Age, Neck circumference, and Gender; USPSTF=U.S. Preventive Services Task Force; vs.=versus.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: Studies will be graded “fair” if any or all of the following problems occur without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^281^

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

#### Definition of Ratings Based on Above Criteria

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.
Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor: Has a fatal flaw, such as uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^281^