# Appendix A Additional Background and Contextual Questions

Appendix A Table 1 Classification of Monitors Used for Diagnosis of OSA^*^

Type | Portability | Number of Channels (i.e., Physiologic Measures) | Typical Parameters | ≥2 Airflow or Effort Channels | Measures AHI
I | Facility based | ≥7; (usually 12–16) | EEG, EOG, EMG, ECG/HR, airflow (nasal or oral), respiratory effort (thoracic or abdominal movement), SaO_2_, body position, leg movement, snoring | Yes | Yes
II | Portable | ≥7 | EEG, EOG, EMG, ECG, or HR,^†^ airflow, respiratory effort (thoracic or abdominal movement), SaO_2_ | Yes | Yes
III | Portable | ≥4; (usually 4–7) | Ventilation or airflow, respiratory effort (thoracic or abdominal movement), ECG or HR, SaO_2_ | Yes | No
IV | Portable | ≥1; (usually 1–3) | Usually SaO_2_;^ǂ^ may include additional channels provided the monitor does not qualify as type III^§^ | No | No

* Modified, with permission, from a previous systematic review;^47^ personal communication with Dr. Ethan Balk (October 5, 2015).

† HR is allowed in place of ECG in type II portable monitors (PMs). Type II PMs usually measure the same channels as type I monitors but are portable.

ǂ Unlike other monitor types that measure SaO_2_ by oximetry, type IV monitors may measure SaO_2_ by oximetry, airflow, or both.

§ Parameters that are more commonly measured by type IV PMs include but are not limited to snoring, body position, leg movement, peripheral arterial tone, and plethysmography.

Abbreviations: AHI=apnea-hypopnea index; ECG=electrocardiogram; EEG=electroencephalogram; EMG=electromyogram; EOG=electrooculogram; HR=heart rate; OSA=obstructive sleep apnea; PM=portable monitor; SaO_2_=arterial oxygen saturation.

Appendix A Table 2 Summary of Treatment Guidelines From Other Groups

Group, Year | Recommendations
American College of Physicians (ACP), 2013^96^ | - All overweight and obese patients diagnosed with OSA should be encouraged to lose weight. (strong recommendation, low-quality evidence); - CPAP treatment as initial therapy for patients diagnosed with OSA. (strong recommendation, moderate-quality evidence); - MADs as an alternative therapy to CPAP treatment for patients diagnosed with OSA who prefer MADs or for those with adverse effects associated with CPAP treatment. (weak recommendation, low-quality evidence)
American Academy of Sleep Medicine (AASM), 2015 (Oral Appliances),^254^ 2019 (PAP Treatment)^95^ | - Clinicians should use PAP compared with no therapy to treat OSA in adults with excessive sleepiness (strong recommendation) and suggest use of PAP compared with no therapy to treat adults with comorbid hypertension and those with impaired sleep-related quality of life. (conditional recommendation); - PAP therapy should be initiated using either APAP at home or in-laboratory PAP titration in adults with OSA and no significant comorbidities and should use either CPAP or APAP for ongoing treatment of OSA in adults. (strong recommendation); - Clinicians should consider use of CPAP or APAP over BPAP in the routine treatment of OSA in adults. (conditional recommendation); - Clinicians should provide educational interventions with initiation of PAP therapy in adults with OSA. (strong recommendation); - Clinicians should consider implementing behavioral or troubleshooting interventions during the initial period of PAP therapy in adults with OSA. (conditional recommendation); - Sleep clinicians should consider providing a prescription for an oral appliance vs. no treatment for adult patients with OSA who are intolerant of CPAP therapy or who prefer alternative therapies (benefits clearly outweigh risks, high-quality evidence)
National Institute for Health and Clinical Excellence (NICE), 2008^255^ | - Recommends CPAP as a treatment option for adults with moderate or severe symptomatic OSAHS.; - Recommends CPAP as a treatment option for adults with mild OSAHS only if they have symptoms that affect their quality of life and their ability to perform their daily activities and only if lifestyle advice and other relevant treatment options have been unsuccessful or are considered inappropriate.; - The diagnosis and treatment of OSAHS and the monitoring of the response should be carried out by a specialist service with appropriately trained medical and support staff.
U.S. Department of Veterans Affairs and the Department of Defense (VA/DoD), 2019^103^ | - For patients with severe OSA (i.e., AHI >30 events/hour), the recommended initial therapy is PAP. For patients with mild to moderate OSA (i.e., AHI 5 to <30 events/hour), either PAP or MAD therapy can be considered for initial therapy; choice of treatment should be based on clinical evaluation, comorbidities, and patient preference.; - Educational, behavioral therapy, and supportive interventions should be offered to improve PAP adherence. Weight loss and a comprehensive lifestyle intervention program should be encouraged in all patients with OSA who are overweight or obese; although weight loss alone is typically insufficient as therapy for OSA, weight loss may improve AHI.; - In OSA patients who are not adherent to PAP or MAD therapy or who have persistent symptoms despite adequate therapy, referral to a clinician with expertise in sleep medicine is recommended.

Abbreviations: AASM=American Academy of Sleep Medicine; ACP=American College of Physicians; AHI=apnea-hypopnea index; APAP=auto-adjusting positive airway pressure; BPAP=bilevel positive airway pressure; CPAP=continuous positive airway pressure; MAD=mandibular advancement device; NICE=National Institute for Health and Clinical Excellence; OSA=obstructive sleep apnea; OSAHS=obstructive sleep apnea-hypopnea syndrome; PAP=positive airway pressure; VA/DoD=U.S. Department of Veterans Affairs and the U.S. Department of Defense.

Appendix A Table 3 Summary of Screening Guidelines From Other Groups

Group, Year | Recommendations
American College of Physicians (ACP), 2014^226^ | - A sleep study is recommended for patients with unexplained daytime sleepiness. (weak recommendation, low-quality evidence); - Polysomnography is recommended for diagnostic testing in patients with suspected OSA. Portable sleep monitors are recommended in patients without serious comorbidities as an alternative to polysomnography when polysomnography is not available for diagnostic testing. (weak recommendation, moderate-quality evidence)
Society of Anesthesia and Sleep Medicine (SASM), 2016^256^ | - Adult patients at risk for OSA should be identified before surgery (Level of Evidence: Low; Grade of Recommendation: Weak for).; - Screening tools such as STOP-BANG, P-SAP, Berlin Questionnaire, and ASA Check List can be used as preoperative screening tools to identify patients with suspected OSA (Level of Evidence: Moderate; Grade of Recommendation: Strong for).; - There is insufficient evidence to support canceling or delaying surgery to perform more advanced screening techniques or sleep testing to diagnose OSA in those patients identified as being at high risk of OSA preoperatively, unless there is evidence of an associated significant or uncontrolled systemic disease or additional problems with ventilation or gas exchange (Level of Evidence: Low; Grade of Recommendation: Weak for).
American Academy of Sleep Medicine (AASM), 2017^6,^ ^257^ | - Clinical tools, questionnaires, and prediction algorithms should not be used to diagnose OSA in adults in the absence of PSG or in-home sleep apnea testing. (strong recommendation); - A home sleep apnea test (HSAT) should not be used for the general screening of populations who are asymptomatic. The need for and appropriateness of an HSAT to diagnose OSA or evaluate treatment efficacy must be based on the patient’s medical history and an examination by a medical provider (face-to-face or via telemedicine). (medical position statement); - Diagnosis of OSA in uncomplicated adult patients presenting with signs and symptoms that indicate an increased risk of moderate to severe OSA can be made with either PSG or in-home sleep apnea testing with a technically adequate device. If a single HSAT is negative, inconclusive, or technically inadequate, PSG should be performed for diagnosis. (strong recommendation); - PSG vs. in-home sleep apnea testing should be used for the diagnosis of OSA in patients with significant cardiorespiratory disease, potential respiratory muscle weakness due to neuromuscular conditions, awake hypoventilation or suspicion of sleep-related hypoventilation, chronic opioid medication use, history of stroke, or severe insomnia. (strong recommendation)
National Institute for Health and Clinical Excellence (NICE), 2008^255^ | - The diagnosis and treatment of OSAHS and the monitoring of the response should be carried out by a specialist service with appropriately trained medical and support staff.; - Moderate to severe OSAHS can be diagnosed from the patient’s medical history and a sleep study using oximetry or other monitoring devices carried out in the patient’s home. In some cases, further studies that monitor additional physiological variables in a sleep laboratory or at home may be required, especially when alternative diagnoses are being considered.; - Guidelines related to initial assessment and diagnosis are being developed (expected publication April 2021).^258^
U.S. Department of Veterans Affairs and the U.S. Department of Defense (VA/DoD), 2019^103^ | - For patients who report sleep complaints, suggest using the STOP Questionnaire to stratify the risk of OSA. Consider assessing for sleep-disordered breathing in patients with a history of cardiovascular or cerebrovascular events, congestive heart failure, and chronic opioid use. (strength of recommendations: weak); - Among patients with a high pretest probability of OSA, suggest using a manually scored type II HSAT (unattended portable monitor) using an event index of ≥15 events per hour to establish diagnosis of moderate to severe OSA. (strength of recommendations: weak)

Abbreviations: AASM=American Academy of Sleep Medicine; ACP=American College of Physicians; ASA=American Society of Anesthesiologists; HSAT=home sleep apnea test; NICE=National Institute for Health and Clinical Excellence; OSA=obstructive sleep apnea; OSAHS=obstructive sleep apnea-hypopnea syndrome; P-SAP=perioperative sleep apnea prediction; PSG=polysomnography; SASM=Society of Anesthesia and Sleep Medicine; STOP-BANG=Snoring, Tiredness, Observed apnea, blood Pressure Questionnaire plus BMI, Age, Neck circumference, and Gender; VA/DoD=U.S. Department of Veterans Affairs and the U.S. Department of Defense.

## Appendix A Contextual Questions

### CQ 1 What Are the Barriers to Undergoing Diagnostic Testing for OSA (e.g., Availability of Polysomnography, Ability to Tolerate Testing)? How Often Do Those Barriers Prevent Completion of Testing?

Identifying and removing barriers to OSA diagnosis continues to be a challenge in the effort to address the disease. Barriers to diagnosis come from multiple aspects of the healthcare system, and many of these obstacles are external to the health care system itself. Following is a summary of the evidence surrounding the barriers to OSA diagnosis and some of measures that have been proposed to address these barriers.

Some studies have examined whether patients followed up with sleep labs after they were referred and—if not—the reasons why they did not follow up. The reasons found for lack of followup include misconceptions about OSA,^259,^ ^260^ work responsibilities,^259^ negative views of OSA services,^259^ and financial and transportation difficulties.^259^ Some misconceptions involve a lack of understanding of the seriousness of the disease, such as conflating snoring with OSA.^259^ Another study that included a large insurer’s administrative data on more than 51,000 patients preauthorized for sleep testing found that patients with signs and symptoms of OSA such as snoring or gasping and sleepiness were more likely to be adherent to sleep testing than patients without such signs and symptoms.^261^

One study described a quality improvement project aimed at identifying barriers to OSA diagnosis that providers and patients faced in an internal medicine clinic in Buffalo, New York.^262^ Among providers, barriers included a lack of knowledge about guidelines and OSA diagnosis, a lack of reminders to screen, and the extra time needed to use screening tools. Despite employing the STOP-BANG Questionnaire in patients with hypertension, physicians could not always document the results from paper questionnaires in the electronic health record. For patients, barriers to diagnosis include their lack of knowledge about OSA, lack of transportation to sleep clinics, and lack of health insurance and the inability to pay for sleep studies.

Other studies have supported the following barriers among providers: difficulty recognizing OSA symptoms,^263,^ ^264^ lack of time or reminders to screen for OSA during an appointment,^265,^ ^266^ delays in diagnostic testing,^264,^ ^267^ and under-referral to specialists for OSA diagnosis.^264^ Multiple studies have also supported the idea that their lack of knowledge about OSA has prevented patients from disclosing their symptoms.^262,^ ^264^

Efforts to make diagnosis more accessible are underway, but these solutions will come with tradeoffs. In-home PSG may address the transportation barriers and financial obstacles to diagnosing OSA.^259,^ ^268–270^ Despite the convenience of in-home PSG, the conclusion from one technical review of 50 commercial PMs and 25 research procedures used with adults indicates that PMs are appropriate for an initial OSA diagnosis.^271^ The authors found that the sensitivity of the commercial devices was high, ranging from 60 to 100 percent, with a median of 93 percent, but that the median specificity was much lower (75%), ranging from 40 to 100 percent. Moreover, it was not clear whether all studies used PSG as the reference measure. One study included in the review that did use PSG to validate portable monitoring^272^ found excellent sensitivity with in-home portable monitoring in comparison with PSG, ranging from 92 percent (for AHI ≥15) to 96 percent (for AHI ≥5); specificity was lower, ranging from 43 to 77 percent. Therefore, providers should consider the limitations of portable monitoring when employing this method.

Finally, many structural barriers continue to prevent patients from being diagnosed with OSA. Finances,^259^ geographical distance from specialists and sleep study centers,^268,^ ^269^ and provider inexperience^264^ all appear to play a significant role in the underdiagnosis of OSA. These barriers are not distributed evenly, and it is likely that a significant portion of population affected by OSA in the United States is underdiagnosed due to these diagnostic obstacles. Direct evidence of diagnostic obstacles remains scarce; therefore, we recommend that more studies investigate this issue.

### CQ 2 Is There an Association Between AHI and Health Outcomes?

The apnea-hypopnea index (AHI) is often used to indicate the severity of OSA and represents the number of apnea and hypopnea events per hour of sleep. According to the American Academy of Sleep Medicine classification, having fewer than 5 AHI events per hour is considered normal, having 5 to 15 AHI events per hour is considered mild OSA, having 15 to 29 AHI events per hour is considered moderate OSA, and 30 or more AHI events per hour is considered severe OSA.^273^

In the previous USPSTF review on this topic (published in 2017), we summarized 11 prospective cohort studies (26,954 total participants) that compared participants with OSA to those without OSA or to those with varying degrees of OSA who were untreated for OSA.^92^ The review found that severe (AHI ≥30) OSA or moderate to severe (AHI ≥15) OSA was associated with an increased risk of all-cause mortality (pooled HR, 2.07 [95% CI, 1.48 to 2.91]; followup ranged from 3.4 to 20 years) and cardiovascular (CV) mortality (data not pooled). The review reported that studies assessing whether moderate (AHI 15 to <30) or mild (AHI 5 to <15) OSA levels are associated with mortality did not find a statistically significant association. The review noted that included studies controlled for multiple potential confounders, but that residual confounding attributable to health-related factors (such as physical activity or diet) was possible and generally not accounted for. A single study was available for each other outcome (i.e., cancer-related mortality, nonfatal CV events, heart failure, coronary heart disease, stroke, cognitive impairment or dementia, and cognitive decline), for which findings were imprecise, consistency was unknown (single study for each), and evidence was limited by risk of bias, especially from potential residual confounding.^92^

More recent systematic reviews (SRs) of these outcomes describe similar findings.^274–280^ These reviews are often framed as investigating the relationship between OSA and a given health outcome; however, OSA is typically measured by AHI and usually following the American Academy of Sleep Medicine classification. These SRs rely largely on prospective and occasionally retrospective cohort studies (that generally have a higher risk of bias, and therefore were not eligible for the 2017 review conducted for the USPSTF) of untreated individuals. Comparison groups vary and include persons with no OSA (AHI <5) or persons with less severe OSA (AHI ranging from 5 to <30). Additionally, most studies included in these reviews were comprised of predominantly male participants.

A 2017 SR considered the relationship between the various levels of OSA severity (measured by AHI) and CV and mortality outcomes.^274^ This review included 16 studies (24,308 total participants) that were published through May 2016 with followup ranging from 2.9 to 18.0 years. Meta-analyses of relevant studies found that severe OSA (AHI ≥30) was associated with increased risk of major CV events (relative risk [RR], 2.04 [95% CI, 1.56 to 2.66]; p<0.001), coronary heart disease (RR, 1.63 [95% CI, 1.18 to 2.26]; p=0.003), stroke (RR, 2.15 [95% CI, 1.42 to 3.24]; p<0.001), cardiac death (RR, 2.96 [95% CI, 1.45 to 6.01]; p=0.003), and all-cause mortality (RR, 1.54 [95% CI, 1.21 to 1.97]; p<0.001), but not heart failure (RR, 1.44 [95% CI, 0.94 to 2.21]; p=0.097). Mild OSA was not significantly associated with increased risk of any of these outcomes and moderate OSA was associated only with increased risk of major CV events (RR, 1.16 [95% CI, 1.01 to 1.33]; p=0.034) and coronary heart disease (RR, 1.38 [95% CI, 1.04 to 1.83]; p=0.026). Several older SRs and meta-analyses, including many of the same primary studies, have found qualitatively similar results indicating that severe OSA is associated with increased risk of many CV and mortality outcomes while mild and moderate often are not.^275–278^

Additional SRs and meta-analyses have considered other important outcomes. In a 2017 meta-analysis of six studies, sleep-disordered breathing was associated with increased odds of cognitive impairment, including “clinically relevant cognitive decline or risk of dementia” (OR, 1.26 [95% CI, 1.05 to 1.50]; p=0.01).^280^ It should be noted that only four of these six studies defined sleep-disordered breathing using AHI; the other two used a clinical diagnosis. A separate 2018 meta-analysis estimated an increased risk of atrial fibrillation with any sleep apnea-hypopnea syndrome (RR, 1.7 [95% CI, 1.53 to 1.89]; p=NR).^279^ Using a subset of studies that provided associations by OSA severity, having mild, moderate, and severe OSA were all associated with having an increased risk of atrial fibrillation with increasing magnitudes (mild RR, 1.52 [95% CI, 1.28 to 1.79]; p=0.01; moderate RR, 1.88 [95% CI, 1.55 to 2.27]; p=0.017; severe RR, 2.16 [95% CI, 1.78 to 2.62]; p<0.001).

Importantly, secondary meta-analyses by gender often identified a similar association between severe OSA and significantly increased risk of CV and mortality for men,^274,^ ^276^ but not for women. Although analyses of men largely drove the overall findings, no significant difference was found between men and women. Authors suggest that this may be due to the higher prevalence of OSA among men, biologic differences between the sexes, and most studies considering only or at least predominantly men.^274^

Overall, meta-analyses suggest that severe OSA (AHI ≥30) is associated with an increased risk of many adverse health outcomes, including CV events, mortality, and cognitive impairment. Some studies suggest that the risk of such outcomes increases with each level of OSA severity, which may indicate a dose-response effect; however, this finding is not consistent across all studies or outcomes. Lastly, findings of increased risk associated with severe OSA are the strongest among male populations; however, it is difficult to assess if these relationships do not hold for female populations or if it is due to more sparse evidence on female populations.