# References

1 American Heart Association. Cardiovascular Disease Cost. Web Page: http://www.Americanheart.Org/216.185.112.5/Presenter.Jhtml?Identifier=4475. 2001;Date accessed: October 27, 2002.
2 Tunstall-Pedoe H, Morrison C, Woodward M, Fitzpatrick B, Watt G. Sex differences in myocardial infarction and coronary deaths in the Scottish MONICA population of Glasgow 1985 to 1991. Presentation, diagnosis, treatment, and 28-day case fatality of 3991 events in men and 1551 events in women. Circulation. 1996;93:1981-1992. [pmid: 8640972].
3 Thaulow E, Erikssen J, Sandvik L, Erikssen G, Jorgensen L, Cohn PF. Initial clinical presentation of cardiac disease in asymptomatic men with silent myocardial ischemia and angiographically documented coronary artery disease (the Oslo Ischemia Study). Am J Cardiol. 1993;72:629-633. [pmid: 8249835].
4 Cohn PF. Detection and prognosis of the asymptomatic patient with silent myocardial ischemia. Am J Cardiol. 1988;61:4B-6B.
5 U.S. Preventive Services Task Force; Guide to Clinical Preventive Services. 2nd ed. Alexandria, VA: International Medical Publishing; 1996.
6 Wilson PW, D'Agostino RB, Levy D, Belanger AM, Silbershatz H, Kannel WB. Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97:1837-1847. [pmid: 9603539].
7 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;2(3S):21-35. [pmid: 11306229].
8 Multiple Risk Factor Intervention Trial Research Group. Exercise electrocardiogram and coronary heart disease mortality in the Multiple Risk Factor Intervention Trial. Am J Cardiol. 1985;55:16-24. [pmid: 2857061].
9 Wong ND, Detrano RC, Diamond G, et al. Does coronary artery screening by electron beam computed tomography motivate potentially beneficial lifestyle behaviors?. Am J Cardiol. 1996;78:1220-1223. [pmid: 8960578].
10 O'Malley PG, Rupard EJ, Jones DL, Feuerstein I, Brazaitis M, Taylor AJ. Does the diagnosis of coronary calcification with electron beam computed tomography motivate behavioral change in smokers?. Mil Med. 2002;167:211-214. [pmid: 11901568].
11 Ashley EA, Raxwal V, Froelicher V. An evidence-based review of the resting electrocardiogram as a screening technique for heart disease. Prog Cardiovasc Dis. 2001;44:55-67. [pmid: 11533927].
12 Whincup PH, Wannamethee G, Macfarlane PW, Walker M, Shaper AG. Resting electrocardiogram and risk of coronary heart disease in middle-aged British men. J Cardiovasc Risk. 1995;2:533-543. [pmid: 8665372].
13 De Bacquer D, De Backer G, Kornitzer M, Blackburn H. Prognostic value of ECG findings for total, cardiovascular disease, and coronary heart disease death in men and women. Heart. 1998;80:570-577. [pmid: 10065025]. [pmcid: 1728877].
14 Menotti A, Seccareccia F. Electrocardiographic Minnesota code findings predicting short-term mortality in asymptomatic subjects. The Italian RIFLE Pooling Project (Risk Factors and Life Expectancy). G Ital Cardiol. 1997;27:40-49. [pmid: 9199942].
15 Menotti A, Mulder I, Kromhout D, Nissinen A, Feskens EJ, Giampaoli S. The association of silent electrocardiographic findings with coronary deaths among elderly men in three European countries. The FINE study. Acta Cardiol. 2001;56:27-36. [pmid: 11315121].
16 Rose G, Baxter PJ, Reid DD, McCartney P. Prevalence and prognosis of electrocardiographic findings in middle-aged men. Br Heart J. 1978;40:636-643. [pmid: 656238]. [pmcid: 483461].
17 Pedoe HD. Predictability of sudden death from resting electrocardiogram. Effect of previous manifestations of coronary heart disease. Br Heart J. 1978;40:630-635. [pmid: 656237]. [pmcid: 483460].
18 Kannel WB, Cobb J. Left ventricular hypertrophy and mortality—results from the Framingham Study. Cardiology. 1992;81:291-298. [pmid: 1301257].
19 Brown DW, Giles WH, Croft JB. Left ventricular hypertrophy as a predictor of coronary heart disease mortality and the effect of hypertension. Am Heart J. 2000;140:848-856. [pmid: 11099987].
20 Dunn FG, McLenachan J, Isles CG, et al. Left ventricular hypertrophy and mortality in hypertension: an analysis of data from the Glasgow Blood Pressure Clinic. J Hypertens. 1990;8:775-782. [pmid: 2170517].
21 Kahn S, Frishman WH, Weissman S, Ooi WL, Aronson M. Left ventricular hypertrophy on electrocardiogram: prognostic implications from a 10-year cohort study of older subjects: a report from the Bronx Longitudinal Aging Study. J Am Geriatr Soc. 1996;44:524-529. [pmid: 8617900].
22 Larsen CT, Dahlin J, Blackburn H, et al. Prevalence and prognosis of electrocardiographic left ventricular hypertrophy, ST segment depression and negative T-wave; the Copenhagen City Heart Study. Eur Heart J. 2002;23:315-324. [pmid: 11812068].
23 Sullivan JM, Vander Zwaag RV, el-Zeky F, Ramanathan KB, Mirvis DM. Left ventricular hypertrophy: effect on survival. J Am Coll Cardiol. 1993;22:508-513. [pmid: 8335822].
24 Verdecchia P, Schillaci G, Borgioni C, et al. Prognostic value of a new electrocardiographic method for diagnosis of left ventricular hypertrophy in essential hypertension. J Am Coll Cardiol. 1998;31:383-390. [pmid: 9462583].
25 Liao YL, Liu KA, Dyer A, et al. Major and minor electrocardiographic abnormalities and risk of death from coronary heart disease, cardiovascular diseases and all causes in men and women. J Am Coll Cardiol. 1988;12:1494-1500. [pmid: 3192848].
26 Hames CG, Rose K, Knowles M, Davis CE, Tyroler HA. Black-white comparisons of 20-year coronary heart disease mortality in the Evans County Heart Study. Cardiology. 1993;82:122-136. [pmid: 8324775].
27 Sutherland SE, Gazes PC, Keil JE, Gilbert GE, Knapp RG. Electrocardiographic abnormalities and 30-year mortality among white and black men of the Charleston Heart Study. Circulation. 1993;88:2685-2692. [pmid: 8252679].
28 Kannel WB, Anderson K, McGee DL, Degatano LS, Stampfer MJ. Nonspecific electrocardiographic abnormality as a predictor of coronary heart disease: the Framingham Study. Am Heart J. 1987;113:370-376. [pmid: 3812192].
29 Daviglus ML, Liao Y, Greenland P, et al. Association of nonspecific minor ST-T abnormalities with cardiovascular mortality: the Chicago Western Electric Study. J Am Med Assoc. 1999;281:530-536.
30 Jones DW, Chambless LE, Folsom AR, et al. Risk factors for coronary heart disease in african americans: the atherosclerosis risk in communities study, 1987-1997. Arch Intern Med. 2002;162:2565-2571. [pmid: 12456228].
31 Knutsen R, Knutsen SF, Curb JD, Reed DM, Kautz JA, Yano K. The predictive value of resting electrocardiograms for 12-year incidence of coronary heart disease in the Honolulu Heart Program. J Clin Epidemiol. 1988;41:293-302. [pmid: 3339383].
32 Cullen K, Stenhouse NS, Wearne KL, Cumpston GN. Electrocardiograms and 13 year cardiovascular mortality in Busselton study. Br Heart J. 1982;47:209-212. [pmid: 6174132]. [pmcid: 481123].
33 Reunanen A, Pyorala K, Punsar S, Aromaa A. Predictive value of ECG findings with respect to coronary heart disease mortality. Adv Cardiol. 1978;21:310-312. [pmid: 619560].
34 Rabkin SW, Mathewson FL, Tate RB. The electrocardiogram in apparently healthy men and the risk of sudden death. Br Heart J. 1982;47:546-552. [pmid: 6177327]. [pmcid: 481180].
35 Sigurdsson E, Thorgeirsson G, Sigvaldason H, Sigfusson N. Unrecognized myocardial infarction: epidemiology, clinical characteristics, and the prognostic role of angina pectoris. The Reykjavik Study. Ann Intern Med. 1995;122:96-102. [pmid: 7993002].
36 Sigurdsson E, Sigfusson N, Sigvaldason H, Thorgeirsson G. Silent ST-T changes in an epidemiologic cohort study—a marker of hypertension or coronary heart disease, or both: the Reykjavik study. J Am Coll Cardiol. 1996;27:1140-1147. [pmid: 8609333].
37 Kannel WB, Abbott RD. A prognostic comparison of asymptomatic left ventricular hypertrophy and unrecognized myocardial infarction: the Framingham Study. Am Heart J. 1986;111:391-397. [pmid: 2936230].
38 Benjamin EJ, Levy D. Why is left ventricular hypertrophy so predictive of morbidity and mortality?. Am J Med Sci. 1999;317:168-175. [pmid: 10100690].
39 Kemp HG, Kronmal RA, Vlietstra RE, Frye RL. Seven year survival of patients with normal or near normal coronary arteriograms: a CASS registry study. J Am Coll Cardiol. 1986;7:479-483. [pmid: 3512658].
40 Sheifer SE, Manolio TA, Gersh BJ. Unrecognized myocardial infarction. Ann Intern Med. 2001;135:801-811. [pmid: 11694105].
41 Verdecchia P, Dovellini EV, Gorini M, et al. Comparison of electrocardiographic criteria for diagnosis of left ventricular hypertrophy in hypertension: the MAVI study. Ital Heart J. 2000;1:207-215. [pmid: 10806988].
42 Sox HC Jr, Garber AM, Littenberg B. The resting electrocardiogram as a screening test. A clinical analysis. Ann Intern Med. 1989;111:489-502. [pmid: 2528311].
43 Gordon DJ, Ekelund LG, Karon JM, et al. Predictive value of the exercise tolerance test for mortality in North American men: the Lipid Research Clinics Mortality Follow-up Study. Circulation. 1986;74:252-261. [pmid: 3731417].
44 Allen WH, Aronow WS, Goodman P, Stinson P. Five-year follow-up of maximal treadmill stress test in asymptomatic men and women. Circulation. 1980;62:522-527. [pmid: 7398012].
45 Jouven X, Ducimetiere P. Recovery of heart rate after exercise. N Engl J Med. 2000;342:662-663. [pmid: 10702064].
46 Cumming GR, Samm J, Borysyk L, Kich L. Electrocardiographic changes during exercise in asymptomatic men: 3-year follow-up. Can Med Assoc J. 1975;112:578-581. [pmid: 1116087]. [pmcid: 1956275].
47 Ekelund LG, Suchindran CM, McMahon RP, et al. Coronary heart disease morbidity and mortality in hypercholesterolemic men predicted from an exercise test: the Lipid Research Clinics Coronary Primary Prevention Trial. J Am Coll Cardiol. 1989;14:556-563. [pmid: 2768706].
48 Fleg JL, Gerstenblith G, Zonderman AB, et al. Prevalence and prognostic significance of exercise-induced silent myocardial ischemia detected by thallium scintigraphy and electrocardiography in asymptomatic volunteers. Circulation. 1990;81:428-436. [pmid: 2297853].
49 Froelicher VFJ, Thomas MM, Pillow C, Lancaster MC. Epidemiologic study of asymptomatic men screened by maximal treadmill testing for latent coronary artery disease. Am J Cardiol. 1974;34:770-776. [pmid: 4432807].
50 Giagnoni E, Secchi MB, Wu SC, et al. Prognostic value of exercise EKG testing in asymptomatic normotensive subjects. A prospective matched study. N Engl J Med. 1983;309:1085-1089. [pmid: 6621650].
51 Josephson RA, Shefrin E, Lakatta EG, Brant LJ, Fleg JL. Can serial exercise testing improve the prediction of coronary events in asymptomatic individuals?. Circulation. 1990;81:20-24. [pmid: 2297826].
52 McHenry PL, O'Donnell J, Morris SN, Jordan JJ. The abnormal exercise electrocardiogram in apparently healthy men: a predictor of angina pectoris as an initial coronary event during long- term follow-up. Circulation. 1984;70:547-551. [pmid: 6478560].
53 Rautaharju PM, Prineas RJ, Eifler WJ, et al. Prognostic value of exercise electrocardiogram in men at high risk of future coronary heart disease: Multiple Risk Factor Intervention Trial experience. J Am Coll Cardiol. 1986;8:1-10. [pmid: 3711503].
54 Lauer MS, Okin PM, Larson MG, Evans JC, Levy D. Impaired heart rate response to graded exercise. Prognostic implications of chronotropic incompetence in the Framingham Heart Study. Circulation. 1996;93:1520-1526. [pmid: 8608620].
55 Nishime EO, Cole CR, Blackstone EH, Pashkow FJ, Lauer MS. Heart rate recovery and treadmill exercise score as predictors of mortality in patients referred for exercise ECG. J Am Med Assoc. 2000;284:1392-1398.
56 Cole CR, Foody JM, Blackstone EH, Lauer MS. Heart rate recovery after submaximal exercise testing as a predictor of mortality in a cardiovascularly healthy cohort. Ann Intern Med. 2000;132:552-555. [pmid: 10744592].
57 Wei M, Kampert JB, Barlow CE, et al. Relationship between low cardiorespiratory fitness and mortality in normal-weight, overweight, and obese men. J Am Med Assoc. 1999;282:1547-1553.
58 Roger VL, Jacobsen SJ, Pellikka PA, Miller TD, Bailey KR, Gersh BJ. Prognostic value of treadmill exercise testing: a population-based study in Olmsted County, Minnesota. Circulation. 1998;98:2836-2841. [pmid: 9860784].
59 Blair SN, Kohl HW 3rd, Barlow CE, Paffenbarger RS Jr, Gibbons LW, Macera CA. Changes in physical fitness and all-cause mortality. A prospective study of healthy and unhealthy men. J Am Med Assoc. 1995;273:1093-1098.
60 Davies B, Ashton WD, Rowlands DJ, et al. Association of conventional and exertional coronary heart disease risk factors in 5,000 apparently healthy men. Clin Cardiol. 1996;19:303-308. [pmid: 8706370].
61 Hopkirk JA, Leader S, Uhl GS, Hickman JRJ, Fischer J. Limitation of exercise-induced R wave amplitude changes in detecting coronary artery disease in asymptomatic men. J Am Coll Cardiol. 1984;3:821-826. [pmid: 6693653].
62 Dunn RL, Matzen RN, VanderBrug-Medendorp S. Screening for the detection of coronary artery disease by using the exercise tolerance test in a preventive medicine population. Am J Prev Med. 1991;7:255-262. [pmid: 1790029].
63 Uhl GS, Kay TN, Hickman JRJ. Computer-enhanced thallium scintigrams in asymptomatic men with abnormal exercise tests. Am J Cardiol. 1981;48:1037-1043. [pmid: 6975560].
64 Bruce RA, Hossack KF, DeRouen TA, Hofer V. Enhanced risk assessment for primary coronary heart disease events by maximal exercise testing: 10 years' experience of Seattle Heart Watch. J Am Coll Cardiol. 1983;2:565-573. [pmid: 6875120].
65 Bruce RA, Fisher LD. Exercise-enhanced assessment of risk factors for coronary heart disease in healthy men. J Electrocardiol. 1987;20(Suppl):162-166. [pmid: 3500993].
66 Diamond GA, Forrester JS. Analysis of probability as an aid in the clinical diagnosis of coronary-artery disease. N Engl J Med. 1979;300:1350-1358. [pmid: 440357].
67 Gianrossi R, Detrano R, Mulvihill D, et al. Exercise-induced ST depression in the diagnosis of coronary artery disease. A meta-analysis. Circulation. 1989;80:87-98. [pmid: 2661056].
68 Ashley EA, Myers J, Froelicher V. Exercise testing in clinical medicine. Lancet. 2000;356:1592-1597. [pmid: 11075788].
69 Froelicher VF, Callaham PR, Angelo J, Lehmann KG. Treadmill exercise testing and silent myocardial ischemia. Isr J Med Sci. 1989;25:495-502. [pmid: 2681058].
70 Kwok Y, Kim C, Grady D, Segal M, Redberg R. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. 1999;83:660-666. [pmid: 10080415].
71 Coplan NL, Fuster V. Limitations of the exercise test as a screen for acute cardiac events in asymptomatic patients. Am Heart J. 1990;119:987-990. [pmid: 2321524].
72 O'Rourke RA, Brundage BH, Froelicher VF, et al. American College of Cardiology/American Heart Association Expert Consensus document on electron-beam computed tomography for the diagnosis and prognosis of coronary artery disease. Circulation. 2000;102:126-140. [pmid: 10880426].
73 Pletcher M, Pignone M, Tice J, Browner W. Using coronary artery calcium, as measured by electron beam computerized tomography to predict coronary heart disease events: A meta-analysis. J Am Med Assoc. Submitted.
74 Agatston AS, Janowitz WR, Kaplan GS, et al. Electron beam CT coronary calcium predicts future coronary events. 1996;94 (Suppl 1): 8:I-360.
75 Yang T, Doherty TM, Wong ND, Detrano RC. Alcohol consumption, coronary calcium, and coronary heart disease events. Am J Cardiol. 1999;84:802-806. [pmid: 10513777].
76 Arad Y, Spadaro LA, Goodman K, Newstein D, Guerci AD. Prediction of coronary events with electron beam computed tomography. J Am Coll Cardiol. 2000;36:1253-1260. [pmid: 11028480].
77 Wong ND, Hsu JC, Detrano RC, Diamond G, Eisenberg H, Gardin JM. Coronary artery calcium evaluation by electron beam computed tomography and its relation to new cardiovascular events. Am J Cardiol. 2000;86:495-498. [pmid: 11009264].
78 Raggi P. Coronary calcium on electron beam tomography imaging as a surrogate marker of coronary artery disease. Am J Cardiol. 2001;87:27A-34A.
79 Sheridan S, Pignone M, Donohue K. Screening for Hypertension: a review of evidence for the US Preventive Services Task Force. Rockville, Md: Agency for Healthcare Research and Quality; Upcoming.
80 Conti CR, Bourassa MG, Chaitman BR, et al. Asymptomatic cardiac ischemia pilot (ACIP).Trans Am Clin Climatol Assoc. 1994;106.
81 Sox HC Jr, Littenberg B, Garber AM. The role of exercise testing in screening for coronary artery disease. Ann Intern Med. 1989;110:456-469. [pmid: 2493211].
82 Multi-Ethnic Study of Atherosclerosis (MESA). MESA. accessed October 29, 2002. Web Page. Available at: http://http:/140.142.220.4/mesa/.