# Acknowledgments

We acknowledge the assistance of Jacqueline Besteman, JD, the Director of the AHRQ EPC Programs, David Atkins, MD, MPH, Chief Medical Officer of the AHRQ Center for Practice Technology and Assessment, Jean Slutsky, PA, MSPH, AHRQ Task Order Officer. We also thank Paul Frame, MD, Tri-County Family Medicine, Cohocton, NY and Carolyn Westhoff, MD, MPH, Department of Obstetrics and Gynecology, Columbia University, New York, NY, our liaisons for the US Preventive Services Task Force. We extend our appreciation as well to the RTI-UNC EPC Co-Director, Kathleen Lohr, PhD, and the RTI-UNC EPC staff: Sonya Sutton, BSPH, and Loraine Monroe of RTI International, and Carol Krasnov, formerly of the University of North Carolina at Chapel Hill Cecil G. Sheps Center for Health Services Research.