# Discussion

We identified no studies that examined the effect of screening for ACAD on health outcomes such as CHD events or mortality. Two studies of fair quality found mixed results with respect to the effect of EBCT results on self-reported adoption of CHD risk-reducing treatments. ECG, ETT and EBCT all appear to provide some independent prognostic information for at least some patients, above and beyond the prognostic information that can be gained from a traditional assessment of risk factors. The effect of this additional information on clinical decision-making, however, has not been assessed.

The additional value of screening for ACAD is likely to be small for patients in whom the prevalence of the disease is low, such as young adults; such screening would produce large numbers of false-positive results. In such cases, the costs and harms associated with additional testing and possibly labeling might exceed any benefits from screening. In older adults, for whom CHD risk is generally higher, the tests will perform better, but whether the benefits of such tests exceed the downsides in middle-aged and older adults is still unclear and awaits further investigation. Screening has been advocated for people with high-risk occupations, but we did not identify new studies examining the effect of screening such patients. Also uncertain is whether testing for ACAD leads to more effective and efficient use of risk-reducing strategies than would be the case for traditional risk factor analysis alone. Data from studies of patients with known CHD but no ischemic symptoms suggest that treatment with medications, such as beta-blockers, or revascularization can improve outcomes over no treatment, but whether the same results would be found in a population of patients with no previous CHD history is unclear.^80^

Even if we assume that the additional information is helpful, few studies have examined the cost-effectiveness of screening for ACAD. In 1989, Sox and colleagues used a decision analysis model to estimate the effectiveness and cost-effectiveness of exercise testing in asymptomatic adults.^81^ Their model was structured so that the main benefit of screening was achieved through detection of patients with severe disease who would benefit from revascularization.

They found that screening average 60 year old men had a cost per life-year saved of $24,600; for women, the cost was $47,606. For 40 year olds, the cost-effectiveness ratios were much larger: $80,349 per life year saved for men and $216,496 per life year saved for women. The presence or absence of CHD risk factors affected the cost-effectiveness ratios. For 60 year old men with no risk factors, the cost per life year saved was $44,332; for men with 1 or more CHD risk factors, it was $20,504. The authors concluded that routine screening was not warranted in general; for persons at increased risk for CHD (e.g., older men with one or more risk factors), however, it may be beneficial.

Although such projections about cost-effectiveness from models are helpful, a better appreciation of the actual benefit from screening would come from one or more adequately powered randomized trials of screening compared to traditional risk factor-based management using global CHD risk assessment and enrolling a broad spectrum of patients, including a sufficient number of women.

Future research also needs to examine the independent prognostic information from EBCT in the context of accurate measurement of traditional risk factors and a sufficient period of follow-up. The large Multi-Ethnic Study of Atherosclerosis (MESA) study,^82^ which is currently ongoing, will help in this regard. Studies examining how providers and patients apply the additional information about risk from tests for ACAD would also be helpful. Finally, better information about the adverse effects of screening is required if researchers are to perform well-informed cost-effectiveness analyses of ACAD screening compared with risk-factor-based decisionmaking.