# Results

We examined the effect of screening for ACAD on health outcomes, the adoption of risk-reducing behaviors, and ability to predict independently the risk of CHD events.

## Effect of Screening Tests on Health Outcomes

We identified no studies that examined the effect of screening tests for ACAD on CHD or other health outcomes. A subgroup analysis of the Multiple Risk Factor Intervention Trial found that patients with an abnormal exercise treadmill test, defined by abnormal heart rate-corrected ST depression, had a lower risk for CHD mortality with risk factor modification than patients in usual-care control group who also had this finding but did not receive specific advice about risk factor reduction.^8^

## Effect of Screening on Adoption of Risk-reducing Behaviors

We identified two studies of fair quality that examined the impact of EBCT results on subsequent risk-reducing behaviors.^9,^ ^10^ Wong and colleagues conducted a nonrandomized study in which they administered questionnaires at baseline and 1 to 2 years after an EBCT scan to 703 asymptomatic men and women.^9^ Using logistic regression to control for other CHD risk factors present at baseline, they found that the presence of calcium on EBCT (CAC score > 0) was associated with statistically significant increases in self-report of new aspirin use (relative risk [RR], 1.86), new lipid-lowering medication use (RR, 3.54), use of vitamin E (RR, 1.62), decreased consumption of dietary fat (RR, 1.58), and increased worry (RR, 2.73).

O'Malley and colleagues surveyed 144 asymptomatic smokers from a cohort of 3,035 individuals who underwent EBCT at the Walter Reed Army Medical Center.^10^ Response rate was 69% (99 of 144). The mean response time was 8.4 months post-scan. Mean age was 50 and 68% were men; most (80%) were self-referred. Increased perception of CHD risk was more common among patients with positive scans than among those with no coronary calcium (40% vs. 12%). Many patients (59%) reported being more motivated to quit smoking after the scan but neither motivation nor stage of behavioral change was associated with the presence of calcium on the scan. Smoking cessation rates were similar in those with and without calcium on their scans (14% and 12%, respectively).

## Effect of Screening on Risk of Future CHD Events

Many studies have examined the value of ECG, ETT, and EBCT in predicting risk of future CHD events. The next 3 sections of the report will consider this evidence.

### Resting Electrocardiogram (ECG)

In a recent systematic review examining the role of ECGs in asymptomatic adults, Ashley and colleagues identified 22 cohort studies that were of at least 5 years' duration and investigated the prevalence of abnormal ECG findings and their ability to predict cardiovascular mortality.^11^ Some studies specifically searched for and excluded patients with any symptoms of cardiovascular disease; others excluded only patients with diagnosed cardiovascular disease. In these studies, the prevalence of the most common ECG abnormalities (Q waves, left ventricular hypertrophy (LVH), bundle branch blocks, and ST segment depression) ranged from 1% to 10%. Abnormal results were more common in men and increased with age. Another common finding, the presence of unrecognized atrial fibrilliation, is not examined further here but may have important health benefits.

Each of the main ECG abnormalities was associated with increases in the risk of CVD mortality. No summary estimates of the magnitude of increased risk were calculated. The sensitivity of ECG abnormalities for all-cause mortality was low (32% for any major abnormality in one study), but the specificity was relatively high (87%).^11^ Another review from 1995 found similar results.^12^

Our review identified a similar set of large, fair or good quality observational cohort studies that examined the prognostic importance of abnormal findings on the resting ECG of asymptomatic persons.^13^–^38^ They are described below with respect to silent myocardial infarction (Q waves), LVH, ST segment and T wave changes, and various combined ECG changes (Tables 1A – 1G).

Table 1A Association Between Resting ECG Abnormalities and Risk of Coronary Heart Disease Mortality in Asymptomatic Individuals: Q waves

Authors and Year | No. of Subjects in Study | Age Range (years) and Sex (% male) | Participants | Follow-up (years) | Prevalence of Finding | Relative Risk for CHD Mortality (95% CI) | Relative Risk Adjusted for the Following Variables
Pedoe et al., 1978^17^ | 8,228* | 40–59 | Employed men in the UK | 4 | 1.0% | 4 | None or not reported
| | 100%
Reunanen et al., 1978^33^ | 3,600* | 30–59 | Men ages 30 to 59 | 5 | Not reported | 1 | Age and follow-up time
| | 100%
Rose et al., 1978^16^ | 15,974^†^ | 40–64 | British civil servants living in London, England | 5 | 1.6% | 4.2^‡^ (2.3–8.0) | Age
| | 100%
Kannel and Abbott, 1986^37^ | Not reported | Not reported | Framingham residents (mainly white) | 10 | Men 4.2% | Men, 3.2 | Age
| | | | | Women 2.5% | Women, 4.8
Sigurdsson et al., 1996^35^ | 9,139 | 35–60 | Residents of Reykjavik, Iceland | 4–24 | Not reported | 7.0 (4.9–10.0) | Age, blood pressure, lipids, blood sugar, smoking
| | 100%
Menotti et al., 1997^14^ | 22,553 | 30–69 | Italians | 6 | Men 0.2–1.4% | 1.25 (0.26–5.31) | ECG abnormality, age, SBP, chol, smoking, BMI
| | 54% | | | Women 0.4–1.5% | 9.88 (1.05–92.6)
Menotti et al., 2001^15^ | 1,785 | 65–84 | Europeans | 10 | 6.8% | 2.25 (1.43–3.55) | Age, SBP, chol, BMI, smoking, cohort (country)
| | 100%

* Asymptomatic subset of study population.

† Approximate number of asymptomatic subjects.

‡ Point estimate of relative risk and confidence intervals calculated by Sox et al., 1989.^42^

§ Two-year cumulative incidence.

∥ Total study population; performed subset analysis on group of asymptomatic men.

¶ Varies with age.

Table 1G Association between Resting ECG Abnormalities and Risk of Coronary Heart Disease Mortality in Asymptomatic Individuals: Minor ECG Changes

Authors and Year | No. of Subject in Study | Age Range (years) and Sex (% male) | Participants | Follow- Up (years) | Prevalence of Minor ECG Changes | Relative Risk for CHD Mortality (95% CI) | Relative Risk Adjusted for the Following Variables
Kannel et al., 1987^28^* | 5,127 | 44–74 | Framingham residents (mainly white) | 30 | Men 8.5% | 3.7^†^ | Age
| | 44% | | | | 2.0^†^ (event)
| | | | | Women 7.7% | 3.0^†^
| | | | | | 2.0^†^ (event)
Knutsen et al., 1988^31^‡ | 7,682 | 45–68 | Men of Asian descent living in Honolulu, Hawaii | 12 | 10% | 2.2 (1.5–3.2) | Age
| | 68% | | | | 1.4 (1.1–1.7) (event)
Liao et al., 1988^25^§ | 17,633 | 40–64 | White residents of Chicago | 11.5 | Men 7.3% | 2.1 | Age, DBP, cholesterol, smoking, diabetes, anti-HTN meds
| | 55% | | | Women 4.5% | 1.5
Hames et al., 1993^26^§ | 2,216 | ≥40 | Black and white residents of Evans Co., GA | 20 | Men 20–40^#^ | 1.22 (0.78–1.92) | Age, SES, race, prevalent CHD, SBP, smoking, chol, BMI, major ECG changes
| | 47% | | | Women 20–40%^#^ | 131 (0.56–2.57)
Sutherland et al., 1993^27^§ | 642 whites | 35–74 | Black and white men in Charleston, SC | 30 | White 13.2% | 1.25 (0.92–1.70) | Age, SBP, chol, BMI, smoking, DM, education, ECG abnormality
| 328 blacks | 100% | | | Black 16.0% | 0.79 (0.52–1.19)
De Bacquer et al., 1998^13^** | 9,954 | 25–74 | Belgian residents (mainly white) | 10 | 1.9% | 1.0 (0.6–1.6) | Age, diabetes, BMI, SBP, total cholesterol, HDL, smoking, anti-HTN meds, other ECG changes
| | 52% | | | 1.5% | 1.6 (0.8–3.1)
Daviglus et al., 1999^29^†† | 1,673 | 40–55 | Men employed at the Western Electric Co. in Chicago | 29 | 1.2%^#^ | 2.4 (1.4–4.1) | Age, education, SBP, smoking, cholesterol, BMI and BMI2
| | 100%

BMI, body mass index; CHD, coronary heart disease; CI, confidence intervals; CVD, cardiovascular disease; DBP, diastolic blood pressure; HDL, high density lipoprotein cholesterol; HTN, hypertension; LDL, low density lipoprotein cholesterol; LVH, left ventricular hypertrophy; MC, Minnesota code; MI, myocardial infarction; SBP, systolic blood pressure

* Minor ECG changes defined as: In the absence of high R wave, there was ST segment depression > 1 mm and/or abnormal T wave flattening or inversion.

† For ages 35–64 years. No confidence intervals reported, but P < 0.001.

‡ Minor ECG changes defined as: Borderline Q wave (MC 1.3), borderline ST depression (MC 4.3), borderline T wave inversion (MC 5.3), 1° AVB (MC 6.3), high R wave (MC 3.1, 3.2), LAD (MC 2.1), RAD (MC 2.2).

§ Minor ECG changes as defined as: Borderline Q wave (MC 1.3), borderline ST depression (MC 4.3), borderline T wave inversion (MC 5.3), 1° AVB (MC 6.3), high R wave (MC 3.1, 3.2), LAD (MC 2.1), RAD (MC 2.2), low QRS voltage (MC 9.1).

∥ P < 0.01.

¶ P > 0.05.

# Varies with age and race.

** Minor ECG changes defined as Borderline Q wave (MC 1.3), borderline ST depression (MC 4.3), borderline T wave inversion (MC 5.3), high R wave (MC 3.1, 3.2), LAD (MC 2.1), RAD (MC 2.2), low QRS voltage (MC 9.1).

†† Minor ECG changes defined as: Mild ST depression (MC 4.3, 4.4), mild T wave abnormality (MC 5.3, 5.4).

‡‡ The percentage of men with three or more ECG with minor abnormalities within the follow-up period.

Q waves or silent myocardial infarction. Abnormal Q waves on ECG are often considered evidence of prior myocardial infarction, although they will be seen in a small proportion of patients with angiographically normal coronary arteries.^39^ The interim development of Q waves on ECG without clinical evidence of a myocardial infarction is considered a clinically unrecognized or “silent” myocardial infarction.

Several cohort studies have examined the incidence and prevalence of Q waves on ECG. Sheifer and colleagues performed a systematic review of these studies.^40^ They found that 20% to 40% of all myocardial infarctions identifiable on ECG were clinically unrecognized. The presence of ECG findings that are diagnostic of myocardial infarction (e.g., Q waves) appears to portend a high risk of future CHD events that may approach that of patients after recognized myocardial infarction (Table 1A).^14^–^17,^ ^33,^ ^35,^ ^37^

As an example, Sigurdsson and colleagues examined the prevalence of unrecognized myocardial infarction in a large cohort study of men in Iceland.^35^ On ECG, it was 0.5% at age 40 but increased to 5.5% at age 75. Unrecognized myocardial infarction was associated with a relative risk of 7.0 (95% Confidence Interval [CI], 4.9 – 10.0) for future death from CHD. Three other studies have reached similar results,^16,^ ^17,^ ^37^ but at least one study found no relationship.^33^

Left ventricular hypertrophy (LVH). ECG can detect LVH, but its sensitivity is low.^41^ The presence of LVH on ECG, however, is strongly associated with adverse CHD-related events.^38^ We identified several studies examining the effect of ECG LVH on the relative risk for CHD events (Table 1B).^13,^ ^15,^ ^17^–^24,^ ^31,^ ^34^

Table 1B Association Between Resting ECG Abnormalities and Risk of Coronary Heart Disease Mortality in Asymptomatic Individuals: Left Ventricular Hypertrophy

Authors and Year | No. of Subjects in Study | Age Range (years) and Sex (% male) | Participants | Follow-up (years) | Prevalence of LVH (VO) or LVH (VS) | Relative Risks for CHD Mortality (95% CI) | Relative Risk Adjusted for the Following Variables
Pedoe et al., 1978^17^ | 8,228 | 40–59 | Employed men in the UK | 4.3 | VO, 2.5% | 1.6 | Not reported
| | 100%
Rabkin et al., 1982^34^ | 3,983 | 15–64 | Pilots in the Royal Canadian Air Force during WWII | 30 | VS, 6.4% | 3.1* | Age
| | 100%
Knutsen et al., 1988^31^ | 7,682 | 45–68 | Men of Asian descent living in Honolulu, Hawaii | 12 | VS, 0.6% | 11.4 (5.9–22.5) | Age
| | 100%
Dunn et al., 1990^20^ | 3,275 | Mean, 50 | Hypertensive patients of Glasgow Blood Pressure Clinic, UK | 6.5 | VO, men 21.7% | 2.7* | Age
| | 49% | | | VS, men 12.8% | 4.0*
| | | | | VO, women 12.7% | 2.0*
| | | | | VS, women 8.8% | 2.3*
Kannel et al., 1992^18^ | 5,209 | 30–62 | Framingham residents (mainly white) | 30 | VS, men 9.7% | 5.6* | Age
| | | | | | 4.7* (morbidity)
| | | | | VS, women 5.6% | 5.0*
| | | | | | 7.4* (morbidity)
Sullivan et al., 1993^23^ | 4,824 | Mean, 55 | Memphis residents (mainly white) | 5 | VS, 5.2%^†^ | 1.9 | Not reported
| | 57%
Sutherland et al., 1993^27^ | 642 Whites | 35–74 | Black and white men in Charleston, SC | 30 | VS, white 0.9% | 5.61 (1.25 – 25.22) | Age, SBP, chol, BMI, smoking, DM, education
| 328 Blacks | 100% | | | VS, black 9.8% | 1.10 (0.46 – 2.68)
Kahn et al., 1996^21^ | 459 | 75–85 | Bronx residents (mainly white) | 6 | VS, 9.2% | 2.0 (1.16–3.46) | Age, sex, HTN, diabetes, BMI, cholesterol, digoxin use, cardiomegaly on chest x-ray, smoking, prior MI^‡^
| | 35% | | | | 1.7 (0.90–3.27) (morbidity)
Menotti et al., 1997^14^ | 22,553 | 30–69 | Italians | 6 | VO, men 5.1–7.4% | 1.62 (0.86–3.05) | ECG abnormality, age, SBP, chol, smoking, BMI
| | 54% | | | VS, men 0.5% | 6.51 (2.69–15.8)
| | | | | VO, women 1.5–4.2% | 5.14 (0.94–28.1)
| | | | | VS, women 0.5% | 14.6 (1.57–?)
De Bacquer et al., 1998^13^ | 9,954 | 25–74 | Belgian residents (mainly white) | 10 | VS, men 0.8% | 1.8 (0.4–7.6) | Age, diabetes, BMI, SBP, total cholesterol, HDL, smoking, anti-HTN meds, other major ECG changes
| | 52% | | | VS, women 0.5% | 1.9 (0.3–14.1)
Verdecchia et al., 1998^24^ | 1,717 | Mean, 52 | Hypertensive Italians | 3.3 | VS, 17.8% | 4.2 (2.1–8.7) | Age, diabetes, previous CVD events
| | 51%
Brown et al., 2000^19^ | 7,924 | 25–74 mean, 49.2 | NHANES II (1976-92) (10% black) | 16.8 | VS, 1.3% | 2.0 (1.2–3.5) | Age, sex, diabetes, BMI, SBP, total cholesterol, smoking, history of CVD^#^
| | 47.6%
Menotti et al., 2001^15^ | 1,785 | 65–84 | Europeans | 10 | VO, 15% | 1.05 (0.68–1.3) | Age, SBP, chol, BMI, smoking, cohort (country)
| | 100% | | | VS, 4.9% | 1.65 (0.93–2.92)
Jones et al., 2002^30^ | 10,368 white | 45–64 | Blacks and whites in MD, NC, MN, MS | 10 | VS, white men 0.8% | 1.6 (0.8–0 3.4)** | Age
| 3,694 blacks | 43% | | | VS, white women 0.9% | 2.2 (0.8–5.9)**
| | | | | VS, black men 5.9% | 2.0 (1.1–3.6)**
| | | | | VS, black women 5.3% | 5.9 (3.6–9.7)**
Larsen et al., 2002^22^ | 11,634 | 25–74 | Copenhagen City residents (mainly white) | 21 | VO, men 19.3% | 1.1 (0.9–1.2) | Sex, diabetes, BMI, DBP, heart rate, total cholesterol, smoking
| | 45% | | | VS, men 1.1% | 1.9 (1.5–2.5)
| | | | | VO, women 5.6% | 1.1 (0.9–1.2)
| | | | | VS, women 0.6% | 1.9 (1.5–2.5)

BMI, body mass index; BP, blood pressure; CHD, coronary heart disease; CI, confidence intervals; CVD, cardiovascular disease; DBP, diastolic blood pressure; HDL, high density lipoprotein cholesterol; HTN, hypertension; LDL, low-density lipoprotein cholesterol; LVH, left ventricular hypertrophy; meds, medications; MI, myocardial infarction; SBP, systolic blood pressure; VO, Voltage only; VS, Voltage with Strain pattern.

* Confidence intervals not reported, but p value reported to be < 0.05.

† Includes LVH by voltage criterion only and persons with LVH by voltage criterion and strain pattern.

‡ 13.9% reported history of previous myocardial infarction.

§ Varies with age.

∥ LVH diagnosis using the Perugia score.

¶ 2% reported previous history of cardiovascular events.

# 4% reported history of previous myocardial infarction.

** Hazard ratio for all CHD events (including mortality).

Most studies examined LVH prevalence in terms of repolarization abnormalities (so-called LVH with strain, labeled VS in Table 1B); this finding is less common than LVH defined only by voltage criteria (VO) and is more strongly associated with risk of cardiovascular events and mortality. The prevalence of ECG LVH with repolarization abnormalities generally ranged from 1.0% to 10%. Studies that adequately adjusted for other risk factors found that the presence of LVH with repolarization abnormalities was associated with a relative risk of between 1.8 and 4.4 for CHD mortality.

A small number of studies investigated LVH defined by voltage-only criteria.^17,^ ^20,^ ^22^ Using this definition, prevalence was higher: approximately 20% in men and 6% to 13% in women. The study by Larsen and colleagues, which was the only one to adjust for other CHD risk factors, found no increased risk from LVH defined by voltage criteria alone (RR, 1.07; 95% CI, 0.92 to 1.24).^22^

ST segment and T wave changes. Some studies examined the prognostic value of ST segment depression, T wave inversions, or both, on ECG (Tables 1C and 1D).^13^–^17,^ ^22,^ ^31,^ ^34,^ ^36^ The overall prevalence of ST segment or T wave changes ranged from 1% to 10% and increased with age. After adjustment for other risk factors, these findings were generally associated with an increase in the relative risk for CHD events of 1.7 to 4.0.

Table 1C Association Between Resting ECG Abnormalities and Risk of Coronary Heart Disease Mortality in Asymptomatic Individuals: ST Segment Depression

Authors and Year | No. of Subjects in Study | Age Range (years) and Sex (% male) | Participants | Follow-up (years) | Prevalence of ST Segment Depression | Relative Risk for CHD Mortality (95% CI) | Relative Risk Adjusted for the Following Variables
Pedoe et al., 1978^17^ | 8,228 | 40–59 | Employed men in the UK | 4.3 | 2.3% | 3.5 | Not reported
| | 100%
Rose et al., 1978^16^ | 15,974* | 40–64 | British civil servants living in London, England | 5 | 0.9% | 2.4^†^ (0.8–7.0) | Age
| | 100%
Rabkin et al., 1982^34^ | 3,983 | 15–64 | Pilots in the Royal Canadian Air Force during WWII | 30 | 16.9% | 4.7 | Age
| | 100%
Knutsen et al., 1988^31^ | 7,682 | 45–68 | Men of Asian descent living in Honolulu, Hawaii | 12 | Major, 1.3% | 6.2 (3.5–11.1) | Age
| | 100% | | | | 3.0 (1.9–4.8) (event)
| | | | | Minor, 0.5% | 3.1 (1.1–8.6)
| | | | | | 2.1 (0.9–4.4) (event)
Sutherland et al., 1993^27^‡ | 642 whites 328 blacks | 35–74 | Black and white men in Charleston, SC | 30 | White 8.2 % | 1.77 (1.23–2.55) | Age, SBP, chol, BMI, smoking, DM, education
| | 100% | | | Black 29.4% | 1.12 (0.81–1.56)
Sigurdsson et al., 1996^36^ | 9,139 | 35–60 | Residents of Reykjavik, Iceland | 4–24 | 2% to 30% varied by age | 2.0 (1.6–2.5) | Age, blood pressure, lipids, blood sugar, smoking
| | 100%
Menotti et al., 1997^14^‡ | 22,553 | 30–69 | Italians | 6 | Men 2.0–7.2% | 3.76 (2.26–6.28) | ECG abnormality, age, SBP, chol, smoking, BMI
| | 54% | | | Women 4.3–9.6% | 1.03 (0.13–8.46)
De Bacquer et al., 1998^13^ | 9,954 | 25–74 | Belgian residents (mainly white) | 10 | Men 1.6% | 3.5 (1.8–6.8) | Age, BMI, SBP, total cholesterol, HDL, diabetes, smoking, anti-HTN meds, other major ECG changes
| | 52% | | | Women 2.7% | 2.6 (1.0–7.0) (event)
Menotti et al., 2001^15^‡ | 1,785 | 65–84 | Europeans | 10 | 22% | 1.53 (1.09–2.15) | Age, SBP, chol, BMI, smoking, cohort (country)
| | 100%
Larsen et al., 2002^22^ | 11,634 | 25–74 | Residents of Copenhagen, Denmark (mainly white) | 21 | Men 1.2% | 1.7 (1.4–2.2) (death) | SBP, DBP, HR, BMI, total cholesterol, diabetes, smoking, sex, alcohol use, physical exercise, family history of CHD
| | 45% | | | Women 2.2% | 1.8 (1.4–2.3) (events)

BMI, body mass index; CHD, coronary heart disease; CI, confidence intervals; CVD, cardiovascular disease; DBP, diastolic blood pressure; ECG, electrocardiographic; HDL, high-density lipoprotein cholesterol; HR, heart rate; HTN, hypertension; LDL, low-density lipoprotein cholesterol; LVH, left ventricular hypertrophy; MI, myocardial infarction; SBP, systolic blood pressure.

* Asymptomatic subset of study population.

† Point estimate of relative risk and confidence intervals calculated by Sox et al., 1989.^42^

‡ Includes T-wave inversion

§ Total study population; performed subset analysis on group of asymptomatic men.

∥ Varies with age

Table 1D Association between Resting ECG Abnormalities and Risk of Coronary Heart Disease Mortality in Asymptomatic Individuals: T Wave Inversions

Authors and Year | No. of Subjects in Study | Age Range (years) and Sex (% male) | Participants | Follow-up (years) | Prevalence of T Wave Inversion | Relative Risk for CHD Mortality (95% CI) | Relative Risk Adjusted for the Following Variables
Pedoe et al., 1978^17^ | 8,228 | 40–59 | Employed men in the UK | 4.3 | 6.0 | 3.8 | Not reported
| | 100%
Rose et al., 1978^16^ | 15,974 | 40–64 | British civil servants living in London, England | 5 | 3.3% | 3.2* (1.9–5.3) | Age
| | 100%
Knutsen et al., 1988^31^ | 7,682 | 45–68 | Men of Asian descent living in Honolulu, Hawaii | 12 | Major, 2.3% | 5.1 (3.1–8.3) | Age
| | 100% | | | | 2.5 (1.7–3.7) (event)
| | | | | Minor, 1.2% | 3.5 (1.7–7.5)
| | | | | | 3.0 (1.8–5.0) (event)
De Bacquer et al., 1998^13^ | 9,954 | 25–74 | Belgian residents (mainly white) | 10 | Men 6.1% | 2.1 (1.2–3.4) | Age, BMI, SBP, total cholesterol, HDL, diabetes, smoking, anti-HTN meds, other major ECG changes
| | 52% | | | Women 9.6% | 1.9 (0.9–3.9)
Larsen et al., 2002^22^ | 11,634 | 25–74 | Residents of Copenhagen, Denmark (mainly white) | 21 | Men 5.3% | 1.5 (1.3–1.8) | SBP, DBP, HR, BMI, total cholesterol, diabetes, smoking, sex, alcohol use, physical exercise, family history of CHD
| | 45% | | | Women 5.3% | 1.5 (1.3–1.7) (event)

BMI, body mass index; CHD, coronary heart disease; CI, confidence intervals; CVD, cardiovascular disease; DBP, diastolic blood pressure; ECG, electrocardiographic; HDL, high-density lipoprotein cholesterol; HTN, hypertension; LDL, low-density lipoprotein cholesterol; LVH, left ventricular hypertrophy; MI, myocardial infarction; SBP, systolic blood pressure.

* Point estimate of relative risk and confidence intervals calculated by Sox et al., 1989.^39^

As an example, Sigurdsson and colleagues examined the independent effect of ST segment depression detected in asymptomatic patients participating in the Reykjavik Heart Study, which began in 1967.^36^ Prevalence was related to age: 2% at age 40, 4% at age 50, 9% at age 60, 17% at age 70, and 30% at age 80. After adjustment for other CHD risk factors, they reported that ST segment depression was associated with a relative risk of 1.6 (95% CI, 1.0 to 2.8) for future angina or myocardial infarction and 2.0 (95% CI, 1.6 to 2.5) for CHD death.

Ventricular ectopy. The presence of premature ventricular impulses (ventricular arrythmia) on ECG also predicts increased risk of future CHD events. We identified 6 studies that examined the prevalence of ventricular ectopy and its effect on future CHD events (Table 1E).^16,^ ^17,^ ^31^–^34^ Prevalence varied from 0.8% to 11%. Relative risk of CHD death was increased in each study except one; the increase in risk ranged from 2.1^31,^ ^34^ to 4.0.^32^

Table 1E Association between Resting ECG Abnormalities and Risk of Coronary Heart Disease Mortality in Asymptomatic Individuals: Ventricular Ectopic Activity

Authors and Year | No. of Subjects in Study | Age Range (years) and Sex (% male) | Participants | Follow-up (years) | Prevalence of Ventricular Ectopy | Relative Risk for CHD Mortality (95% CI) | Relative Risk Adjusted for the Following Variables
Pedoe et al., 1978^17^ | 8,228 | 40–59 | Employed men in the UK | 4.3 | 1.3% | 0.8 (0.04–12.3) | Not reported
| | 100%
Reunanen et al., 1978^33^ | 3,660* | Not reported | Men aged 30–59 | 5 | Not reported | 3.5 | Not reported
Rose et al., 1978^16^ | 15,974^†^ | 40–64 | British civil servants living in London, England | 5 | 1.3% | 3.4‡ (1.5–7.5) | Age
| | 100%
Cullen et al., 1982^32^ | 1,497^†^ | 40–79 | Men and women | 13 | 3% | 2.1 | Not reported
| | 50%
Rabkin et al., 1982^34^ | 3,983 | 15–64 | Pilots in the Royal Canadian Air Force during WWII | 30 | 11% | 4.0 | Age
| | 100%
Knutsen et al., 1988^31^ | 7,682 | 45–68 | Men of Asian descent living in Honolulu, Hawaii | 12 | 0.8% | 4.0 (1.7–9.6) | Age
| | 100% | | | | 1.4 (0.6–3.0) (event)

* Approximate number of asymptomatic subjects.

† Asymptomatic subset of study population.

‡ Point estimate of RR and confidence intervals calculated by Sox et al., 1989.^39^

Grouped ECG abnormalities. In addition to individual ECG findings, several studies examined whether the incidence and prevalence of groups of “major” or “minor” ECG changes affected the risk of future CHD events.^13,^ ^25^–^29,^ ^31^

Studies that examined the impact of major ECG changes (principally major ST segment or T wave changes, conduction blocks, ventricular ectopy, and atrial fibrillation; Table 1F) found relative risks for CHD mortality of 2 to nearly 4.^13,^ ^25,^ ^31^

Table 1F Association between Resting ECG Abnormalities and Risk of Coronary Heart Disease Mortality in Asymptomatic Individuals: Major ECG Changes

Authors and Year | No. of Subjects in Study | Age Range (years) and Sex (% male) | Participants | Follow-up (years) | Prevalence of Major ECG Changes | Relative Risk for CHD Mortality (95% CI) | Relative Risk Adjusted for the Following Variables
Liao et al., 1988^25^* | 17,633 | 40–64 | White residents of Chicago | 11.5 | Men 9.6% | 3.7^†^ | Age, diabetes, DBP, cholesterol, smoking, anti-HTN meds
| | 66% | | | Women 12.9% | 1.9^†^
Knutsen et al., 1988^31^‡ | 7,682 | 45–68 | Men of Asian descent living in Honolulu, Hawaii | 12 | 5.6% | 2.9 (1.9–4.4) | Age
| | 100% | | | | 1.8 (1.4–2.4) (event)
Hames et al, 1993^26^§ | 2,216 | ≥40 | Black and white residents of Evans Co., GA | 20 | Men 5–20% | 1.9 (1.03–3.49) | Age, SES, race, prevalent CHD, SBP, smoking, chol, BMI, minor ECG changes
| | 47% | | | Women 5–30% | 1.75 (0.87–3.49)
Sutherland et al., 1993^27^§ | 642 Whites | 35–74 | Black and white men in Charleston, SC | 30 | White 6.9% | 2.72 (1.47–5.04) | Age, SBP, chol, BMI, smoking, DM, education, ECG abnormality
| 328 Blacks | 100% | | | Black 13.7% | 1.95 (0.93–4.11)
De Bacquer et al., 1998^13^* | 9,954 | 25–74 | Belgian residents (mainly white) | 10 | Men 3.7% | 2.1 (1.2–3.7) | Age, diabetes, BMI, SBP, total cholesterol, HDL, smoking, anti-HTN meds, other ECG changes
| | 52% | | | Women 3.1% | 3.1 (1.4–6.9)

BMI, body mass index; CHD, coronary heart disease; CI, confidence intervals; CVD, cardiovascular disease; DBP, diastolic blood pressure; HDL, high-density lipoprotein cholesterol; HTN, hypertension; LDL, low-density lipoprotein cholesterol; LVH, left ventricular hypertrophy; MC, Minnesota code; meds, medications; MI, myocardial infarction; SBP, systolic blood pressure.

* Major ECG changes defined as: Major ST depression (MC 4.1, 4.2), Major T wave inversion (MC 5.1, 5.2), CHB (MC 6.1), 2° AVB (MC 6.2), LBBB (MC 7.1), RBBB (C 7.2), frequent PVCs (MC 8.1), aflutter/afib (MC 8.3).

† No confidence interval reported, but P < 0.01.

‡ Major ECG changes defined as: Major ST depression (MC 4.1, 4.2), Major T wave inversion (MC 5.1, 5.2), CHB (MC 6.1), 2° AV block (MC 6.2), LBBB (MC ;7.1), RBBB (MC 7.2), frequent PVCs (MC 8.1), unspecified intraventricular block (MC 7.4), aflutter/afib (MC 8.3).

§ Major ECG changes defined as: Major ST depression (MC 4.1, 4.2), Major T wave inversion (MC 5.1, 5.2), LBBB (MC 7.1), RBBB (MC 7.2), frequent PVCs (MC 8.1), aflutter/afib (MC 8.3).

∥ Varies with age and race.

¶ Estimates for the 40 to 64 age range.

Minor or nonspecific ECG abnormalities (principally small changes in the ST segments and T waves or minor conduction abnormalities; Table 1G) have been associated with increased cardiovascular morbidity and mortality.^13,^ ^25^–^28,^ ^31^ Daviglus et al. studied 1,673 men employed at the Western Electric Company in Chicago, Illinois, who had no history of CHD or definitive ECG evidence of previous CHD events.^29^ All subjects had a baseline resting ECG and were followed for 29 years. For men who had minor, nonspecific abnormalities on three or more annual ECGs, the relative risk for dying of coronary heart disease was 2.39 (95% CI, 1.39 to 4.12). Kannel et al. examined the Framingham cohort of 5,127 men and women who were free of overt CHD at study entry and followed with biennial ECGs.^28^ Subjects who had nonspecific ECG abnormalities on any of the first 4 biennial examinations (prevalence: men, 6.5%; women, 5.2%), had a 1.4-fold greater risk of developing CHD than those without such ECG findings.

Most ECG studies examined cohorts that were predominantly European in origin, but three studies included large numbers of African-American patients.^26,^ ^27,^ ^30^ The Charleston Heart Study found that although major ECG abnormalities are more prevalent in black men, they may confer greater independent risk of CHD death in white men (RR, 2.72; 95% CI, 1.47 to 5.04) than in black men (RR, 1.95; 95% CI, 0.93 to 4.11).^27^ Jones et al. reported that in the Artherosclerosis Risk in Communities (ARIC) study cohort, LVH with associated ST-T wave abnormalities on rest ECG was associated with a particularly high age-adjusted risk of CHD events in black women (Hazard Ratio [HR] 5.9; 95% CI 3.6 to 9.7).^30^ Black men with LVH with associated ST-T wave abnormalities had an HR of 2.0 (95% CI, 1.1 to 3.6) for CHD events. LVH with associated ST-T wave abnormalities in white men and women was not found to be a statistically significant predictor of CHD events in this study. Available studies suggest that the prognostic value of noninvasive screening may differ somewhat by population groups, but further research is needed to better characterize them precisely.

Adverse effects. The main adverse effects of ECGs are the false-positive test results, which can lead to further unnecessary tests and treatments and the adverse events associated with these additional interventions. A positive result also labels the person as being at increased risk, which may itself have adverse outcomes. When applied in low-risk asymptomatic populations with a low prevalence of CHD and low risk of CHD events in the next 5 to 10 years, most positive test results will occur in patients who will not go on to have a CHD event over that time span. Because of the limited sensitivity of the resting ECG and the low prevalence of disease in asymptomatic adults, a majority of CHD events will occur among persons with an initially normal ECG.^42^

### Exercise Treadmill Testing (ETT)

ETT is widely used as a diagnostic test in the initial evaluation of patients with symptoms suggestive of myocardial ischemia and for persons with previously recognized coronary heart disease. Although ETT has been applied and studied as a screening or prognostic test in asymptomatic persons, its utility in this patient population is controversial.

Several fair or good quality observational cohort studies of asymptomatic adults have prospectively evaluated the value of ETT in predicting future CHD events, such as angina, myocardial infarction, and death (Table 2).^43^–^53^ Most studies reported total CHD events as their main outcome. Others reported CHD mortality or total mortality as their main outcomes, or in addition to reporting CHD events. CHD mortality and particularly total mortality are less subject to ascertainment bias than total CHD events. In these studies, the prevalence of an abnormal ETT, usually defined as ST segment depression of ≥ 1 mm, ranged from 5% to 25%. After adjustment for other risk factors, the independent relative risk of CHD events associated with a positive test generally ranged from 2.6 to 5.7, sensitivity for occurrence of CHD events over the length of the studies (3 to 12 years duration) ranged from 10% to 62%, and positive predictive value ranged from 6% to 48%.

Table 2 Association between Abnormal ST Segment Response to Exercise and CHD Events in Asymptomatic Individuals

Authors and Year | No. of Subjects in Study | Age Range (years) and Sex (% male) | Participants | Follow-up (years) | Technique | Prevalence of Abnormal Test (%) | Relative Risk for CHD Events with Abnormal ST Segment Response | Sensitivity for CHD Events | Positive Predictive Value of Abnormal ST Response | Relative Risk Adjusted for the Following Variables
Allen et al., 1980^44^ | 888 | Adults | Men and Women | 5 | Maximal Ellestad | Men 14% | 3.3^*^ | 38 | 15.7 | Not reported
| | 65% | | | | Women 5% | 1.8^†^ | 10 | 6
Cumming et al., 1975^46^ | 510 | 40–65 | Civil servants in Canada | 3 | Maximal cycle ergometry | 12.0% | 10.0 | 42 | 25 | Not reported
| | 100%
Ekelund et al., 1989;^47^ | 3,640 | 35–59 | Lipid Research Clinics Study (white men) | 8.1 | Submaximal Modified Bruce | 8.3% | Placebo group | 30^‡^ | 7.1^‡^ | Age, LDL, HDL, SBP, smoking, family history
| | 100% | | | | | 5.7 (2.7–12.2)
Gordon, et al., 1986^43^ | | | | | | | Cholesty-ramine group
| | | | | | | 4.9 (2.2–10.8)
Fleg et al., 1990^48^ | 407 | 40–90 mean = 60 | Residents of Baltimore, Maryland (mainly white) | 4.6 | Maximal treadmill with Thallium Modified Balke | 6.0% | 3.6(1.6–8.1) | 28 | 48 | Age, sex, HTN, FBS, total cholesterol, BMI, smoking, exercise duration
| | | | | | 16.0% | 2.4 | 40 | 24
Froelicher et al., 1974^49^ | 1,390^#^ | 20–52 | Aircrewmen in the US Air Force evaluated for flying status | 6.3 | Maximal treadmill | 10.0% | 14.3 | 60.9 | 20 | Not reported
Giagnoni et al., 1983^50^ | 514 | 18–65 | Factory workers in Italy | 6 | Submaximal Supine cycle ergometry | Not reported | 5.5 (2.8–11.2) | 62 | 15 | Age, SBP, smoking, coronary risk index
| | 73%
McHenry et al., 1984^52^ | 916 | 27–55 mean = 37 | Employees of the Indiana State Police Department | 12.7 | Maximal treadmill Modified Balke | 2.5% | 7.4 | 39 | 34 | Not reported
| | 100%
Rautaharju et al., 1986^53^ | 6,205** | 35–57 | MRFIT | 7 | Submaximal | 12.2% | 3.5^††^ | Not reported | 36^††^ | Age, DBP, cholesterol, number of cigarettes smoked daily
| | 100%
Gibbons et al., 2000^51^ | 25,927 | 20–82 mean = 42.9 | Patients of a preventive medicine clinic in Texas (mainly white) | 8.4 | Maximal treadmill Modified Balke | No RF, 3.0% | 21 (6.9–63.3) | 60 | 2.2 | Age
| | 100% | | | | >1 RF, 7.0% | 9 | 61 | 7.7
Jouven et al., 2000^45^ | 6,101 | 42–53 | Frenchmen in Paris Civil Service | 23 | Bicycle ergometry | 4.4% | 2.6 (1.93–3.59)^††^ | 10 | 17–25 | Age, BMI, HR at rest, smoking, physical activity, DM, total chol, PVC's
| | 100%

* No confidence intervals reported, but reported statistically significant with P < 0.05.

† No confidence intervals reported, but reported not statistically significant with P > 0.05.

‡ Sensitivity and positive predictive value for CHD death.

§ Concordant positive results for both the thallium scintigraphy and exercise ECG.

∥ Positive test for exercise ECG only.

¶ Confidence interval not reported, but P < 0.05.

# Includes 63 subjects with history suggestive of CHD.

** Refers to the subset of patients randomized to usual care.

†† Relative risk and positive predictive value for CHD death, P < 0.05.

More recent studies of the value of exercise testing in asymptomatic men have examined the utility of other risk markers, including functional capacity, chronotropic incompetence, heart rate recovery, and the development of exercise-induced premature ventricular contractions and the risk of CHD events or mortality.^45,^ ^47,^ ^54^–^59^ In general, these findings are associated with moderate increases in CHD risk after adjustment for other CHD risk factors (relative risks 1.7 to 3.2). Some are quite common; failure to achieve target heart rate was noted in 21% of patients in the Framingham Offspring Study, for example.^54^

In addition to its ability to predict future CHD events, a positive ETT may be able to detect the small proportion of asymptomatic patients with severe coronary artery disease, such as left main or 3-vessel coronary artery obstruction, findings that may warrant immediate revascularization. Davies and colleagues examined the yield of exercise ECG in 5,000 asymptomatic middle-aged men in London; 162 men (3.2%) had an abnormal exercise ECG response.^60^ Among the men with abnormal tests, 92 agreed to undergo further evaluation, and 67 had significant coronary artery disease on angiography, defined as at least 1 vessel with 50% stenosis. Of these 67 patients, 26 underwent revascularization for 3-vessel or left main coronary artery disease and 7 had angioplasty; the remaining 34 were treated medically. No data are available on the 70 patients who did not undergo further evaluation. Assuming those lost to follow-up did not have 3-vessel or left main coronary disease, the yield of ETT for detecting severe disease was approximately 0.5%. To detect these patients with severe coronary artery obstructions during screening, however, requires that all patients with positive ETT undergo cardiac catheterization, which may have other, untoward effects as well.

Although a positive ETT can provide useful prognostic information, using ETT in asymptomatic populations with low risk of CHD (often less than 1% per year) will lead to many false-positive results. For example, Hopkirk et al. reviewed the medical records of 225 asymptomatic air-crew members who had an abnormal ST segment response during screening exercise ECG and subsequently had a cardiac catheterization.^61^ The authors found that only 29% of the men had angiographically demonstrable CAD.

In terms of CHD risk, the positive predictive values identified in the cohort studies discussed above were generally low (range: 6% to 48%). Many of the studies that found higher pre-test and post-test probabilities of disease are older investigations that reflect the higher prevalence and seriousness of CHD in the 1980's and earlier.

Data from the prospective cohort studies suggest that the majority of asymptomatic persons with an abnormal ETT do not have CHD events, at least within the follow-up time frame, usually 3 to 8 years. Persons who do have events are more likely to develop angina than have myocardial infarction or sudden death.^52^ Within a defined cohort of low-risk patients, a larger absolute number of CHD events occurs among patients with initially normal ETT results than among those with initially abnormal results.

Other investigators have developed sophisticated scoring systems for improving ETT accuracy.^62^ Adding nuclear perfusion imaging to ECG analysis may increase sensitivity somewhat but may also increase costs.^63^ However, the low predictive value of screening ETT is driven mainly by the low underlying prevalence of disease in asymptomatic patients, and hence it cannot be corrected solely by improving test accuracy.

Table 3 considers the effect of different levels of pretest probabilities (couched as underlying prevalence of disease) on the yield of a screening test (generally speaking, not specifically for ACAD). It presents 2 cases for 2 screening tests. In 1 case, the prevalence of disease is only 1%; in the other, it is 10%. The screening tests differ in terms of the assumed sensitivity and specificity, with test “B” having more favorable assumptions than test “A.”

Table 3 Yield of Screening Tests under Different Assumptions about Pretest Probabilities and Sensitivity and Specificity Rates

Case 1. Use of screening tests in a hypothetical cohort of 1,000 people in whom the prevalence of disease is 1% (i.e. 10 people have the disease, 990 do not)
1a. Using a screening test “A” with 70% sensitivity and 80% specificity, the following results will be expected:
7 people with the disease will be detected (true positives)
3 people with the disease will be missed (false negatives)
792 people without disease will test negative (true negatives)
198 people without disease will test positive (false positives)
Probability of disease in those testing positive = 3.4%
Probability of disease in those testing negative = 0.4%
1b. Using a better screening test “B” with 80% sensitivity and 90% specificity, the following results will be expected:
8 people with the disease will be detected (true positives)
2 people with the disease will be missed (false negatives)
891 people without disease will test negative (true negatives)
99 people without disease will test positive (false positives)
Probability of disease in those testing positive = 7.5%
Probability of disease in those testing negative = 0.2%
Case 2. Use of screening tests in a hypothetical cohort of 1,000 people in whom the prevalence of disease is 10% ( i.e. 100 people have the disease, 900 do not).
2a. Using a screening test “A” with 70% sensitivity and 80% specificity, the following results will be expected:
70 people with the disease will be detected (true positives)
30 people with the disease will be missed (false negatives)
720 people without disease will test negative (true negatives)
180 people without disease will test positive (false positives)
Probability of disease in those testing positive = 28%
Probability of disease in those testing negative = 4%
2b. Using a better screening test “B” with 80% sensitivity and 90% specificity, the following results will be expected:
80 people with the disease will be detected (true positives)
20 people with the disease will be missed (false negatives)
810 people without disease will test negative (true negatives)
90 people without disease will test positive (false positives)
Probability of disease in those testing positive = 47%
Probability of disease in those testing negative = 2.4%

As shown in Case 1 (1% prevalence), the probability of disease in those testing positive ranges from 3.4% to 7.5%; the probability of disease in those testing negative ranges from 0.2% to 0.4%. Although test B performs better than test A, the differences on an absolute scale are small.

By contrast, in Case 2, the range of probability of disease in those testing positive is from 28% to 47% (and 2.4% to 4% for probability of disease in those testing negative). The numbers for true- and false-negative or -positive persons of course differ between the two cases (and by test), and the probabilities of disease (for those testing either positive or negative) are far higher for Case 2 than Case 1. These hypothetical results demonstrate the large impact of underlying prevalence (or pretest probabilities) on the yield of tests and highlight the caution that must be taken in interpreting screening test results.

Some investigators and policymakers have suggested that the value of ETT is greater when it is applied to patients with one or more CHD risk factors because selecting a higher-risk cohort for screening increases the prevalence of disease and positive predictive value. Bruce et al. reported that, in the Seattle Heart Watch Study of 4,158 asymptomatic men and women, a positive exercise ECG in the absence of risk factors provided little predictive value.^64^ However, among patients with one or more other CHD risk factors, the occurrence of 2 different types of abnormal ETT response was associated with a 15-fold increase in risk compared to those with normal ETT.^65^

A large cohort study of 25,927 asymptomatic healthy middle-aged men in Texas found that an abnormal ETT in a man without risk factors conferred an age-adjusted relative risk for CHD death of 21 (95% CI, 6.9 to 63.3). Although the relative risk associated with a positive test was large, the post-test probability for patients with no risk factors was only 1.25%.^51^ In a man with 3 or more conventional cardiac risk factors, a positive ETT conveyed an independent increase in relative risk of 8 for death from CHD.

In addition to false-positive results, ETT can be normal or nondiagnostic in an important proportion of patients who will go on to have a CHD event. Older studies reported sensitivity for ST segment depression of 1 mm or greater to be 65% to 70%.^66,^ ^67^ However, more recent investigators have questioned the accuracy and relevance of this older information for asymptomatic adults today, particularly because the spectrum of disease encountered now may be less severe and because of the presence of work-up bias in earlier studies.^68,^ ^69^ In addition, most of the early investigations studied primarily male populations; test performance in women appears to be lower than for men, at least for symptomatic patients.^70^ The suboptimal sensitivity of ETT for CHD events may be partly explained by the fact that ST segment depression on ETT detects ischemia from obstructive coronary arteries, but many acute CHD events result from sudden occlusion of a previously nonobstructed artery segment.^71^ Use of other measures from the exercise test that are not as dependent on identifying atherosclerotic obstructions may partly mitigate this dilemma.^68^

### Electron Beam Computed Tomography (EBCT)

Recent studies have examined the role of EBCT for the detection of coronary calcium as a potential screening test for CHD. EBCT can detect and quantify the amount of calcium deposited in the walls of coronary arteries. For symptomatic patients, EBCT has a sensitivity of 80% and specificity of 40% for detecting obstructed arteries when compared with coronary angiography.^72^ Coronary calcium may be a marker for anatomic changes that are associated with an increased future risk of CHD. Conversely, the absence of coronary calcium may identify a low-risk cohort, at least for periods of time up to 3 to 5 years. Pletcher and colleagues recently conducted a systematic review and meta-analysis of the independent risk information available from EBCT for asymptomatic adults.^73^ They identified 5 fair-quality studies that met their inclusion criteria.^74^–^78^ They then applied data standardization measures to allow better comparison and meta-analysis of the different results. The 5 studies had follow-up periods of 32 to 72 months and enrolled middle-aged adults (mean ages ranged from 52 to 66 years; women accounted for 11% to 49% of participants). Most studies used crude measures of other CHD risk factors, mainly self-report of the presence or absence of smoking, hypertension, diabetes, and lipid disorders, although one study used direct measures of most risk factors.^75^ In addition, the CHD outcomes measured usually included revascularization, which may be affected by the EBCT result itself.

After adjustment for other risk factors, higher calcium scores were associated with a higher risk of CHD events. Calcium scores of 1 to 100 were associated with a relative odds of 2.1 (95% CI, 1.6 to 2.9) compared with a score of 0. Scores above 100 were associated with higher risk, but the magnitude of the increased risk was smaller for the study that best measured other risk factors^75^ than for those using crude measures. Patients with a calcium score of 0 generally had very low rates of CHD events over the defined follow-up period. Pletcher and colleagues concluded that EBCT may have a role in better defining the risk of CHD events for patients who are found to be at intermediate levels of risk based on traditional risk factors, but they did not identify any studies that examined if EBCT data affected clinical decision-making.

Potential adverse effects of screening for ACAD with EBCT include increased false-positive test results and labeling. As is the case with ECG and ETT, false-positive EBCT results often cause patients to undergo invasive diagnostic procedures such as coronary angiography, with resultant costs and risk of adverse events. Patients with obstructed arteries identified on angiography may then undergo revascularization, the efficacy of which is unclear.

Abnormal test results may also produce considerable anxiety until the test result is determined to be false. Labeling a person as suffering from coronary disease may also have negative consequences. Mixed evidence from hypertension screening suggests that being labeled as having increased risk may be associated with poorer future health.^79^ The studies by Wong et al. and O'Malley et al. suggest that patients with abnormal EBCT results are more worried about their health than those with negative results, but the impact of this finding on health and quality of life is unclear.^9,^ ^10^