# Appendix: Peer Review

## Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. External reviewers comprised clinicians, researchers, representatives of professional societies, and potential users of the report. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report and to complete a checklist. The peer reviewers' comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

Michael Lauer, MD

Robert Detrano, MD

Victor Froelicher, MD

Hal Sox, MD

Mark Grunwald, MD

Nick Fitterman, MD

Euan Ashley, MD

Paolo Raggi, MD