# References

1 U. S. Preventive Services Task Force. Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(19):1997–2007. doi: 10.1001/jama.2016.15450. PMID: 27838723.27838723
2 U.S. Preventive Services Task Force. Lipid Disorders in Adults (Cholesterol, Dyslipidemia): Screening. 2008. https://www.uspreventiveservicestaskforce.org/uspstf/recommendation/lipid-disorders-in-adults-cholesterol-dyslipidemia-screening-2008. Accessed Apr 10 2020.
3 Chou R, Dana T, Blazina I, . Statins for prevention of cardiovascular disease in adults: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2016 Nov 15;316(19):2008–24. doi: 10.1001/jama.2015.15629. PMID: 27838722.27838722
4 Chou R, Dana T, Blazina I, . Screening for Dyslipidemia in Younger Adults: A Systematic Review for the U.S. Preventive Services Task Force. Ann Intern Med. 2016;165(8):560–4. doi: 10.7326/M16-0946. PMID: 27538032.27538032
5 Force USPST. Screening for Lipid Disorders in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(6):625–33. doi: 10.1001/jama.2016.9852. PMID: 27532917.27532917
6 Heron M. Deaths: Leading Causes for 2017. Jun 24 2019. https://stacks.cdc.gov/view/cdc/79488.
7 Xu J, Murphy S, Kochanek K, . Mortality in the United States, 2018 [Data brief]. Centers for Disease Control and Prevention; 2020. https://www.cdc.gov/nchs/products/databriefs/db355.htm. Accessed Apr 10 2020.
8 Virani Salim S, Alonso A, Benjamin Emelia J, . Heart Disease and Stroke Statistics—2020 Update: A Report From the American Heart Association. Circulation. 2020 2020/03/03;141(9):e139–e596. doi: 10.1161/CIR.0000000000000757.31992061
9 Virani SS, Alonso A, Aparicio HJ, . Heart Disease and Stroke Statistics-2021 Update: A Report From the American Heart Association. Circulation. 2021 Feb 23;143(8):e254–e743. doi: 10.1161/cir.0000000000000950. PMID: 33501848.33501848
10 Lloyd-Jones DM, Wilson PW, Larson MG, . Lifetime risk of coronary heart disease by cholesterol levels at selected ages. Arch Intern Med. 2003 Sep 8;163(16):1966–72. doi: 10.1001/archinte.163.16.1966. PMID: 12963571.12963571
11 Sanchis-Gomar F, Perez-Quilis C, Leischik R, . Epidemiology of coronary heart disease and acute coronary syndrome. Ann Transl Med. 2016 Jul;4(13):256. doi: 10.21037/atm.2016.06.33. PMID: 27500157.27500157
12 U.S. Department of Health and Human Services Office of Minority Health. Heart Disease and American Indians/Alaska Natives. 2021. https://minorityhealth.hhs.gov/omh/browse.aspx?lvl=4&lvlid=34. Accessed May 15.
13 Volgman AS, Palaniappan LS, Aggarwal NT, . Atherosclerotic Cardiovascular Disease in South Asians in the United States: Epidemiology, Risk Factors, and Treatments: A Scientific Statement From the American Heart Association. Circulation. 2018 Jul 3;138(1):e1–e34. doi: 10.1161/cir.0000000000000580. PMID: 29794080.29794080
14 Shah NS, Molsberry R, Rana JS, . Heterogeneous trends in burden of heart disease mortality by subtypes in the United States, 1999-2018: observational analysis of vital statistics. Bmj. 2020 Aug 13;370:m2688. doi: 10.1136/bmj.m2688. PMID: 32816805.32816805
15 Lecerf JM, de Lorgeril M. Dietary cholesterol: from physiology to cardiovascular risk. The British journal of nutrition. 2011 Jul;106(1):6–14. doi: 10.1017/s0007114511000237. PMID: 21385506.21385506
16 National Institute of Health. Detection, Evaluation and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) National Cholesterol Education Program. NIH Publication No. 02-5215. 2002. https://www.nhlbi.nih.gov/files/docs/resources/heart/atp-3-cholesterol-full-report.pdf PMID: 1248596612485966.
17 Lerner DJ, Kannel WB. Patterns of coronary heart disease morbidity and mortality in the sexes: a 26-year follow-up of the Framingham population. Am Heart J. 1986;111(2):383–90. PMID: 0003946178.3946178
18 Go AS, Mozaffarian D, Roger VL, . Heart disease and stroke statistics--2013 update: a report from the American Heart Association. Circulation. 2013 Jan 1;127(1):e6–e245. doi: 10.1161/CIR.0b013e31828124ad. PMID: 23239837.23239837
19 Sheifer SE, Gersh BJ, Yanez ND, . Prevalence, predisposing factors, and prognosis of clinically unrecognized myocardial infarction in the elderly. J Am Coll Cardiol. 2000;35(1):119–26. PMID: 10636269.10636269
20 Sigurdsson E, Thorgeirsson G, Sigvaldason H, . Unrecognized myocardial infarction: epidemiology, clinical characteristics, and the prognostic role of angina pectoris: the Reykjavik Study. Ann Intern Med. 1995;122(2):96–102. PMID: 7993002.7993002
21 Arnett DK, Blumenthal RS, Albert MA, . 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2019 09 10;140(11):e596–e646. doi: 10.1161/CIR.0000000000000678. PMID: 30879355.30879355
22 Welsh JA, Sharma A, Abramson JL, . Caloric sweetener consumption and dyslipidemia among US adults. JAMA. 2010;303(15):1490–7. PMID: 20407058.20407058
23 Tóth PP, Potter D, Ming EE. Prevalence of lipid abnormalities in the united states: the national health and nutrition examination survey 2003–2006. J. 2012;6(4):325–30. PMID: 22836069.22836069
24 Centers for Disease Control and Prevention. Cholesterol: Risk Factors. Centers for Disease Control and Prevention. https://www.cdc.gov/cholesterol/risk_factors.htm. Accessed Apr 10 2020.
25 Coffey S. Dyslipidemia. U.S. Department of Health and Human Services, Health Resources and Services Administration; 2011. http://hab.hrsa.gov/deliverhivaidscare/clinicalguide11/cg-602_dyslipidemia.html. Accessed Feb 19 2014.
26 Stein JH. Dyslipidemia in the era of HIV protease inhibitors. Prog Cardiovasc Dis. 2003;45(4):293–304. doi: 10.1053/pcad.2003.3. PMID: 12638093.12638093
27 Saari K, Koponen H, Laitinen J, . Hyperlipidemia in persons using antipsychotic medication: a general population-based birth cohort study. The Journal of clinical psychiatry. 2004;65(4):547–50. PMID: 15119919.15119919
28 Sniderman AD, Williams K, Contois JH, . A meta-analysis of low-density lipoprotein cholesterol, non-high-density lipoprotein cholesterol, and apolipoprotein B as markers of cardiovascular risk. Circulation: Cardiovascular Quality and Outcomes. 2011;4(3):337–45. PMID: 21487090.21487090
29 Di Angelantonio E, Sarwar N, Perry P, . Major lipids, apolipoproteins, and risk of vascular disease. JAMA. 2009 Nov 11;302(18):1993–2000. doi: 10.1001/jama.2009.1619. PMID: 19903920.19903920
30 Robinson JG, Wang S, Smith BJ, . Meta-analysis of the relationship between non–high-density lipoprotein cholesterol reduction and coronary heart disease risk. J Am Coll Cardiol. 2009;53(4):316–22. PMID: 19161879.19161879
31 Ramjee V, Sperling LS, Jacobson TA. Non–high-density lipoprotein cholesterol versus apolipoprotein B in cardiovascular risk stratification: do the math. J Am Coll Cardiol. 2011;58(5):457–63. PMID: 21777740.21777740
32 Arsenault BJ, Mora S, Nestel PJ, . Clinician’s Corner. Association of LDL cholesterol, non – HDL cholesterol, and apolipoprotein B levels with risk of cardiovascular events. JAMA. 2012;307(12) PMID: 22453571.22453571
33 U. S. Preventive Services Task Force. Screening for lipid disorders in adults: recommendation statement, 2008. Internet: http://www.uspreventiveservicestaskforce.org/uspstf08/lipid/lipidrs.html (11.5. 2012). 2015.
34 Helfand M, Buckley DI, Freeman M, . Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med. 2009 Oct 6;151(7):496–507. PMID: 19805772.19805772
35 Greenland P, Blaha MJ, Budoff MJ, . Coronary Calcium Score and Cardiovascular Risk. J Am Coll Cardiol. 2018 07 24;72(4):434–47. doi: 10.1016/j.jacc.2018.05.027. PMID: 30025580.30025580
36 Curry SJ, Krist AH, Owens DK, . Risk Assessment for Cardiovascular Disease With Nontraditional Risk Factors: US Preventive Services Task Force Recommendation Statement. JAMA. 2018 Jul 17;320(3):272–80. doi: 10.1001/jama.2018.8359. PMID: 29998297.29998297
37 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Circulation. 2014 Jun 24;129(25 Suppl 2):S49–73. doi: 10.1161/01.cir.0000437741.48606.98. PMID: 24222018.24222018
38 Sharifi M, Rakhit RD, Humphries SE, . Cardiovascular risk stratification in familial hypercholesterolaemia. Heart. 2016 Jul 1;102(13):1003–8. doi: 10.1136/heartjnl-2015-308845. PMID: 27126396.27126396
39 U.S. Preventive Services Task Force. Final Research Plan: Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: Preventive Medication. 2020. https://www.uspreventiveservicestaskforce.org/uspstf/document/final-research-plan/aspirin-use-to-prevent-cardiovascular-disease-and-colorectal-cancer-preventive-medication. Accessed May 15 2021.
40 DeFilippis AP, Young R, Carrubba CJ, . An analysis of calibration and discrimination among multiple cardiovascular risk scores in a modern multiethnic cohort. Ann Intern Med. 2015 Feb 17;162(4):266–75. doi: 10.7326/m14-1281. PMID: 25686167.25686167
41 Cook NR, Ridker PM. Calibration of the Pooled Cohort Equations for Atherosclerotic Cardiovascular Disease: An Update. Ann Intern Med. 2016 Dec 6;165(11):786–94. doi: 10.7326/m16-1739. PMID: 27723890.27723890
42 Dalton JE, Perzynski AT, Zidar DA, . Accuracy of Cardiovascular Risk Prediction Varies by Neighborhood Socioeconomic Position: A Retrospective Cohort Study. Ann Intern Med. 2017 Oct 3;167(7):456–64. doi: 10.7326/m16-2543. PMID: 28847012.28847012
43 Kavousi M, Leening MJ, Nanchen D, . Comparison of application of the ACC/AHA guidelines, Adult Treatment Panel III guidelines, and European Society of Cardiology guidelines for cardiovascular disease prevention in a European cohort. JAMA. 2014 Apr 09;311(14):1416–23. doi: 10.1001/jama.2014.2632. PMID: 24681960.24681960
44 Rana JS, Tabada GH, Solomon MD, . Accuracy of the atherosclerotic cardiovascular risk equation in a large contemporary, multiethnic population. J Am Coll Cardiol. 2016 May 10;67(18):2118–30. doi: 10.1016/j.jacc.2016.02.055. PMID: 27151343.27151343
45 Ko DT, Sivaswamy A, Sud M, . Calibration and discrimination of the Framingham Risk Score and the Pooled Cohort Equations. Cmaj. 2020 Apr 27;192(17):E442–e9. doi: 10.1503/cmaj.190848. PMID: 32392491.32392491
46 DeFilippis AP, Young R, McEvoy JW, . Risk score overestimation: the impact of individual cardiovascular risk factors and preventive therapies on the performance of the American Heart Association-American College of Cardiology-Atherosclerotic Cardiovascular Disease risk score in a modern multi-ethnic cohort. Eur Heart J. 2017 Feb 21;38(8):598–608. doi: 10.1093/eurheartj/ehw301. PMID: 27436865.27436865
47 Mora S, Wenger NK, Cook NR, . Evaluation of the Pooled Cohort Risk Equations for Cardiovascular Risk Prediction in a Multiethnic Cohort From the Women’s Health Initiative. JAMA Intern Med. 2018 Sep 1;178(9):1231–40. doi: 10.1001/jamainternmed.2018.2875. PMID: 30039172.30039172
48 Colantonio LD, Richman JS, Carson AP, . Performance of the atherosclerotic cardiovascular disease pooled cohort risk equations by social deprivation status. J Am Heart Assoc. 2017 Mar 17;6(3):17. doi: 10.1161/JAHA.117.005676. PMID: 28314800.28314800
49 Moons KG, Altman DG, Reitsma JB, . Transparent Reporting of a multivariable prediction model for Individual Prognosis or Diagnosis (TRIPOD): explanation and elaboration. Ann Intern Med. 2015 Jan 6;162(1):W1–73. doi: 10.7326/m14-0698. PMID: 25560730.25560730
50 Andersson C, Enserro D, Larson MG, . Implications of the US cholesterol guidelines on eligibility for statin therapy in the community: comparison of observed and predicted risks in the Framingham Heart Study Offspring Cohort. J Am Heart Assoc. 2015 Apr 17;4(4):17. doi: 10.1161/JAHA.115.001888. PMID: 25888372.25888372
51 Yadlowsky S, Hayward RA, Sussman JB, . Clinical implications of revised pooled cohort equations for estimating atherosclerotic cardiovascular disease risk. Ann Intern Med. 2018 Jul 03;169(1):20–9. doi: 10.7326/M17-3011. PMID: 29868850.29868850
52 Cainzos-Achirica M, Miedema MD, McEvoy JW, . Coronary Artery Calcium for Personalized Allocation of Aspirin in Primary Prevention of Cardiovascular Disease in 2019: The MESA Study (Multi-Ethnic Study of Atherosclerosis). Circulation. 2020 May 12;141(19):1541–53. doi: 10.1161/circulationaha.119.045010. PMID: 32233663.32233663
53 Lin JS, Evans CV, Johnson E, . Nontraditional risk factors in cardiovascular disease risk assessment: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Jul 17;320(3):281–97. doi: 10.1001/jama.2018.4242. PMID: 29998301.29998301
54 Kashani A, Phillips CO, Foody JM, . Risks associated with statin therapy a systematic overview of randomized clinical trials. Circulation. 2006;114(25):2788–97. PMID: 17159064.17159064
55 Thompson PD, Clarkson PM, Rosenson RS. An assessment of statin safety by muscle experts. Am J Cardiol. 2006;97(8):S69–S76.
56 Alsheikh-Ali AA, Ambrose MS, Kuvin JT, . The safety of rosuvastatin as used in common clinical practice: a postmarketing analysis. Circulation. 2005 Jun 14;111(23):3051–7. PMID: 15911706.15911706
57 Richardson K, Schoen M, French B, . Statins and cognitive function: A systematic review. Ann Intern Med. 2013;159(10):688–97. PMID: 24247674.24247674
58 Dale KM, Coleman CI, Henyan NN, . Statins and cancer risk: a meta-analysis. JAMA. 2006;295(1):74–80. PMID: 16391219.16391219
59 Newman CB, Preiss D, Tobert JA, . Statin Safety and Associated Adverse Events: A Scientific Statement From the American Heart Association. Arterioscler Thromb Vasc Biol. 2019 Feb;39(2):e38–e81. doi: 10.1161/atv.0000000000000073. PMID: 30580575.30580575
60 Almeida SO, Budoff M. Effect of statins on atherosclerotic plaque. Trends Cardiovasc Med. 2019 Nov;29(8):451–5. doi: 10.1016/j.tcm.2019.01.001. PMID: 30642643.30642643
61 Stone NJ, Robinson JG, Lichtenstein AH, . 2013 ACC/AHA Guideline on the Treatment of Blood Cholesterol to Reduce Atherosclerotic Cardiovascular Risk in Adults. J Am Coll Cardiol. 2014;63(25 Part B):2889. doi: 10.1016/j.jacc.2013.11.002. PMID: 24222016.24239923
62 Salami JA, Warraich H, Valero-Elizondo J, . National Trends in Statin Use and Expenditures in the US Adult Population From 2002 to 2013: Insights From the Medical Expenditure Panel Survey. JAMA Cardiol. 2017 01 01;2(1):56–65. doi: 10.1001/jamacardio.2016.4700. PMID: 27842171.27842171
63 Department of Veterans Affairs. Department of Defense. VA/DoD clinical practice guideline for the management of dyslipidemia for cardiovascular risk reduction. 2014. https://www.healthquality.va.gov/guidelines/CD/lipids/VADoDDyslipidemiaCPG2014.pdf. Accessed Apr 10 2020.
64 Grundy Scott M, Stone Neil J, Bailey Alison L, . 2018 AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2019 2019/06/18;139(25):e1082–e143. doi: 10.1161/CIR.0000000000000625. PMID: 30423393.30586774
65 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD; 2016. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed Apr 10 2020.
66 Ridker PM, Danielson E, Fonseca FA, . Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med. 2008 Nov 20;359(21):2195–207. doi: 10.1056/NEJMoa0807646. PMID: 18997196.18997196
67 Chan KL, Teo K, Dumesnil JG, . Effect of Lipid lowering with rosuvastatin on progression of aortic stenosis: results of the aortic stenosis progression observation: measuring effects of rosuvastatin (ASTRONOMER) trial. Circulation. 2010 Jan 19;121(2):306–14. doi: 10.1161/circulationaha.109.900027. PMID: 20048204.20048204
68 Incorrect Data in Text, Table, Figure, and Supplement. JAMA. 2020;323(7):669–70. doi: 10.1001/jama.2020.0182.
69 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. Bmj. 2003 Sep 6;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
70 Cornell JE, Mulrow CD, Localio R, . Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 18;160(4):267–70. doi: 10.7326/M13-2886. PMID: 24727843.24727843
71 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. Bmj. 2011 Jul 22;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
72 U.S. Preventive Services Task Force. Screening for Lipid Disorders in Adults: Recommendation Statement Agency for Healthcare Research and Quality. AHRQ Publication No. 08-05114-EF-2. Rockville (MD): 2008. http://www.uspreventiveservicestaskforce.org/uspstf08/lipid/lipidrs.htm Accessed February 19, 2014.
73 Anderssen SA, Hjelstuen AK, Hjermann I, . Fluvastatin and lifestyle modification for reduction of carotid intima-media thickness and left ventricular mass progression in drug-treated hypertensives. Atherosclerosis. 2005 Feb;178(2):387–97. doi: 10.1016/j.atherosclerosis.2004.08.033. PMID: 15694949.15694949
74 Asselbergs FW, Diercks GF, Hillege HL, . Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation. 2004 Nov 2;110(18):2809–16. doi: 10.1161/01.Cir.0000146378.65439.7a. PMID: 15492322.15492322
75 Beishuizen ED, van de Ree MA, Jukema JW, . Two-year statin therapy does not alter the progression of intima-media thickness in patients with type 2 diabetes without manifest cardiovascular disease. Diabetes Care. 2004 Dec;27(12):2887–92. doi: 10.2337/diacare.27.12.2887. PMID: 15562202.15562202
76 Bone HG, Kiel DP, Lindsay RS, . Effects of atorvastatin on bone in postmenopausal women with dyslipidemia: a double-blind, placebo-controlled, dose-ranging trial. J Clin Endocrinol Metab. 2007 Aug 28;92(12):4671–7. doi: 10.1210/jc.2006-1909. PMID: 17726081.17726081
77 Colhoun HM, Betteridge DJ, Durrington PN, . Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet. 2004 Aug 21–27;364(9435):685–96. doi: 10.1016/s0140-6736(04)16895-5. PMID: 15325833.15325833
78 Crouse JR, 3rd, Raichlen JS, Riley WA, . Effect of rosuvastatin on progression of carotid intima-media thickness in low-risk individuals with subclinical atherosclerosis: the METEOR Trial. JAMA. 2007 Mar 28;297(12):1344–53. doi: 10.1001/jama.297.12.1344. PMID: 17384434.17384434
79 Downs JR, Clearfield M, Weis S, . Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS. Air Force/Texas Coronary Atherosclerosis Prevention Study. JAMA. 1998 May 27;279(20):1615–22. doi: 10.1001/jama.279.20.1615. PMID: 9613910.9613910
80 Furberg C, and TAO, ALLHAT Cft, . Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). JAMA. 2002 Dec 18;288(23):2998–3007. doi: 10.1001/jama.288.23.2998. PMID: 12479764.12479764
81 Furberg CD, Adams HP, Jr., Applegate WB, . Effect of lovastatin on early carotid atherosclerosis and cardiovascular events. Asymptomatic Carotid Artery Progression Study (ACAPS) Research Group. Circulation. 1994 Oct;90(4):1679–87. doi: 10.1161/01.cir.90.4.1679. PMID: 7734010.7734010
82 Heljić B, Velija-Asimi Z, Kulić M. The statins in prevention of coronary heart diseases in type 2 diabetics. Bosn J Basic Med Sci. 2009 Feb;9(1):71–6. doi: 10.17305/bjbms.2009.2860. PMID: 19284399.19284399
83 Itoh H, Komuro I, Takeuchi M, . Intensive treat-to-target statin therapy in high-risk Japanese patients with hypercholesterolemia and diabetic retinopathy: report of a randomized study. Diabetes Care. 2018 Jun;41(6):1275–84. doi: 10.2337/dc17-2224. PMID: 29626074.29626074
84 Kitas GD, Nightingale P, Armitage J, . A multicenter, randomized, placebo-controlled trial of atorvastatin for the primary prevention of cardiovascular events in patients with rheumatoid arthritis. Arthritis rheumatol. 2019 Sep;71(9):1437–49. doi: 10.1002/art.40892. PMID: 30983166.30983166
85 Knopp RH, d’Emden M, Smilde JG, . Efficacy and safety of atorvastatin in the prevention of cardiovascular end points in subjects with type 2 diabetes: the Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in non-insulin-dependent diabetes mellitus (ASPEN). Diabetes Care. 2006 Jul;29(7):1478–85. doi: 10.2337/dc05-2415. PMID: 16801565.16801565
86 Mercuri M, Bond MG, Sirtori CR, . Pravastatin reduces carotid intima-media thickness progression in an asymptomatic hypercholesterolemic mediterranean population: the Carotid Atherosclerosis Italian Ultrasound Study. Am J Med. 1996 Dec;101(6):627–34. doi: 10.1016/s0002-9343(96)00333-6. PMID: 9003110.9003110
87 Muldoon MF, Ryan CM, Sereika SM, . Randomized trial of the effects of simvastatin on cognitive functioning in hypercholesterolemic adults. Am J Med. 2004 Dec 1;117(11):823–9. doi: 10.1016/j.amjmed.2004.07.041. PMID: 15589485.15589485
88 Nakamura H, Arakawa K, Itakura H, . Primary prevention of cardiovascular disease with pravastatin in Japan (MEGA Study): a prospective randomised controlled trial. Lancet. 2006 Sep 30;368(9542):1155–63. doi: 10.1016/s0140-6736(06)69472-5. PMID: 17011942.17011942
89 Salonen R, Nyyssönen K, Porkkala E, . Kuopio Atherosclerosis Prevention Study (KAPS). A population-based primary preventive trial of the effect of LDL lowering on atherosclerotic progression in carotid and femoral arteries. Circulation. 1995 Oct 1;92(7):1758–64. doi: 10.1161/01.cir.92.7.1758. PMID: 7671358.7671358
90 Sever PS, Dahlöf B, Poulter NR, . Prevention of coronary and stroke events with atorvastatin in hypertensive patients who have average or lower-than-average cholesterol concentrations, in the Anglo-Scandinavian Cardiac Outcomes Trial--Lipid Lowering Arm (ASCOT-LLA): a multicentre randomised controlled trial. Lancet. 2003 Apr 5;361(9364):1149–58. doi: 10.1016/s0140-6736(03)12948-0. PMID: 12686036.12686036
91 Shepherd J, Blauw GJ, Murphy MB, . Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002 Nov 23;360(9346):1623–30. doi: 10.1016/s0140-6736(02)11600-x. PMID: 12457784.12457784
92 Vallejo-Vaz AJ, Robertson M, Catapano AL, . Low-density lipoprotein cholesterol lowering for the primary prevention of cardiovascular disease among men with primary elevations of low-density lipoprotein cholesterol levels of 190 mg/dL or above: analyses from the WOSCOPS (West of Scotland Coronary Prevention Study) 5-year randomized trial and 20-year observational follow-up. Circulation. 2017 Nov 14;136(20):1878–91. doi: 10.1161/CIRCULATIONAHA.117.027966. PMID: 28877913.28877913
93 Yusuf S, Bosch J, Dagenais G, . Cholesterol lowering in intermediate-risk persons without cardiovascular disease. N Engl J Med. 2016 May 26;374(21):2021–31. doi: 10.1056/NEJMoa1600176. PMID: 27040132.27040132
94 Porath A, Arbelle JE, Fund N, . Statin therapy: diabetes mellitus risk and cardiovascular benefit in primary prevention. Isr Med Assoc J. 2018 Aug;20(8):480–5. PMID: 30084572.30084572
95 Ridker PM, Pradhan A, MacFadyen JG, . Cardiovascular benefits and diabetes risks of statin therapy in primary prevention: an analysis from the JUPITER trial. Lancet. 2012 Aug 11;380(9841):565–71. doi: 10.1016/s0140-6736(12)61190-8. PMID: 22883507.22883507
96 Collier DJ, Poulter NR, Dahlöf B, . Impact of atorvastatin among older and younger patients in the Anglo-Scandinavian Cardiac Outcomes Trial lipid-lowering arm. J Hypertens. 2011 Mar;29(3):592–9. doi: 10.1097/HJH.0b013e328342c8f7. PMID: 21297502.21297502
97 Albert MA, Glynn RJ, Fonseca FA, . Race, ethnicity, and the efficacy of rosuvastatin in primary prevention: the Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) trial. Am Heart J. 2011 Jul;162(1):106–14.e2. doi: 10.1016/j.ahj.2011.03.032. PMID: 21742096.21742096
98 Colhoun HM, Thomason MJ, Mackness MI, . Design of the Collaborative AtoRvastatin Diabetes Study (CARDS) in patients with type 2 diabetes. Diabet Med. 2002 Mar;19(3):201–11. doi: 10.1046/j.1464-5491.2002.00643.x. PMID: 11918622.11918622
99 Downs JR, Clearfield M, Tyroler HA, . Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TEXCAPS): additional perspectives on tolerability of long-term treatment with lovastatin. Am J Cardiol. 2001 May 1;87(9):1074–9. doi: 10.1016/s0002-9149(01)01464-3. PMID: 11348605.11348605
100 Ford I, Blauw GJ, Murphy MB, . A Prospective Study of Pravastatin in the Elderly at Risk (PROSPER): screening experience and baseline characteristics. Curr Control Trials Cardiovasc Med. 2002 May 20;3(1):8. doi: 10.1186/1468-6708-3-8. PMID: 12097148.12097148
101 Freeman DJ, Norrie J, Sattar N, . Pravastatin and the development of diabetes mellitus: evidence for a protective treatment effect in the West of Scotland Coronary Prevention Study. Circulation. 2001 Jan 23;103(3):357–62. doi: 10.1161/01.cir.103.3.357. PMID: 11157685.11157685
102 Glynn RJ, Koenig W, Nordestgaard BG, . Rosuvastatin for primary prevention in older persons with elevated C-reactive protein and low to average low-density lipoprotein cholesterol levels: exploratory analysis of a randomized trial. Ann Intern Med. 2010 Apr 20;152(8):488–96, w174. doi: 10.7326/0003-4819-152-8-201004200-00005. PMID: 20404379.20404379
103 Gotto AM, Jr. Establishing the benefit of statins in low-to-moderate--risk primary prevention: the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Atherosclerosis. Supplements. 2007 Aug;8(2):3–8. doi: 10.1016/j.atherosclerosissup.2007.02.002. PMID: 17588826.17588826
104 Gotto AM, Jr., Whitney E, Stein EA, . Application of the National Cholesterol Education Program and joint European treatment criteria and clinical benefit in the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Eur Heart J. 2000 Oct;21(19):1627–33. doi: 10.1053/euhj.2000.2288. PMID: 10988016.10988016
105 Gotto AM, Jr., Whitney E, Stein EA, . Relation between baseline and on-treatment lipid parameters and first acute major coronary events in the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Circulation. 2000 Feb 8;101(5):477–84. doi: 10.1161/01.cir.101.5.477. PMID: 10662743.10662743
106 Han BH, Sutin D, Williamson JD, . Effect of statin treatment vs usual care on primary cardiovascular prevention among older adults: the ALLHAT-LLT randomized clinical trial. JAMA Intern Med. 2017 Jul 01;177(7):955–65. doi: 10.1001/jamainternmed.2017.1442. PMID: 28531241.28531241
107 Koenig W, Ridker PM. Rosuvastatin for primary prevention in patients with European systematic coronary risk evaluation risk ≥ 5% or Framingham risk >20%: post hoc analyses of the JUPITER trial requested by European health authorities. Eur Heart J. 2011 Jan;32(1):75–83. doi: 10.1093/eurheartj/ehq370. PMID: 20971747.20971747
108 Kushiro T, Mizuno K, Nakaya N, . Pravastatin for cardiovascular event primary prevention in patients with mild-to-moderate hypertension in the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) study. Hypertension (Dallas, Tex. : 1979). 2009 Feb;53(2):135–41. doi: 10.1161/hypertensionaha.108.120584. PMID: 19104004.19104004
109 Lonn E, Bosch J, Pogue J, . Novel approaches in primary cardiovascular disease prevention: the HOPE-3 trial rationale, design, and participants’ baseline characteristics. Can J Cardiol. 2016 Mar;32(3):311–8. doi: 10.1016/j.cjca.2015.07.001. PMID: 26481083.26481083
110 Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study Group. Design and baseline characteristics of a study of primary prevention of coronary events with pravastatin among Japanese with mildly elevated cholesterol levels. Circ J. 2004 Sep;68(9):860–7. doi: 10.1253/circj.68.860. PMID: 15329509.15329509
111 Mizuno K, Nakaya N, Ohashi Y, . Usefulness of pravastatin in primary prevention of cardiovascular events in women: analysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA study). Circulation. 2008 Jan 29;117(4):494–502. doi: 10.1161/circulationaha.106.671826. PMID: 18172039.18172039
112 Mora S, Glynn RJ, Hsia J, . Statins for the primary prevention of cardiovascular events in women with elevated high-sensitivity C-reactive protein or dyslipidemia: results from the Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin (JUPITER) and meta-analysis of women from primary prevention trials. Circulation. 2010 Mar 9;121(9):1069–77. doi: 10.1161/circulationaha.109.906479. PMID: 20176986.20176986
113 Nakamura H, Mizuno K, Ohashi Y, . Pravastatin and cardiovascular risk in moderate chronic kidney disease. Atherosclerosis. 2009 Oct;206(2):512–7. doi: 10.1016/j.atherosclerosis.2009.03.031. PMID: 19423108.19423108
114 Nakaya N, Mizuno K, Ohashi Y, . Low-dose pravastatin and age-related differences in risk factors for cardiovascular disease in hypercholesterolaemic Japanese: analysis of the management of elevated cholesterol in the primary prevention group of adult Japanese (MEGA study). Drugs Aging. 2011 Sep 1;28(9):681–92. doi: 10.2165/11595620-000000000-00000. PMID: 21815708.21815708
115 Neil HA, DeMicco DA, Luo D, . Analysis of efficacy and safety in patients aged 65-75 years at randomization: Collaborative Atorvastatin Diabetes Study (CARDS). Diabetes Care. 2006 Nov;29(11):2378–84. doi: 10.2337/dc06-0872. PMID: 17065671.17065671
116 Newman CB, Szarek M, Colhoun HM, . The safety and tolerability of atorvastatin 10 mg in the Collaborative Atorvastatin Diabetes Study (CARDS). Diab Vasc Dis Res. 2008 Sep;5(3):177–83. doi: 10.3132/dvdr.2008.029. PMID: 18777490.18777490
117 Nishiwaki M, Ikewaki K, Ayaori M, . Risk reductions for cardiovascular disease with pravastatin treatment by dyslipidemia phenotype: a post hoc analysis of the MEGA Study. J Cardiol. 2013 Mar;61(3):196–200. doi: 10.1016/j.jjcc.2012.10.005. PMID: 23265677.23265677
118 Ridker PM. Rosuvastatin in the primary prevention of cardiovascular disease among patients with low levels of low-density lipoprotein cholesterol and elevated high-sensitivity C-reactive protein: rationale and design of the JUPITER trial. Circulation. 2003 Nov 11;108(19):2292–7. doi: 10.1161/01.Cir.0000100688.17280.E6. PMID: 14609996.14609996
119 Ridker PM, Fonseca FA, Genest J, . Baseline characteristics of participants in the JUPITER trial, a randomized placebo-controlled primary prevention trial of statin therapy among individuals with low low-density lipoprotein cholesterol and elevated high-sensitivity C-reactive protein. Am J Cardiol. 2007 Dec 1;100(11):1659–64. doi: 10.1016/j.amjcard.2007.09.072. PMID: 18036365.18036365
120 Ridker PM, Macfadyen JG, Nordestgaard BG, . Rosuvastatin for primary prevention among individuals with elevated high-sensitivity c-reactive protein and 5% to 10% and 10% to 20% 10-year risk. Implications of the Justification for Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) trial for “intermediate risk”. Circ Cardiovasc Qual Outcomes. 2010 Sep;3(5):447–52. doi: 10.1161/circoutcomes.110.938118. PMID: 20736443.20736443
121 Ridker PM, Rifai N, Clearfield M, . Measurement of C-reactive protein for the targeting of statin therapy in the primary prevention of acute coronary events. N Engl J Med. 2001 Jun 28;344(26):1959–65. doi: 10.1056/nejm200106283442601. PMID: 11430324.11430324
122 Sever PS, Dahlöf B, Poulter NR, . Rationale, design, methods and baseline demography of participants of the Anglo-Scandinavian Cardiac Outcomes Trial. ASCOT investigators. J Hypertens. 2001 Jun;19(6):1139–47. doi: 10.1097/00004872-200106000-00020. PMID: 11403364.11403364
123 Sever PS, Poulter NR, Dahlöf B, . Reduction in cardiovascular events with atorvastatin in 2,532 patients with type 2 diabetes: Anglo-Scandinavian Cardiac Outcomes Trial--Lipid-Lowering Arm (ASCOT-LLA). Diabetes Care. 2005 May;28(5):1151–7. doi: 10.2337/diacare.28.5.1151. PMID: 15855581.15855581
124 Shepherd J, Blauw GJ, Murphy MB, . The design of a prospective study of Pravastatin in the Elderly at Risk (PROSPER). PROSPER Study Group. PROspective Study of Pravastatin in the Elderly at Risk. Am J Cardiol. 1999 Nov 15;84(10):1192–7. doi: 10.1016/s0002-9149(99)00533-0. PMID: 10569329.10569329
125 Shepherd J, Cobbe SM, Ford I, . Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. West of Scotland Coronary Prevention Study Group. N Engl J Med. 1995 Nov 16;333(20):1301–7. doi: 10.1056/nejm199511163332001. PMID: 7566020.7566020
126 Sirtori CR, Bianchi G, Bond MG, . Pravastatin intervention trial on carotid artery atherosclerosis in patients with mild hypercholesterolemia: the CAIUS study. Int J Cardiovasc Imaging. 1995;11(2):119–24.
127 Tajima N, Kurata H, Nakaya N, . Pravastatin reduces the risk for cardiovascular disease in Japanese hypercholesterolemic patients with impaired fasting glucose or diabetes: diabetes subanalysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study. Atherosclerosis. 2008 Aug;199(2):455–62. doi: 10.1016/j.atherosclerosis.2008.05.027. PMID: 18635188.18635188
128 Uchiyama S, Nakaya N, Mizuno K, . Risk factors for stroke and lipid-lowering effect of pravastatin on the risk of stroke in Japanese patients with hypercholesterolemia: analysis of data from the MEGA Study, a large randomized controlled trial. J Neurol Sci. 2009 Sep 15;284(1–2):72–6. doi: 10.1016/j.jns.2009.04.002. PMID: 19423132.19423132
129 Staffa JA, Chang J, Green L. Cerivastatin and reports of fatal rhabdomyolysis. N Engl J Med. 2002 Feb 14;346(7):539–40. doi: 10.1056/nejm200202143460721. PMID: 11844864.11844864
130 Roberts MD. Supplemental NDA 21-366/S-016, Crestor (rosuvastatin calcium). 2010. https://www.accessdata.fda.gov/drugsatfda_docs/nda/2010/021366s016MedR.pdf.
131 Colhoun HM, Betteridge DJ, Durrington PN, . Effects of atorvastatin on kidney outcomes and cardiovascular disease in patients with diabetes: an analysis from the Collaborative Atorvastatin Diabetes Study (CARDS). Am J Kidney Dis. 2009 Nov;54(5):810–9. doi: 10.1053/j.ajkd.2009.03.022. PMID: 19540640.19540640
132 Culver AL, Ockene IS, Balasubramanian R, . Statin use and risk of diabetes mellitus in postmenopausal women in the Women’s Health Initiative. Arch Intern Med. 2012 Jan 23;172(2):144–52. doi: 10.1001/archinternmed.2011.625. PMID: 22231607.22231607
133 Jick SS, Bradbury BD. Statins and newly diagnosed diabetes. Br J Clin Pharmacol. 2004 Sep;58(3):303–9. doi: 10.1111/j.1365-2125.2004.02142.x. PMID: 15327590.15327590
134 Sattar N, Preiss D, Murray HM, . Statins and risk of incident diabetes: a collaborative meta-analysis of randomised statin trials. Lancet. 2010 Feb 27;375(9716):735–42. doi: 10.1016/s0140-6736(09)61965-6. PMID: 20167359.20167359
135 Cholesterol Treatment Trialists C, Mihaylova B, Emberson J, . The effects of lowering LDL cholesterol with statin therapy in people at low risk of vascular disease: meta-analysis of individual data from 27 randomised trials. Lancet (London, England). 2012 2012/08//;380(9841):581–90. doi: 10.1016/s0140-6736(12)60367-5. PMID: 22607822.22607822
136 Kohli-Lynch CN, Bellows BK, Thanassoulis G, . Cost-effectiveness of low-density lipoprotein cholesterol level-guided statin treatment in patients with borderline cardiovascular risk. JAMA Cardiol. 2019 Aug 28;28:28. doi: 10.1001/jamacardio.2019.2851. PMID: 31461121.31461121
137 Miedema MD, Dardari ZA, Kianoush S, . Statin eligibility, coronary artery calcium, and subsequent cardiovascular events according to the 2016 United States Preventive Services Task Force (USPSTF) Statin Guidelines: MESA (Multi-Ethnic Study of Atherosclerosis). J Am Heart Assoc. 2018 Jun 13;7(12):13. doi: 10.1161/JAHA.118.008920. PMID: 29899017.29899017
138 Mortensen MB, Nordestgaard BG. Statin use in primary prevention of atherosclerotic cardiovascular disease according to 5 major guidelines for sensitivity, specificity, and number needed to treat. JAMA Cardiol. 2019 Oct 02;02:02. doi: 10.1001/jamacardio.2019.3665. PMID: 31577339.31577339
139 Pletcher MJ, Pignone M, Jarmul JA, . Population impact & efficiency of benefit-targeted versus risk-targeted statin prescribing for primary prevention of cardiovascular disease. J Am Heart Assoc. 2017 Feb 10;6(2):10. doi: 10.1161/JAHA.116.004316. PMID: 28188251.28188251
140 Shah RV, Spahillari A, Mwasongwe S, . Subclinical atherosclerosis, statin eligibility, and outcomes in African American individuals: the Jackson Heart study. JAMA Cardiol. 2017 Jun 01;2(6):644–52. doi: 10.1001/jamacardio.2017.0944. PMID: 28315622.28315622
141 Thanassoulis G, Williams K, Altobelli KK, . Individualized statin benefit for determining statin eligibility in the primary prevention of cardiovascular disease. Circulation. 2016 Apr 19;133(16):1574–81. doi: 10.1161/CIRCULATIONAHA.115.018383. PMID: 26945047.26945047
142 Fulcher J, O’Connell R, Voysey M, . Efficacy and safety of LDL-lowering therapy among men and women: meta-analysis of individual data from 174,000 participants in 27 randomised trials. Lancet. 2015 Apr 11;385(9976):1397–405. doi: 10.1016/s0140-6736(14)61368-4. PMID: 25579834.25579834
143 Brodney S, Valentine KD, Sepucha K, . Patient preference distribution for use of statin therapy. JAMA Netw Open. 2021 Mar 1;4(3):e210661. doi: 10.1001/jamanetworkopen.2021.0661. PMID: 33720368.33720368
144 Albarqouni L, Doust J, Glasziou P. Patient preferences for cardiovascular preventive medication: a systematic review. Heart. 2017 Oct;103(20):1578–86. doi: 10.1136/heartjnl-2017-311244. PMID: 28501795.28501795
145 Van der Aalst CM, Kuijpers D. Risk or Benefit in Screening for Cardiovascular Disease (ROBINSCA): the rationale and study design of a population-based randomized-controlled screening trial for cardiovascular disease. J Clin Trials. 2019;9(1):1000361.
146 van der Aalst CM, Denissen S, Vonder M, . Screening for cardiovascular disease risk using traditional risk factor assessment or coronary artery calcium scoring: the ROBINSCA trial. Eur Heart J Cardiovasc Imaging. 2020 Oct 20;21(11):1216–24. doi: 10.1093/ehjci/jeaa168. PMID: 32584979.32584979
147 Denissen SJ, van der Aalst CM, Vonder M, . Impact of a cardiovascular disease risk screening result on preventive behaviour in asymptomatic participants of the ROBINSCA trial. Eur J Prev Cardiol. 2019 Aug;26(12):1313–22. doi: 10.1177/2047487319843396. PMID: 30966821.30966821
148 Diederichsen AC, Rasmussen LM, Søgaard R, . The Danish Cardiovascular Screening Trial (DANCAVAS): study protocol for a randomized controlled trial. Trials. 2015 Dec 5;16:554. doi: 10.1186/s13063-015-1082-6. PMID: 26637993.26637993
149 Blaha MJ, Nasir K, Budoff MJ, . Impact of C-Reactive Protein and Coronary Artery Calcium on Benefit Observed With Atorvastatin. J Am Coll Cardiol. 2018 May 29;71(21):2487–8. doi: 10.1016/j.jacc.2018.03.478. PMID: 29793637.29793637
150 Mitchell JD, Fergestrom N, Gage BF, . Impact of statins on cardiovascular outcomes following coronary artery calcium scoring. J Am Coll Cardiol. 2018 Dec 25;72(25):3233–42. doi: 10.1016/j.jacc.2018.09.051. PMID: 30409567.30409567
151 Arad Y, Goodman KJ, Roth M, . Coronary calcification, coronary disease risk factors, C-reactive protein, and atherosclerotic cardiovascular disease events: the St. Francis Heart Study. J Am Coll Cardiol. 2005 Jul 5;46(1):158–65. doi: 10.1016/j.jacc.2005.02.088. PMID: 15992651.15992651
152 Dorsch MP, Lester CA, Ding Y, . Effects of race on statin prescribing for primary prevention with high atherosclerotic cardiovascular disease risk in a large healthcare system. J Am Heart Assoc. 2019 Nov 19;8(22):e014709. doi: 10.1161/JAHA.119.014709. PMID: 31707943.31707943
153 Gamboa CM, Colantonio LD, Brown TM, . Race-sex differences in statin use and low-density lipoprotein cholesterol control among people with diabetes mellitus in the reasons for geographic and racial differences in stroke study. J Am Heart Assoc. 2017 May 10;6(5):e004264. doi: 10.1161/jaha.116.004264. PMID: 28490523.28490523
154 Gu A, Kamat S, Argulian E. Trends and disparities in statin use and low-density lipoprotein cholesterol levels among US patients with diabetes, 1999-2014. Diabetes Res Clin Pract. 2018 May;139:1–10. doi: 10.1016/j.diabres.2018.02.019. PMID: 29476887.29476887
155 Karmali KN, Lee JY, Brown T, . Predictors of cholesterol treatment discussions and statin prescribing for primary cardiovascular disease prevention in community health centers. Prev Med. 2016 Jul;88:176–81. doi: 10.1016/j.ypmed.2016.04.011. PMID: 27090436.27090436
156 Schroff P, Gamboa CM, Durant RW, . Vulnerabilities to health disparities and statin use in the REGARDS (Reasons for Geographic and Racial Differences in Stroke) study. J Am Heart Assoc. 2017 Aug 28;6(9):e005449. doi: 10.1161/jaha.116.005449. PMID: 28847913.28847913
157 Suero-Abreu GA, Karatasakis A, Rashid S, . Factors associated with disparities in appropriate statin therapy in an outpatient inner city population. Healthcare (Basel, Switzerland). 2020 Sep 24;8(4):361. doi: 10.3390/healthcare8040361. PMID: 32987753.32987753
158 Wall HK, Ritchey MD, Gillespie C, . Vital Signs: Prevalence of Key Cardiovascular Disease Risk Factors for Million Hearts 2022 - United States, 2011-2016. MMWR Morb Mortal Wkly Rep. 2018 Sep 07;67(35):983–91. doi: 10.15585/mmwr.mm6735a4. PMID: 30188885.30188885
159 Taylor F, Huffman MD, Macedo AF, . Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2013 Jan 31;2013(1):Cd004816. doi: 10.1002/14651858.CD004816.pub5. PMID: 23440795.23440795
160 Ray KK, Seshasai SR, Erqou S, . Statins and all-cause mortality in high-risk primary prevention: a meta-analysis of 11 randomized controlled trials involving 65,229 participants. Arch Intern Med. 2010 Jun 28;170(12):1024–31. doi: 10.1001/archinternmed.2010.182. PMID: 20585067.20585067
161 Tonelli M, Lloyd A, Clement F, . Efficacy of statins for primary prevention in people at low cardiovascular risk: a meta-analysis. Cmaj. 2011 Nov 8;183(16):E1189–202. doi: 10.1503/cmaj.101280. PMID: 21989464.21989464
162 Stone NJ, Robinson J, Lichtenstein AH, . Evidence Report: Managing high blood cholesterol in adults—systematic evidence review from the cholesterol expert panel, 2013 US Department of Health and Human Services. 2013. http://www.nhlbi.nih.gov/sites/www.nhlbi.nih.gov/files/cholesterol-in-adults.pdf Accessed May 10, 2021.
163 Heart Protection Study Collaborative Group. Randomized trial of the effects of cholesterol-lowering with simvastatin on peripheral vascular and other major vascular outcomes in 20,536 people with peripheral arterial disease and other high-risk conditions. J Vasc Surg. 2007 Apr;45(4):645–54; discussion 53-4. doi: 10.1016/j.jvs.2006.12.054. PMID: 17398372.17398372
164 Bukkapatnam RN, Gabler NB, Lewis WR. Statins for primary prevention of cardiovascular mortality in women: a systematic review and meta-analysis. Prev Cardiol. 2010;13(2):84–90. doi: 10.1111/j.1751-7141.2009.00059.x. PMID: 20377811.20377811
165 U.S. Food & Drug Administration Division of Metabolism and Endocrinology Products (DMEP). Memorandum: 15 December 2008, Advisory Committee meeting for rosuvastatin Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research; 2009. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/EndocrinologicandMetabolicDrugsAdvisoryCommittee/UCM193831.pdf. Accessed August 9, 2016.
166 Kaul S, Morrissey RP, Diamond GA. By Jove! What is a clinician to make of JUPITER? Arch Intern Med. 2010 Jun 28;170(12):1073–7. doi: 10.1001/archinternmed.2010.189. PMID: 20585074.20585074
167 Taylor F, Huffman MD, Macedo FA, . Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2011(5) PMID: 21249663.21249663
168 Bonovas S, Filioussi K, Flordellis CS, . Statins and the risk of colorectal cancer: a meta-analysis of 18 studies involving more than 1.5 million patients. J Clin Oncol. 2007 Aug 10;25(23):3462–8. PMID: 17687150.17687150
169 Finegold JA, Manisty CH, Goldacre B, . What proportion of symptomatic side effects in patients taking statins are genuinely caused by the drug? Systematic review of randomized placebo-controlled trials to aid in individual patient choice. Eur J Prev Cardiolog. 2014;21(4):464–74. PMID: 24623264.24623264
170 Macedo AF, Taylor F, Casas JP, . Unintended effects of statins from observational studies in the general population: systematic review and meta-analysis. BMC Med. 2014;12(51) PMID: 24655568.24655568
171 Herrett E, Williamson E, Brack K, . Statin treatment and muscle symptoms: series of randomised, placebo controlled n-of-1 trials. Bmj. 2021;372:n135. doi: 10.1136/bmj.n135.33627334
172 Wood FA, Howard JP, Finegold JA, . N-of-1 trial of a statin, placebo, or no treatment to assess side effects. N Engl J Med. 2020 Nov 26;383(22):2182–4. doi: 10.1056/NEJMc2031173. PMID: 33196154.33196154
173 Kostis JB, Dobrzynski JM. Prevention of cataracts by statins: a meta-analysis. J Cardiovasc Pharmacol Ther. 2014 Mar;19(2):191–200. doi: 10.1177/1074248413511690. PMID: 24311734.24311734
174 Preiss D, Sattar N. Statins and the risk of new-onset diabetes: a review of recent evidence. Curr Opin Lipidol. 2011 Dec;22(6):460–6. doi: 10.1097/MOL.0b013e32834b4994. PMID: 21897230.21897230
175 Preiss D, Seshasai SR, Welsh P, . Risk of incident diabetes with intensive-dose compared with moderate-dose statin therapy: a meta-analysis. JAMA. 2011 Jun 22;305(24):2556–64. doi: 10.1001/jama.2011.860. PMID: 21693744.21693744
176 Dormuth CR, Filion KB, Paterson JM, . Higher potency statins and the risk of new diabetes: multicentre, observational study of administrative databases. Bmj. 2014;348:g3244. doi: 10.1136/bmj.g3244. PMID: 24874977.24874977
177 Holmes MV, Lange LA, Palmer T, . Causal effects of body mass index on cardiometabolic traits and events: a Mendelian randomization analysis.[Erratum appears in Am J Hum Genet. 2014 Feb 6;94(2):312]. Am J Hum Genet. 2014 Feb 6;94(2):198–208. doi: 10.1016/j.ajhg.2013.12.014. PMID: 24462370.24462370
178 Swerdlow DI, Preiss D, Kuchenbaecker KB, . HMG-coenzyme A reductase inhibition, type 2 diabetes, and bodyweight: evidence from genetic analysis and randomised trials. Lancet. 2014.
179 Ward NC, Watts GF, Eckel RH. Statin Toxicity. Circ Res. 2019 Jan 18;124(2):328–50. doi: 10.1161/circresaha.118.312782. PMID: 30653440.30653440
180 Maki KC, Ridker PM, Brown WV, . An assessment by the Statin Diabetes Safety Task Force: 2014 update. J. 2014 May–Jun;8(3 Suppl):S17–29. doi: 10.1016/j.jacl.2014.02.012. PMID: 24793439.24793439
181 Navarese EP, Robinson JG, Kowalewski M, . Association Between Baseline LDL-C Level and Total and Cardiovascular Mortality After LDL-C Lowering: A Systematic Review and Meta-analysis. JAMA. 2018;319(15):1566–79. doi: 10.1001/jama.2018.2525.29677301
182 Song F, Xiong T, Parekh-Bhurke S, . Inconsistency between direct and indirect comparisons of competing interventions: meta-epidemiological study. Bmj. 2011;343:d4909. doi: 10.1136/bmj.d4909. PMID: 21846695.21846695
183 Morrison A, Polisena J, Husereau D, . The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012;28(02):138–44. PMID: 22559755.22559755
184 Pham B, Klassen TP, Lawson ML, . Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005;58(8):769–76. e2. PMID: 16086467.16086467
185 Lundh A, Sismondo S, Lexchin J, . Industry sponsorship and research outcome. Cochrane Database Syst Rev. 2012;12:MR000033. doi: 10.1002/14651858.MR000033.pub2. PMID: 23235689.23235689
186 Sismondo S. Pharmaceutical company funding and its consequences: a qualitative systematic review. Contemp Clin Trials. 2008 Mar;29(2):109–13. PMID: 17919992.17919992
187 Golder S, Loke YK. Is there evidence for biased reporting of published adverse effects data in pharmaceutical industry-funded studies? Br J Clin Pharmacol. 2008 Dec;66(6):767–73. doi: 10.1111/j.1365-2125.2008.03272.x. PMID: 18754841.18754841
188 Naci H, Dias S, Ades AE. Industry sponsorship bias in research findings: a netword meta-analysis of LDL cholesterol redution in randomized trials of statins. Bmj. 2014;349:g5741.25281681
189 Sabatine MS, Giugliano RP, Keech AC, . Evolocumab and Clinical Outcomes in Patients with Cardiovascular Disease. N Engl J Med. 2017 05 04;376(18):1713–22. doi: 10.1056/NEJMoa1615664. PMID: 28304224.28304224
190 Schwartz GG, Steg PG, Szarek M, . ODYSSEY OUTCOMES Committees and Investigators. Alirocumab and cardiovascular outcomes after acute coronary syndrome. N Engl J Med. 2018;379(22):2097–107.30403574
191 Raal FJ, Rosenson RS, Reeskamp LF, . Evinacumab for Homozygous Familial Hypercholesterolemia. N Engl J Med. 2020 Aug 20;383(8):711–20. doi: 10.1056/NEJMoa2004215. PMID: 32813947.32813947
192 Laufs U, Banach M, Mancini GBJ, . Efficacy and Safety of Bempedoic Acid in Patients With Hypercholesterolemia and Statin Intolerance. J Am Heart Assoc. 2019 Apr 2;8(7):e011662. doi: 10.1161/jaha.118.011662. PMID: 30922146.30922146
193 Strandberg TE, Kolehmainen L, Vuorio A. Evaluation and treatment of older patients with hypercholesterolemia: a clinical review. JAMA. 2014 Sep 17;312(11):1136–44. doi: 10.1001/jama.2014.10924. PMID: 25226479.25226479
194 Giral P, Neumann A, Weill A, . Cardiovascular effect of discontinuing statins for primary prevention at the age of 75 years: a nationwide population-based cohort study in France. Eur Heart J. 2019 Nov 14;40(43):3516–25. doi: 10.1093/eurheartj/ehz458. PMID: 31362307.31362307
195 Lavie G, Hoshen M, Leibowitz M, . Statin Therapy for Primary Prevention in the Elderly and Its Association with New-Onset Diabetes, Cardiovascular Events, and All-Cause Mortality. Am J Med. 2021 May;134(5):643–52. doi: 10.1016/j.amjmed.2020.09.058. PMID: 33217370.33217370
196 Cholesterol Treatment Trialists’ Collaboration. Efficacy and safety of statin therapy in older people: a meta-analysis of individual participant data from 28 randomised controlled trials. Lancet. 2019 Feb 2;393(10170):407–15. doi: 10.1016/s0140-6736(18)31942-1. PMID: 30712900.30712900
197 Orkaby AR, Driver JA, Ho YL, . Association of Statin Use With All-Cause and Cardiovascular Mortality in US Veterans 75 Years and Older. JAMA. 2020 Jul 7;324(1):68–78. doi: 10.1001/jama.2020.7848. PMID: 32633800.32633800
198 Awad K, Mikhailidis DP, Toth PP, . Efficacy and Safety of Alternate-Day Versus Daily Dosing of Statins: a Systematic Review and Meta-Analysis. Cardiovasc Drugs Ther. 2017 Aug;31(4):419–31. doi: 10.1007/s10557-017-6743-0. PMID: 28741244.28741244
199 Grundy SM, Stone NJ, Bailey AL, . 2018 AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol: Executive Summary: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2019 06 18;139(25):e1046–e81. doi: 10.1161/CIR.0000000000000624. PMID: 30565953.30565953
200 Anderson TJ, Gregoire J, Pearson GJ, . 2016 Canadian Cardiovascular Society Guidelines for the Management of Dyslipidemia for the Prevention of Cardiovascular Disease in the Adult. Can J Cardiol. 2016 Nov;32(11):1263–82. doi: 10.1016/j.cjca.2016.07.510. PMID: 27712954.27712954
201 National Institute for Health Care Excellence. Cardiovascular disease: risk assessment and reduction, including lipid modification: Clinical Guideline [CG181]. 2016. https://www.nice.org.uk/guidance/cg181. Accessed Apr 10 2020.
202 Mach F, Baigent C, Catapano AL, . 2019 ESC/EAS Guidelines for the management of dyslipidaemias: lipid modification to reduce cardiovascular risk: The Task Force for the management of dyslipidaemias of the European Society of Cardiology (ESC) and European Atherosclerosis Society (EAS). Eur Heart J. 2019;41(1):111–88. doi: 10.1093/eurheartj/ehz455. PMID: 31504418.31504418
203 Bosch J, Lonn EM, Dagenais GR, . Antihypertensives and Statin Therapy for Primary Stroke Prevention: a Secondary Analysis of the HOPE-3 Trial. Stroke. 2021 PMID: 33985364.33985364
204 Ridker PM, MacFadyen J, Cressman M, . Efficacy of rosuvastatin among men and women with moderate chronic kidney disease and elevated high-sensitivity C-reactive protein: a secondary analysis from the JUPITER (Justification for the Use of Statins in Prevention-an Intervention Trial Evaluating Rosuvastatin) trial. J Am Coll Cardiol. 2010 Mar 23;55(12):1266–73. doi: 10.1016/j.jacc.2010.01.020. PMID: 20206456.20206456