# Acknowledgments

The authors acknowledge Jennifer Lin, MD, MCR, director of the Kaiser Permanente Research Affiliates EPC; Christina Bougatsos, MPH, of Oregon Health & Science University; and Associate Biostatistician, Yun Yu, MS, of Oregon Health & Science University. The authors also thank the AHRQ Medical Officer, Howard Tracer, MD, as well as the U.S. Preventive Services Task Force.