# Chapter 4 Discussion

## Summary of Review Findings

Table 14 summarizes the evidence reviewed for this update. In adults at increased cardiovascular risk but without prior cardiovascular events, statin therapy was associated with reduced risk of clinical outcomes compared with placebo or no statin use, based on pooled evidence from 22 trials with 6 months to 6 years of followup. Figure 2 is a visual representation of pooled results for primary outcomes. Compared with the 2016 USPSTF review, estimated benefits of statin therapy on mortality were slightly attenuated (smaller). Three trials were added for this update: one new trial of patients with rheumatoid arthritis (TRACE-RA^84^) and two trials (ALLHAT-LLT^80^ and PROSPER^91^) that were previously excluded because they exceeded the threshold for secondary prevention participants (>10%), but provided results for the primary prevention population. The difference in estimates was largely due to the addition of ALLHAT-LLT and PROSPER, which each found no difference between statin therapy versus placebo or usual care in risk of all-cause or cardiovascular mortality. PROSPER enrolled older patients (70 to 82 years of age, mean 75 years) compared to the other primary prevention trials (mean 52 to 66 years), which could have diminished effects of statin therapy on mortality due to competing non-cardiovascular mortality or decreased effectiveness of statins in this age group due to other factors. ALLHAT-LLT poses challenges in interpretation because it was open-label and had high attrition in the statin therapy arm and high crossover from the usual care arm, with a small difference between statin therapy and usual care in achieved cholesterol levels (difference in LDL-C 14.2% in ALLHAT-LLT compared with 26% to 50% in other large primary prevention trials^66,79,93^), with greater than expected LDL-C reduction in the usual care arm. Despite the attenuated estimates, updated pooled results continued to indicate a statistically significant decreased risk of all-cause mortality (18 trials, RR 0.92, 95% CI, 0.87 to 0.98; I^2^=0%; ARD −0.35%, after 1 to 6 years) and estimates for stroke (15 trials, RR 0.78, 95% CI, 0.68 to 0.90; I^2^=22%; ARD −0.39%, after 6 months to 6 years), MI (12 trials, RR 0.67, 95% CI, 0.60 to 0.75; I^2^=14%; ARD, −0.85%, after 2 to 6 years), revascularization (10 trials, RR 0.71, 95% CI, 0.63 to 0.80; I^2^=15%; ARD, −0.59% after 2 to 6 years), and composite cardiovascular outcomes (15 trials, RR 0.72, 95% CI, 0.64 to 0.81; I^2^=51%; ARD −1.28% after 1 to 6 years) were similar compared to the 2016 USPSTF review. For cardiovascular mortality, the pooled estimate with additional data was no longer statistically significant and the estimated benefit was smaller (12 trials, RR 0.91, 95% CI, 0.81 to 1.02; I^2^=0% ARD −0.13%; NNT=769 compared with 10 trials in the 2016 USPSTF review; RR 0.82, 95% CI, 0.71 to 0.94; I^2^=0%; ARD, −0.20%; NNT, 500 after 2 to 6 years). Findings were generally robust in sensitivity and stratified analyses based on trial quality, duration of followup, baseline TC or LDL-C levels, exclusion of trials that were stopped early, and exclusion of trials that enrolled a small proportion of patients with prior cardiovascular events. Based on updated pooled estimates, the NNT with statin therapy to prevent one death after 1 to 6 years increased to 286 compared with 250 in the 2016 USPSTF review; for MI, stroke, and composite cardiovascular outcomes, the NNTs were very similar. The NNT estimates are based on pooled data from primary prevention trials; in specific populations and settings the NNT will vary according to the baseline risk of the population and the duration of followup.

Table 14 Summary of Evidence Table

Key Question | Studies (k); Study Designs | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
1a. Benefits of statins | k=22 RCTs (19 in prior report, 3 new); N=90,624; For individual outcomes, k ranged from 10 (for revascularization) to 18 (for all-cause mortality) and N ranged from 65,924 (revascularization) to 85,186 (all-cause mortality) | - All-cause mortality: RR 0.92 (95% CI, 0.87 to 0.98; I^2^=0%); ARD −0.35%; - CV mortality: RR 0.91 (95% CI, 0.81 to 1.02; I^2^=0%); ARD −0.13%; - Fatal or nonfatal stroke: RR 0.78 (95% CI, 0.68 to 0.90; I^2^=22%); ARD −0.39%; - Fatal or nonfatal MI: RR 0.67 (95% CI, 0.60 to 0.75; I^2^=14%) ARD, −0.85%; - Revascularization: RR 0.71 (95% CI, 0.63 to 0.80; I^2^=15%); ARD, −0.59%; - Composite CV outcomes: RR 0.72 (95% CI, 0.64 to 0.81; I^2^=51%); ARD −1.28% | Consistent; Some imprecision for CV mortality; otherwise precise | Variability in inclusion criteria, statin therapy, duration of followup, and definition of composite CV outcomes; Findings for CV mortality sensitive to inclusion of 1 trial with methodological limitations | Moderate (CV mortality); High (all other outcomes) | High applicability to U.S. primary care settings; All studies enrolled participants with CVD risk factors; The trials primarily enrolled White participants; mean age was 52 to 66 years in all trials except for one (mean age 75 years)
1b. Benefits according to demographic, clinical or socioeconomic characteristics | k=10 (7 in prior report, 3 new); N=81,093 | 7 trials found no clear differences in risk estimates associated with statin therapy vs. placebo or no statin defined by demographic and clinical factors; Meta-analyses of three trials that reported results for participants over age 70 were generally consistent with those for total populations; No trial evaluated socioeconomic characteristics. | Consistent; Some imprecision in meta-analyses stratified according to age | Few studies reported outcomes according to clinical characteristics; no study reported on socioeconomic characteristics | Moderate for demographic characteristic (insufficient for age >75 years); Low to moderate for clinical characteristics | High applicability to U.S. primary care settings.; The trials primarily enrolled White participants; no trial reported data for persons >80 years of age and only one trial reported data for persons >75 years of age
1c. Benefits according to fixed or titrated dose | k=3 trials dose titrated (all in prior report);; N=15,356; 19 trials fixed dose (16 in prior report, 3 new); N=75,268 | No trial directly compared a strategy of titrating statin doses to achieve target LDL-C levels vs. fixed statin dose.; In indirect comparisons, there were no clear differences between trials that permitted limited dose titration compared with those that used fixed dose therapy | Consistent; Imprecise (dose titration) | No direct evidence | Low | High applicability to U.S. primary care settings
2a. Harms of statins | k=19 trials (17 in prior review, 2 new); N=75,005; k=3 observational studies (2 in prior report, 1 new); N=417,523 | - Study withdrawal due to AEs: RR 0.97, (95% CI, 0.78 to 1.19; I^2^=84%) ARD, 0.03%; - Serious AEs: RR 0.97 (95% CI, 0.93 to 1.01; I^2^=0%) ARD, 0.09%; - Cancer: RR 0.98 (95% CI, 0.91 to 1.04; I^2^=0%) ARD, −0.10%; - Diabetes: RR 1.04 (95% CI, 0.92 to 1.19; I^2^=52%) ARD, 0.11%; - Myalgia: RR 0.98 (95% CI, 0.86 to 1.11; I^2^=30%) ARD, 0.02%); - Rhabdomyolysis: RR 1.54 (95% CI, 0.36 to 6.64; I^2^=0%) ARD, 0.01%; - ALT elevation: RR 0.94 (95% CI, 0.78 to 1.13; I^2^=0%) ARD, −0.03%; - Renal impairment (2 trials), cognition (1 trial): No increase in risk; - Cataract surgery (1 trial): 3.8% vs. 3.3%, RR 1.24 (95% CI, 1.03 to 1.49) | Some inconsistency (diabetes); Some imprecision (renal impairment, rhabdomyolysis, cataract surgery, cognition); Otherwise consistent and precise | See Key Question 1a | Low (cognition and cataract surgery); Moderate (renal impairment and diabetes); High (other harms) | See Key Question 1a
2b. Harms according to demographic, clinical or socioeconomic characteristics | k=4 trials (all included in prior report with new data identified); N=38,806 | No difference in harms of statin therapy based on within-study analyses stratified according to age (3 trials), sex (2 trials), or race/ethnicity (1 trial).; One trial found high intensity statin therapy associated with increased risk of incident diabetes in persons with one or more diabetes risk factors, but not in those without diabetes risk factors | Unable to assess consistency (sex, race/ethnicity, and diabetes risk factors); Imprecise | Findings based on one or a small number of studies | Low | High applicability to U.S. primary care settings
3. Benefits and harms according to statin intensity | k=4 trials (3 in prior report, 1 new); N=9,360 | One new trial found no difference in clinical outcomes with statin treatment of different intensities but achieved small between-group differences in LDL-C levels; Three trials that evaluated different statin intensities were not adequately powered to detect differences in clinical outcomes; Indirect comparisons of trials stratified according to the intensity of therapy did not indicate a dose-dependent association | Consistent; Some imprecision | The largest head-to-head trial of different statin intensities was conducted in Japan and used different statin intensity definitions than in the U.S.; most findings based on indirect, across-study comparisons; most trials evaluated moderate intensity statin therapy | Moderate | High applicability to U.S. primary care settings; Most trials evaluated moderate-intensity statin therapy

Abbreviations: AE=adverse event; ALT= alanine transaminase; ARD=absolute risk difference; CI=confidence interval; CV=cardiovascular; CVD=cardiovascular disease; LDL-C=low-density lipoprotein-cholesterol; MI=myocardial infarction; RCT=randomized clinical trial; RR=relative risk; U.S.=United States.

Figure 2 Dot Plots for Primary Outcomes

Abbreviations: AE=adverse event; ALT=Alanine Aminotransferase; CI=confidence interval; CV=cardiovascular; MA=meta-analysis; MI=myocardial infarction; Prop=proportion; RR=relative risk; SOE=strength of evidence.

Figure 2 contains a dot plot that shows the dichotomous outcomes for statins versus placebo or no statin. The outcomes on the y-axis of the plot include all-cause mortality, cardiovascular mortality, stroke (fatal or nonfatal), myocardial infarction (fatal or nonfatal), revascularization, composite cardiovascular outcomes, withdrawal due to adverse events, serious adverse events, cancer, diabetes, myalgia, rhabdomyolysis, and alanine aminotransferase elevation. The pooled proportions of each outcome is indicated by a red triangle for statins and a blue circle for control. The middle of the figure contains a forest plot with decreased likelihood of a given outcome indicated to the left and increased likelihood of a given outcome indicated on the right along the x-axis. The right side of the figure contains risk ratios with 95% confidence intervals, the proportion and number of participants who experienced each outcome in the statins arm, the proportion and number of participants who experienced each outcome in the control arm, the number of trials, the I-squared value, and the strength of evidence.

Our findings regarding benefits of statin therapy were generally consistent with other high-quality systematic reviews^159–162^ that primarily focused on patients without prior cardiovascular events, though there was variability in inclusion criteria (e.g., inclusion threshold for proportion of patients with prior cardiovascular events, inclusion of trials of patients with specific conditions such as severe kidney disease, or inclusion of trials of statins for prevention of noncardiovascular outcomes such as Alzheimer’s disease) and methods for analyzing outcomes (e.g., events that occurred during statin therapy or inclusion of events that occurred after treatment was discontinued). Our review provides a more comprehensive and up-to-date analysis compared to other systematic reviews, as it includes trials published subsequent to the prior reviews, including the large HOPE-3 trial^93^ and additional data on primary prevention participants from ALLHAT-LLT,^80^ WOSCOPS,^92^ and PROSPER.^91^ For all-cause mortality, our point estimate was very similar to the estimates reported in other systematic reviews,^159–161^ though in one of the reviews, which did not include HOPE-3, the difference was not statistically significant (RR 0.91, 95% CI, 0.83 to 1.01).^160^ Cardiovascular mortality was not analyzed as an outcome in the other systematic reviews.

As in the 2016 USPSTF review, benefits of statins appeared similar in patient groups defined by demographic characteristics such as sex and race/ethnicity and clinical characteristics such as presence of diabetes or renal dysfunction, though some analyses may have lacked statistical power to detect differences. Evidence on how benefits of statin therapy vary according to age remains limited for older (>70 or >75 years) persons. Although within-study analyses indicated no differences in benefits of statin when patients were stratified according to age, all studies except for one (JUPITER)^66^ stratified patients using lower (55, 60, or 65 year) cutoffs. A pooled analysis from three trials with data for patients >70 years of age reported results generally consistent with the overall (not restricted by age) pooled estimates, but results were imprecise.^66,91,106^

For effects of statin therapy by sex, our findings are in accordance with a pooled analysis on the effects of statins in women enrolled in JUPITER,^66^ AFCAPS/TexCAPS,^79^ and MEGA,^88^ which reported pooled estimates for all-cause mortality (RR 0.78, 95% CI, 0.53 to 1.15) and cardiovascular events (RR 0.63, 95% CI, 0.49 to 0.82) that were consistent with our pooled estimates,^112^ as well as an individual patient data meta-analysis of primary and secondary prevention trials from the Cholesterol Treatment Trialists’ Collaboration that found similar effects of statin therapy in women and men, based on degree of LDL-lowering.^142^ Results from a good-quality systematic review on the effect of statins in women that included trials^80,163^ in which more than 10 percent of the population had prior CVD events also reported estimates for all-cause mortality (3 studies; RR 0.90, 95% CI, 0.60 to 1.35; I^2^=11%) and CHD events (6 studies; RR 0.78, 95% CI, 0.64 to 0.96; I^2^=7%)^164^ that were similar to our estimates.

Benefits of statin therapy did not appear to be restricted to patients with severely elevated lipid levels, as similar effects were observed in groups stratified according to baseline TC or LDL-C level^66,77,79,88,93,125^ and in trials that excluded patients with moderate or severe dyslipidemia but included those who had other cardiovascular risk factors.^66,75,77,85,90^ Similarly, trials that stratified patients according to a baseline global cardiovascular risk score reported similar risk estimates in those classified as higher and lower assessed risk.^66,79,93^ Given similar RR estimates, however, the absolute benefits of statin therapy will be greater in patients at higher baseline risk. This has implications for determining the cardiovascular risk threshold used to select patients for statin treatment (e.g., 10-year risk >7.5% vs. >10%). In JUPITER, which enrolled patients with an LDL-C level of less than 130 mg/dL and a CRP level of 2.0 mg/L or greater, a post-hoc analysis found that the incidence of cardiovascular events in patients with at least one additional cardiovascular risk factor was nearly twice as high as in those without additional risk factors (15.5 vs. 7.7 events per 1,000 patient-years),^165,166^ resulting in a NNT to prevent 1 cardiovascular event about twice as high in the subgroup without additional risk factors, assuming a similar relative benefit.^66^ Although an individual patient data meta-analysis from the Cholesterol Treatment Trialists’ Collaboration found that benefits of statin therapy were larger in patients at lower (<10%) 10-year cardiovascular risk compared with those at greater risk, it included trials of primary or secondary prevention and the analysis was based on response (degree of LDL-C lowering) to statin therapy.^142^

As in the 2016 USPSTF review, statin treatment in adults without prior cardiovascular events was not associated with increased risk of withdrawal due to adverse events, serious adverse events, cancer, or elevated liver enzymes versus placebo or no statin therapy. Very limited evidence indicated no differences in harms of statins according to age, sex, or race/ethnicity. Our findings regarding harms of statins for primary prevention are generally consistent with other systematic reviews, some of which also included trials of statins for secondary prevention.^57,58,159,167,168^ Similar to meta-analyses of trials of primary and secondary prevention,^54,169^ we found no increased risk of muscle-related harms with statin use, although observational studies of patients taking statins for various indications have found an increased risk of myopathy compared with nonuse,^170^ as well as study withdrawal due to adverse events or muscle symptoms. However, these findings could be due to expectations regarding side effects and nocebo effects. This is supported by two recent N-of-1 trials of patients intolerant to statin therapy (ineligible for inclusion because >10% of participants had prior cardiovascular events) that found no difference in muscle symptom scores between statin versus placebo;^171,172^ in one of the trials,^172^ muscle symptom scores were lower in patients randomized to no tablet compared to those randomized to either a statin or placebo tablet.

HOPE-3 found statin therapy associated with increased risk of cataract surgery, an unanticipated finding. None of the other primary prevention trials evaluated risk of cataracts or cataract surgery. A systematic review that included secondary prevention trials and observational studies reported findings discordant with HOPE-3, with statins associated with decreased risk of incident cataracts (OR, 0.81, 95% CI, 0.71 to 0.93) and cataract surgery (OR, 0.66, 95% CI, 0.61 to 0.71).^173^ A recent scientific statement issued by the American Heart Association that included observational studies and studies of secondary prevention found no convincing evidence of a causal relationship between statins and cognitive dysfunction.^59^

As in the 2016 USPSTF review, statin therapy for primary prevention was not associated with increased risk of incident diabetes (6 trials, RR 1.04, 95% CI, 0.92 to 1.19; I^2^=52%). However, results of individual primary prevention trials were inconsistent, with one large trial (JUPITER) showing increased risk of diabetes (3.0% vs. 2.4%; RR 1.25, 95% CI, 1.05 to 1.49).^66^ This could be due to JUPITER being the only trial assessing incident diabetes to utilize high-potency statin therapy. Other analyses that included trials of statins for secondary prevention suggest an association between intensity of statin dose and risk of incident diabetes.^161,174–176^ In JUPITER, the risk of diabetes was increased in patients with risk factors for diabetes at baseline but not in persons without diabetes risk factors. Based on JUPITER, among patients with diabetes risk factors, 134 cardiovascular events were prevented for every 54 additional incident cases of diabetes, while among persons without diabetes risk factors, 86 cardiovascular events were prevented and no incident cases of diabetes were diagnosed.^95^ A potential mechanism by which statins may increase risk of diabetes is through a modest increase in body weight, though other mechanisms may also contribute.^177–180^ Observational studies reported somewhat inconsistent results regarding the association between statin therapy and diabetes risk, but differed in study design and with regard to whether they controlled for statin intensity or accounted for statin adherence.^94,132,133^

Evidence on the association between statin use in adults without prior cardiovascular events and renal or cognitive harms was sparse but indicated no increase in risk. Our findings are consistent with a systematic review of RCTs and observational studies on the effect of statins on cognition that found no effect on incidence of Alzheimer’s disease or dementia and no differences in performance on tests of procedural memory, attention, motor speed, global cognitive performance, executive function, declarative memory, processing speed, or visuoperception.^57^ Unlike our review, this systematic review included trials of patients receiving statins for any reason, including for prevention of cognitive decline or dementia and for secondary prevention following a cardiovascular event. A recent scientific statement issued by the American Heart Association that included observational studies and studies of secondary prevention also found no convincing evidence of a causal relationship between statins and cognitive dysfunction.^59^

As in the 2016 USPSTF review, we identified no study directly comparing treatment with statins titrated to attain target cholesterol levels versus other (e.g., fixed-dose) treatment strategies. Although indirect comparisons based on trials of statins versus placebo or no statin that permitted dose titration compared with those that used fixed-dose therapy showed no clear differences in risk of all-cause or cardiovascular mortality, MI, or stroke, only three^79,81,88^ of 22 primary prevention trials (all included in the 2016 USPSTF review) permitted dose titration. Further, dose titration in these trials was limited (statin therapy did not go from low- to high-intensity in any trial, and one trial only titrated within the low-intensity category), precluding strong conclusions.

Little direct evidence was available to determine effects of statin therapy intensity on clinical outcomes or adverse events. Two trials included in the 2016 USPSTF review that directly compared different statin intensities were underpowered to evaluated clinical outcomes.^76,87^ One new trial found no difference between more versus less intensive statin therapy based on LDL-C targets, but was of limited usefulness for evaluating statin intensity because it achieved little differential between groups in LDL-C or statin doses.^83^ Indirect comparisons based on trials of statins versus placebo or no statin stratified according to the intensity of therapy were also limited, as most trials evaluated moderate-intensity therapy. For all-cause mortality, risk estimates were similar in trials of low-intensity (RR 0.72, 95% CI, 0.52 to 1.00; I^2^=0%), moderate-intensity (RR 0.95, 95% CI, 0.89 to 1.02; I^2^=0%) and high-intensity (RR 0.81, 95% CI, 0.68 to 0.97; I^2^=0%) statins. Estimates for composite cardiovascular outcomes were also similar in trials of low- (RR 0.68, 95% CI, 0.51 to 0.90; I^2^=0%), moderate- (RR 0.79, 95% CI, 0.70 to 0.90; I^2^=46%) and high-intensity statins (RR 0.58, 95% CI, 0.48 to 0.70; I^2^=0%). For other clinical outcomes, there were too few trials of low- and high-intensity statins for meaningful comparisons. A meta-analysis from the Cholesterol Treatment Trialists’ Collaboration of individual patient data found an association between the degree of LDL-C reduction and reduced risk of clinical outcomes, potentially providing indirect evidence regarding the relative effectiveness of higher- versus lower-intensity statin therapy.^135^ Although this analysis included trials of patients with prior cardiovascular events, estimates were similar in patients with an estimated 5-year risk of less than 5 percent or of 5 to 10 percent, a subgroup unlikely to include persons with prior cardiovascular events. A good-quality systematic review also found no clear effects of statin intensity on benefits or harms outcomes but categorized statins as low (fluvastatin, lovastatin, pravastatin, simvastatin) or high (atorvastatin and rosuvastatin) potency without consideration of statin dose or estimated lipid-lowering effect.^161^ A recent meta-analysis found more intensive LDL-C lowering associated with progressively greater reduction with higher baseline LDL-C in risk of mortality and cardiovascular outcomes, but was based on primary and secondary prevention trials and included trials of nonstatin and combination lipid lowering therapies.^181^

## Limitations

Our review had some limitations. Statistical heterogeneity was present in several pooled analyses. Therefore, we used the DerSimonian and Laird random-effects model to pool studies. The DerSimonian and Laird random-effects model may result in CIs that are too narrow when heterogeneity is present, particularly when the number of studies is small.^70^ Therefore, we repeated analyses in which statistical heterogeneity was present using the profile likelihood method, which resulted in similar findings. To address statistical heterogeneity, we also performed sensitivity and subgroup analyses based on study quality, duration of followup, intensity of statin therapy, baseline lipid levels, and exclusion of trials that enrolled some patients with prior cardiovascular events. Although statistical heterogeneity remained present in some analyses, results were generally robust in sensitivity and stratified analyses. The pooled estimate for cardiovascular mortality appeared sensitive to inclusion of primary prevention data from ALLHAT-LLT, which was open-label and had other methodological limitations. A post-hoc sensitivity analysis in which ALLHAT-LLT was excluded resulted in statin therapy being associated with a statistically significant reduction in risk of CV mortality (Appendix E).

We did not have access to individual patient data. Therefore, our findings are based on analyses of study-level data and our ability to analyze effects in subgroups was restricted to published reports. Two mixed (primary and secondary prevention) trials^74,90^ that met inclusion criteria because fewer than 10 percent of patients had prior cardiovascular events did not report data separately for the primary prevention population; therefore, our analysis was based on results for the whole population. However, excluding these trials from our analyses did not affect our findings. Primary prevention data from the previously included WOSCOPS trial^92^ and two trials^80,91^ that were previously excluded due to secondary prevention patients exceeding the 10 percent threshold were added for this update.

We used indirect comparisons when direct evidence was unavailable or limited to evaluate effects of titrated versus fixed-dose statin therapy, intensity of statin therapy, and subgroup effects. Although findings based on indirect comparisons were generally consistent with available direct evidence, results based on indirect comparisons should be interpreted with caution due to potential differences across trials that could invalidate assumptions regarding similarity of treatment effects.^182^

We excluded non–English-language articles, which could result in language bias. However, some research suggests that English-language restriction has little effect on the conclusions of systematic reviews of topics other than complementary medicine, and we did not identify any large non-English trials of statins versus placebo referenced in other systematic reviews.^183,184^ We limited formal assessments for publication bias using statistical and graphical methods for small sample effects to analyses with at least 10 studies, as research indicates that such methods can be misleading with smaller numbers of studies.^71^ Findings suggest potential small sample effects for the cardiovascular mortality analysis, but are difficult to interpret due to very few small sample trials. Only three trials received no industry funding.^80,81,87^ Although research has found an association between receipt of industry funding and biased estimates,^185–187^ analyses of statin trials found no association between funding source and degree of LDL-C reduction.^188^

## Emerging Issues/Next Steps

Determining the optimal methods for assessing cardiovascular risk generally and in specific populations (e.g., defined by race/ethnicity or socioeconomic) status remains an ongoing area of interest, due to documented overestimation and underestimation by the PCE.^40–47^ Various modifications to the PCE have been proposed, but require additional validation.^21,49–52^ There is also ongoing interest in use of biomarkers or imaging to supplement traditional risk factors for predicting cardiovascular risk, such as measurement of coronary artery calcium score, measurement of carotid intima-media thickness, CRP levels, and alternative lipid measures.^34,37^ The 2019 ACC/AHA primary prevention guideline suggests consideration of these and other “risk-enhancing” factors to refine assessments based on the PCE (see Introduction/Risk Factors).^21^ However, evidence is needed to understand effects of utilizing the 2019 ACC/AHA approach on clinical outcomes.

Although pitavastatin was approved by the U.S. Food and Drug Administration in 2009, no trial of statins for primary prevention evaluated this drug. Drugs in the proprotein convertase subtilisin/kexin type 9 (PCSK9) class were first approved by the U.S. Food and Drug Administration in 2015 for use with diet and maximally tolerated statin therapy in persons with familial dyslipidemia or clinical atherosclerotic CVD who require additional LDL-C reduction. PCSK9 drugs reduce LDL-C levels by about 60 percent compared with standard therapy, including maximally tolerated statins. PCSK9 drugs have been shown to reduce risk of cardiovascular events in patients with atherosclerotic CVD or following acute coronary syndrome^189,190^ but effectiveness for primary prevention has not been evaluated. PCSK9 drugs are indicated for secondary prevention in persons at very high risk and may be indicated in persons with familial dyslipidemia, when maximal statin therapy is inadequate.^64^ Other emerging lipid-lowering therapies include evinacumab (a monoclonal antibody against the gene encoding angiopoietin-like 3)^191^ and bempedoic acid (an inhibitor of ATP-citrate lyase^192^), but their role in primary prevention is uncertain.

## Relevance for Priority Populations

Statin therapy appears to be associated with similar relative effectiveness versus placebo based on age younger or older than 55, 60, 65, or 70 years. However, because risk of cardiovascular events increases with age, absolute benefits of statin therapy are larger in older adults. For example, in the JUPITER trial, the NNT to prevent one cardiovascular event was 62 in persons age 70 years or older and 94 in those younger than age 70 years.^66^ The trials of statin therapy included in this review reported no increased risk of muscle-related, liver-related, renal, oncologic, or cognitive adverse events versus placebo, but only three trials evaluated potential interactions between age and adverse events (and found no statistically significant interaction).^66,96,102,106^ Older persons may be at increased risk of adverse events due to use of concomitant medications or comorbid conditions, warranting additional research to fully understand the balance of benefits and harms in this population. In addition, evidence on benefits and harms of statin therapy in persons older than 70 years of age remains limited. Only three trials^66,91,106^ reported data for persons greater than 70 years old (one^106^ reported results in persons >75 years of age), with imprecise pooled estimates. Evidence was extremely limited for patients over 80 years of age; most trials were restricted to younger patients and trials that did enroll patients older than age 80 years did not report results separately for this group.^91,193^ Although observational studies have found statins associated with improved cardiovascular outcomes in older persons, findings are susceptible to confounding.^194–197^

CHD is more prevalent in American Indians/Alaska Natives compared with other races, and age-adjusted death rates are higher among Black and South Asian compared with White nonHispanic persons. Accurate risk assessment in racial/ethnic groups remains a challenge, with no specific risk calculator for certain populations (e.g., Hispanic, American Indian/Alaska Native, East or South Asian, and others), with studies showing inaccuracies of the PCE in these groups. In trials that reported race/ethnicity, White participants were the predominant group in all but one trial^93^ (one other trial^88^ was conducted in Japan but did not report race). Evidence on how benefits or harms of statin therapy vary by race or ethnicity was limited to two trials that indicated no significant interactions.^66,93,97^ Studies indicate disparities in statin therapy according to race, with decreased utilization in Black compared with White persons.^152–154,156,157^ Research is needed to understand factors associated with differential statin use by race, such as access to health care and other social determinants, variability in preferences regarding statin use, and system racism. Evidence on how statin utilization varies by socioeconomic factors was limited but also indicated disparities associated with not having health insurance and lower income level.^153,154,156^

## Future Research

Several research gaps limit the full understanding of benefits and harms of statin therapy. Trials that directly compare titrated statin therapy to target lipid levels versus fixed-dose therapy would help to inform optimal dosing strategies. Trials that directly compare higher- versus lower- intensity statin therapy and are powered to assess clinical outcomes are also needed. Although evidence suggests that alternate day or more intermittent dosing of statins is associated with similar effects on lipid parameters compared with daily dosing and may be better tolerated,^198^ studies are needed to understand effects on clinical outcomes. Additional research would be helpful for more definitively determining whether statin therapy is associated with increased risk of diabetes, as well as factors associated with increased diabetes risk with statin therapy. More research is also needed to clarify benefits and harms of statins in older persons, including persons older than 80 years of age. No study has evaluated benefits and harms of discontinuation of statin therapy in persons attaining older ages (e.g., 75 or 80 years). Evidence to determine whether benefits or harms of statin therapy varies by race/ethnicity remains sparse and research is needed to better understand causes of disparities in statin utilization, as well as effective methods to reduce disparities.

Additional research is needed to validate proposed modifications to the PCE to improve accuracy, generally as well as in specific racial and ethnic groups. Studies are needed to determine how application of different CV risk thresholds impact clinical outcomes and whether use of coronary artery calcium scores or other “risk enhancers” to refine PCE risk estimates are associated with improved clinical outcomes. A large European trial of coronary artery calcium scoring versus traditional risk assessment (using the SCORE instrument) is currently in progress, with results expected in 2023.^146^ Research is also needed to better understand how frequently cardiovascular risk assessment (including lipid testing) should be performed, ideally by directly comparing how different assessment intervals impact use of statin therapy as well as subsequent clinical outcomes.

## Conclusions

In adults at increased CVD risk but without prior CVD events, statin therapy is associated with reduced risk of all-cause mortality and CVD events; effects on cardiovascular mortality were not statistically significant. Benefits of statin therapy appear to be present across diverse demographic and clinical populations, with greater absolute benefits in patients at higher baseline risk, and do not appear to be restricted to patients with marked dyslipidemia.