# Chapter 3 Results

A total of 2,056 citations identified from literature searches and 39 from reference lists were reviewed, and 303 articles were assessed at the full-text level. After full-text review, we included a total of 23 trials^66,67,73–93^ (N=95,768, reported in 60 publications) and 1 new cohort study^94^ (n=261,032) on harms. Nineteen trials were carried forward from the previous review.^3^ One new placebo-controlled trial of patients with rheumatoid arthritis was added (TRACE-RA).^84^ In addition, primary prevention data were added from two trials (ALLHAT-LLT^80^ and PROSPER^91^) that were previously excluded because more than 10 percent of the study populations had prior cardiovascular disease (CVD) events; we also excluded secondary prevention data from one trial (WOSCOPS^92^) that met inclusion criteria (<10% with prior CVD events) but previously did not report results from the primary prevention population separately. We identified additional data on selected outcomes from JUPITER (in groups stratified by presence of renal dysfunction)^95^ and ASCOT-LLA (stratified by age).^96^ Evidence tables describing the details of included studies and quality ratings for each study are described in Appendix B.

## Key Question 1a What Are the Benefits of Statins in Reducing the Incidence of CVD-Related Morbidity or Mortality or All-Cause Mortality in Asymptomatic Adults Without Prior CVD Events?

### Summary

Based on 22 trials (3 trials added for this report), pooled estimates found statin therapy associated with decreased risk of all-cause mortality (18 trials, N=85,186; relative risk [RR] 0.92, 95% confidence interval [CI], 0.87 to 0.98; I^2^=0%; absolute risk difference [ARD] −0.35%), fatal or nonfatal stroke (15 trials, N=76,610; RR 0.78, 95% CI, 0.68 to 0.90; I^2^=22%; ARD −0.39%), fatal or nonfatal MI (12 trials, N=75,401; RR 0.67, 95% CI, 0.60 to 0.75; I^2^=14%; ARD, −0.85%), revascularization (10 trials, N=65,924; RR 0.71, 95% CI, 0.63 to 0.80; I^2^=15%; ARD, −0.59%); and composite cardiovascular outcomes (15 trials, N=74,390; RR 0.72, 95% CI, 0.64 to 0.81; I^2^=51%; ARD −1.28%). With the addition of new data, the estimate for cardiovascular mortality was attenuated (smaller) compared to the 2016 USPSTF review and no longer statistically significant (12 trials, N=75,138; RR 0.91, 95% CI, 0.81 to 1.02; I^2^=0%; ARD −0.13%).

### Evidence

The prior USPSTF review^3^ included 19 RCTs on statins versus placebo or no statin in adults at increased cardiovascular risk but without prior CVD events (primary prevention). Statin use was associated with reduced risk of all-cause mortality, cardiovascular mortality, fatal or nonfatal stroke, fatal or nonfatal MI, revascularization, and composite cardiovascular outcomes (Table 3).

Table 3 Comparison of Pooled Estimates From Randomized, Controlled Trials of Statins for Primary Prevention From the 2016 and 2022 USPSTF Reviews

Outcome | 2016 USPSTF Review^3^ | 2022 Update
All-cause mortality | 15 trials (n=71,131); RR 0.86 (95% CI, 0.80 to 0.93; I^2^=0%); ARD −0.40% (95% CI, −0.64 to −0.17); NNT 250 | 18 trials (n=85,186); RR 0.92 (95% CI, 0.87 to 0.98; I^2^=0%); ARD −0.35% (95% CI, −0.57 to −0.14); NNT 286
CV mortality | 10 trials (n=64,322); RR 0.82 (95% CI, 0.71 to 0.94); I^2^=0%; −0.20% (95% CI, −0.35 to −0.05); NNT 500 | 12 trials (n=75,138); RR 0.91 (95% CI, 0.81 to 1.02; I^2^=0%); ARD −0.13% (95% CI, −0.25 to −0.02); NNT 769
Stroke | 13 trials (n=62,863); RR 0.71 (95% CI, 0.62 to 0.82; I^2^=0%); ARD −0.38% (95% CI, −0.53 to −0.23); NNT 263 | 15 trials (n=76,610); RR 0.78 (95% CI, 0.68 to 0.90; I^2^=22%); ARD −0.39% (95% CI, −0.54 to −0.25); NNT 256
MI | 12 trials (n=68,506); RR 0.64 (95% CI, 0.57 to 0.71; I^2^=0%); ARD −0.81% (95% CI, −1.19 to −0.43); NNT 123 | 12 trials (n=75,401); RR 0.67 (95% CI, 0.60 to 0.75; I^2^=14%); ARD, −0.85% (95% CI, −1.22 to −0.47); NNT 118
Revascularization | 7 trials (n=54,803); RR 0.63 (95% CI, 0.56 to 0.72; I^2^=0%); ARD −0.66% (95% CI, −0.87 to −0.43); NNT 152 | 10 trials (n=65,924); RR 0.71 (95% CI, 0.63 to 0.80; I^2^=15%); ARD, −0.59% (95% CI, −0.77 to −0.41); NNT 169
Composite CV outcomes | 13 trials (n=69,215); RR 0.70 (95% CI, 0.63 to 0.78; I^2^=36%); ARD −1.39% (95% CI, −1.79 to −0.99); NNT 72 | 15 trials (n=74,390); RR 0.72 (95% CI, 0.64 to 0.81; I^2^=51%); ARD −1.28% (95% CI, −1.61 to −0.95); NNT 78

Abbreviations: ARD=absolute risk difference; CV=cardiovascular; MI=myocardial infarction; NNT=number needed to treat; RR=relative risk.

For this update, 22 RCTs (reported in 55 publications) that assessed effects of statins versus placebo or no statin for primary prevention were included (Table 4; Appendix B1).^66,67,73–82,84–93,96–128^ One new primary prevention trial of patients with rheumatoid arthritis (TRACE-RA, n=3,002) was published subsequent to the 2016 USPSTF review.^84^ WOSCOPS,^125^ a mixed primary and secondary prevention trial that was included in the 2016 USPSTF review (<10% secondary prevention participants) recently published separate efficacy results for the primary prevention population (n=5,529), which replaced previously utilized data from the entire study population (n=6,595). In addition, two mixed primary and secondary prevention trials (ALLHAT-LLT [n=10,355; 8,880 primary prevention]^80^ and PROSPER [n=5,804; 3,239 primary prevention]^91,124^) that were excluded in the prior USPSTF review because they exceeded the 10 percent threshold of secondary prevention participants were added because separate data for primary prevention participants were available.

Table 4 Study Characteristics of Randomized Trials of Statins vs. Placebo or No Statin

Study name Author, year; Quality | Inclusion criteria | Duration of followup | Statin intensity | Intervention and comparator (N) | Mean age | Sex (% female) | Race/ethnicity (%) | Mean baseline LDL-C | Mean baseline HDL-C | Mean baseline TC | Mean baseline TG | Risk factors
ACAPS; Furberg, 1994^81^; Fair | Ages 40 to 79 years; Early-onset carotid atherosclerosis; LDL-C 160 to 189 mg/dL with ≤1 risk factor, 130 to 159 mg/dL with >1 risk factor at baseline, or TG ≤400 mg/dL after intensive dietary treatment | 3 years | Low (20 mg) and moderate (40 mg) | Lovastatin 20 mg/day, titrated to 40 mg/day for target LDL-C of 90 to 110 mg/dL (n=460); Placebo (n=459) | 62 years | 50% | White: 93%; Other race/ethnicity: NR | 156 mg/dL | 52 mg/dL | 235 mg/dL | 138 mg/dL | Diabetes: 2%; Smoking: 12%; Hypertension: 31%; Mean BMI men: 25.9 kg/m^2^; Mean BMI women: 25.7 kg/m^2^
AFCAPS/TexCAPS; Downs, 1998^79^; Fair | Ages 45 to 73 years (men) or 55 to 73 years (women); TC 180 to 264 mg/dL; LDL-C 130 to 190 mg/dL; HDL-C ≤45 mg/dL (men) or ≤47 mg/dL (women); TG ≤400 mg/dL; Also included patients with LDL-C 125 to 129 mg/dL if TC-to-HDL-C ratio >6.0 | 5 years | Low (20 mg) and moderate (40 m) | Lovastatin 20 mg/day, titrated to 20 to 40 mg/day for target LDL-C of ≤110 mg/dL (n=3304); Placebo (n=3301) | 58 years | 15% | White: 89%; Other race/ethnicity: NR | 150 mg/dL | 36 mg/dL | 221 mg/dL | 158 mg/dL | Diabetes: 3%; Smoking: 12.5%; Mean SBP: 138 mm Hg; Mean DBP: 78 mm Hg; Mean BMI men: 27 kg/m^2^; Mean BMI women: 26 kg/m^2^; Daily aspirin use: 17%; 1998 Joint Task Force (European) 10-year risk:; Very high (>40%): 0.04%; High (20 to 40%): 20%; Moderate (10 to 20%): 80%; Low or mild (<10%): 0.07%
ALLHAT-LLT; Furberg, 2002^80^; Fair | Age ≥55 years with stage 1 or 2 hypertension and at least 1 additional CHD risk factor; Excluded: use of lipid-lowering therapy, intolerant of statins, significant liver or kidney disease, secondary cause of dyslipidemia | 6 years | Moderate | Pravastatin 40 mg/day (total: n=5170; primary prevention only: n=4475); Usual care (total: n=5185; primary prevention only: n=4405) | 71 years | 49% | White, non-Hispanic: 41%; Black, non-Hispanic: 33%; White, Hispanic: 15%; Black, Hispanic: 4%; Other race/ethnicity: 6% | 129 mg/dL | 48 mg/dL | 205 mg/dL | 151 mg/dL | History of CHD: 14%; Hypertension: 90%; Diabetes: 35%; Smoking: 23%; Mean BMI: 29.9 kg/m2; Mean SBP: 145 mm Hg; Mean DBP: 84 mm Hg
ASCOT-LLA; Sever, 2003^90^; Fair | Ages 40 to 79 years Untreated or treated hypertension; TC ≤251 mg/dL; No current fibrate or stain use; ≥3 CVD risk factors TG <399 mg/dL | 3 years | Moderate | Atorvastatin 10 mg/day (n=5168); Placebo (n=5137) | 63 years | 19% | White: 95%; Other race/ethnicity: NR | 131 mg/dL | 50 mg/dL | 212 mg/dL | 147 mg/dL | LVH: 14%; Other ECG abnormalities: 14%; PVD: 5%; Other CVD: 4%; Diabetes: 25%; Smoking: 33%; Mean BMI: 28.6 kg/m^2^; History of stroke or TIA: 10%; Mean number of risk factors: 4
ASPEN; Knopp, 2006^85^; Fair | Ages 40 to 75 years; Diabetes; LDL-C <160 mg/dL | 4 years^*^ | Moderate | Atorvastatin 10 mg/day (n=959^*^); Placebo (n=946^*^) | 60 years | 38% | White: 84%; Black: 6%; Other race/ethnicity: NR | 114 mg/dL | 48 mg/dL | 195 mg/dL | 145 mg/dL | Diabetes: 100% (duration, 8 years); Smoking: 13%; Mean SBP: 133 mm Hg; Mean DBP: 77 mm Hg; Mean BMI: 29 kg/m^2^
ASTRONOMER; Chan, 2010^67^; Good | Ages 18 to 82 years; Asymptomatic mild or moderate aortic stenosis (aortic valve velocity, 2.5 to 4.0 m/s); No clinical indications for statin use (CAD, cerebrovascular disease, PVD, diabetes); Lipids within target levels for respective risk categories according to Canadian guidelines | 4 years | High | Rosuvastatin 40 mg/day (n=136); Placebo (n=135) | 58 years | 38% | White: 99%; Other race/ethnicity: NR | 122 mg/dL | 62 mg/dL | 205 mg/dL | 111 mg/dL | Smoking: 11%; Mean BP: 129/71 mm Hg; Mean BMI: 28 kg/m^2^
Beishuizen, 2004^75^; Fair | Ages 30 to 80 years; Type 2 diabetes (duration ≥1 year); No history of CVD; TC 155 to 267 mg/dL; TG ≤531 mg/dL | 2 years | Moderate | Cerivastatin 0.4 mg/day; after mean of 15 months, switched to simvastatin 20 mg/day (n=125); Placebo (n=125) | 59 years | 53% | White: 68%; Asian: 19%; Other: 13% | 135 mg/dL | 48 mg/dL | 215 mg/dL | 164 mg/dL | Diabetes: 100%; Current smoker: 24%; Hypertension: 51%; Mean BMI: 31.0 kg/m^2^
Bone, 2007^76^; Fair | Women ages 40 to 75 years; LDL-C ≥130 to <190 mg/dL; No history of diabetes or CHD; Criteria modified during trial to women with LDL-C ≥160 mg/dL and ≥2 CVD risk factors | 1 year | Moderate (10 to 20 mg) and high (40 to 80 mg) | Atorvastatin 10 mg/day (n=118); Atorvastatin 20 mg/day (n=121); Atorvastatin 40 mg/day (n=124); Atorvastatin 80 mg/day (n=122); Placebo (n=119) | 59 years | 100% overall | White: 88%; Other race/ethnicity: NR | 157 mg/dL | 54 mg/dL | 243 mg/dL | 141 mg/dL | Current or former smoker: 47%
CAIUS; Mercuri, 1996^86^; Fair | Age 45 to 65 years with elevated LDL and no symptomatic coronary artery disease and at least one carotid artery lesion. | 3 years | Moderate | Pravastatin 40 mg/day (n=151); Placebo (n=154) | 55 years | 47% | NR | 181 mg/dL | 53 mg/dL | 262 mg/dL | 138 mg/dL | Smoking: 24%; Mean SBP: 134 mm Hg; Mean DBP: 82 mm Hg; Mean BMI: 25 kg/m2; Family history of CVD: 45%
CARDS; Colhoun, 2004^77^; Good | Ages 40 to 75 years; Diabetes and ≥1 additional risk factor for CHD; No previous CVD events; BMI <35 kg/m^2^; HbA1c <12%; SBP <200 mm Hg; DBP <110 mm Hg; Not receiving any other lipid-lowering medication; LDL-C ≤160 mg/dL; TG ≤600 mg/dL | 4 years | Moderate | Atorvastatin 10 mg/day (n=1428); Placebo (n=1410) | 62 years | 32% | White: 95%; Other race/ethnicity: NR | 118 mg/dL | 55 mg/dL | 207 mg/dL | Median, 150 mg/dL | Diabetes: 100% (mean duration, 8 years); Smoking: 23%; Mean SBP: 144 mm Hg; Mean DBP: 83 mm Hg; Mean BMI: 29 kg/m^2^
Heljić, 2009^82^; Fair | Obese patients with diabetes; No preexisting CHD; TG ≤266 mg/dL; States LDL-C used as entry criterion but values NR | 1 year | Moderate | Simvastatin 40 mg/day (n=45); Placebo (n=50) | 61 years | 58% | NR | 170 mg/dL | 41 mg/dL | 239 mg/dL | 217 mg/dL | Mean BP: <140/90 mm Hg; Mean BMI: 31.6 kg/m^2^
HOPE-3; Yusuf, 2016^93^; Good | Men age ≥55 years and women age ≥65 years with ≥1 CV risk factors (including elevated waist-to-hip ratio, low HDL-C, current or recent tobacco use, dysglycemia, family history of premature CHD, or mild renal dysfunction) or women age ≥60 years with ≥2 CV risk factors | 6 years | Moderate | Rosuvastatin 10 mg/day (n=6361); Placebo (n=6344) | 66 years | 46% | Chinese: 29%; Hispanic: 28%; Asian: 21%; White: 20%; Black: 2%; Other: 2% | 128 mg/dL | 45 mg/dL | 201 mg/dL | 128 mg/dL | Diabetes: 6%; IGF or IGT: 13%; Smoking: 28%; Mean SBP: 138 mm Hg; Mean DBP: 82 mm Hg; Hypertension: 38%; Mean BMI: 27 kg/m^2^; Family history of early-onset CHD: 26%; Early-onset renal dysfunction: 3%; Elevated waist-to-hip ratio: 87%; Low HDL-C: 36%; INTERHEART risk score ≤12: 37%; INTERHEART risk score 13-16: 30%; INTERHEART risk score >16: 33%
HYRIM; Anderssen, 2005^73^; Fair | Men ages 40 to 74 years; Receiving drug treatment for hypertension; TC 174 to 309 mg/dL; TG <399 mg/dL; BMI 25 to 35 kg/m^2^ <1 hour/week of regular exercise | 4 years | Low | Fluvastatin 40 mg/day (n=142); Fluvastatin 40 mg/day + lifestyle intervention (physical activity plus dietary intervention) (n=141); Placebo (n=143); Placebo + lifestyle intervention (n=142) | 57 years | 0% | NR | 150 mg/dL | 49 mg/dL | 230 mg/dL | 158 mg/dL | Smoking: 16%; Mean SBP: 141 mm Hg; Mean DBP: 88 mm Hg; Mean BMI: 29 kg/m^2^
JUPITER; Ridker, 2008^66^; Good | Men age ≥50 years or women age ≥60 years; No history of CVD; LDL-C <130 mg/dL; CRP ≥2.0 mg/L; TG <500 mg/dL | 2 years | High | Rosuvastatin 20 mg/day (n=8901); Placebo (n=8901) | Median 66 years in each arm | 39% | White: 71%; Black: 13%; Hispanic: 13%; Other: 4% | Median 108 mg/dL in each arm | Median 49 mg/dL in each arm | Median 186 mg/dL in inter-vention arm; median 185 mg/dL in placebo arm | Median 118 mg/dL in each arm | Median HbA1c: 5.7% in each arm; Smoking: 16%; Median BP: 134/80 mm Hg in each arm; Median BMI: 28 kg/m^2^ in each arm; Median CRP: 4.2 mg/L in intervention arm; 4.3 mg/L in placebo arm; Family history of CHD: 12%; Metabolic syndrome: 42%; Daily aspirin use: 17%; Framingham risk score ≤10%: 50%; Framingham risk score >10%: 50%
KAPS; Salonen, 1995^89^; Good | Men age 42, 48, 54, or 60 years; LDL-C ≥164 mg/dL; TC <308 mg/dL; BMI <32 kg/m^2^; ALT <1.5 ULN | 3 years | Moderate | Pravastatin 40 mg/day (n=224); Placebo (n=223) | 58 years | 0% | NR | 189 mg/dL | 46 mg/dL | 259 mg/dL | 151 mg/dL | Prior MI: 7.5%; Diabetes: 2.5%; Smoking: 27%; Hypertension: 33%
MEGA; Nakamura, 2006^88^; Fair | Ages 40 to 70 years; TC 220 to 270 mg/dL; No history of CHD or stroke | 5 years | Low | Intensive lipid control with diet + pravastatin 10 mg/day, titrated to 20 mg/day for target TC of <220 mg/dL (n=3866); Standard lipid control with diet only (n=3966) | 58 years | 69% | NR | 157 mg/dL | 58 mg/dL | 242 mg/dL | 128 mg/dL | Diabetes: 21%; Smoking: 21%; Hypertension: 42%; Mean BMI: 24 kg/m^2^
METEOR; Crouse, 2007^78^; Fair | Men ages 45 to 70 years or women ages 55 to 70 years; LDL-C 120 to <190 mg/dL if age only risk factor or LDL-C 120 to <160 mg/dL if ≥2 CHD risk factors and 10-year; CHD risk <10%; HDL-C ≤60 mg/dL; TG <500 mg/dL; Maximum CIMT 1.2 to <3.5 mm | 2 years | High | Rosuvastatin 40 mg/day (n=702); Placebo (n=282) | 57 years | 40% | White: 60%; Other race/ethnicity: NR | 155 mg/dL | 50 mg/dL | 229 mg/dL | 128 mg/dL | Smoking: 3.9%; Hypertension: 20%; BMI >30 kg/m^2^: 20%; Family history of CHD: 9.6%; Metabolic syndrome: 15%; ≥2 risk factors: 34%
Muldoon, 2004^87^; Fair | Generally healthy men and women ages 35 to 70 years; LDL-C 160 and 220 mg/dL | 6 months | Low (10 mg) and moderate (40 mg) | Simvastatin 40 mg/day (n=103); Simvastatin 10 mg/day (n=103); Placebo (n=102) | 54 years | 52% | White: 86%; Other race/ethnicity: NR | 181 mg/dL | 51 mg/dL | 263 mg/dL | 151 mg/dL | NR
PREVEND-IT; Asselbergs, 2004^74^; Fair | Ages 28 to 75 years; Persistent microalbuminuria (urine albumin >10 mg/L in 1 early-morning spot sample and 15 to 300 mg in two 24-hour samples); BP <160/100 mm Hg and no antihypertensive medication; TC <309 mg/dL or <193 mg/dL if previous MI; No lipid-lowering medications | 4 years | Moderate | Pravastatin 40 mg/day (n=433); Placebo (n=431) | 52 years | 35% | White: 96%; Other race/ethnicity: NR | 157 mg/dL | 39 mg/dL | 224 mg/dL | 120 mg/dL | Prior CVD event: 3% (MI, 0.4%); Diabetes: 3%; Smoking: 40%; Mean SBP: 131 mm Hg; Mean DBP: 77 mm Hg; Mean BMI: 26 kg/m^2^; Use of aspirin and antiplatelet agents: 2.5%
PROSPER; Shepherd, 2002^91^; Good | Age 70 to 82 years with elevated risk of vascular disease due to smoking, hypertension or diabetes | 3 years | Moderate | Pravastatin 40 mg/day (n=1585); Placebo (n=1654) | 75 years | 58% | NR | 146 mg/dL | 51 mg/dL | 220 mg/dL | 135 mg/dL | Smoking (current): 33%; Mean SBP: 157 mm Hg; Mean DBP: 85 mm Hg; Hypertension: 72%; Diabetes: 12%
TRACE-RA; Kitas, 2019^84^; Fair | Age >50 years with RA diagnosis according to ACR 1987 criteria or RA disease duration >10 years; Excluded: known CVD requiring statins, DM, myopathy | 2 years | High | Atorvastatin 40 mg/day (n=1504); Placebo (n=1498) | 61 years | 75% | 98% white; 0.5% Asian/Asian British; 0.6% Black/Black British; 0.8% other mixed race | 124 mg/dL | 59 mg/dL | 209 mg/dL | 113 mg/dL | Smoking (current): 17%^*^; Mean SBP: 135 mm Hg; Mean DBP: 79 mm Hg; Hypertension: 23%^*^
WOSCOPS; Shepherd, 1995^125^; Good | Men ages 45 to 64 years; At risk for CAD; TC >251 mg/dL; LDL-C >155 mg/dL with ≥1 value within 173 to 232 mg/dL; No significant CAD | 5 years | Moderate | Pravastatin 40 mg/day (n=3302); Placebo (n=3293) | 55 years | 0% | NR | 192 mg/dL | 44 mg/dL | 272 mg/dL | 163 mg/dL | Smoking: 44%; Mean SBP: 136 mm Hg; Mean DBP: 84 mm Hg; Mean BMI 26kg/m^2^

Abbreviations: ACAPS=Asymptomatic Carotid Artery Progression Study; ACR=American College of Radiologists; AFCAPS/TexCAPS=Air Force/Texas Coronary Atherosclerosis Prevention Study; ALLHAT-LLT=Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial–Lipid-Lowering Trial; ALT= alanine aminotransferase; ASCOT-LLA=Anglo-Scandinavian Cardiac Outcomes Trial–Lipid Lowering Arm; ASPEN=Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in Non-insulin Dependent Diabetes Mellitus; ASTRONOMER=Aortic Stenosis Progression Observation: Measuring Effects of Rosuvastatin; BMI=body mass index; BP=blood pressure; CAD=coronary artery disease; CAIUS=Carotid Atherosclerosis Italian Ultrasound Study; CARDS=Collaborative Atorvastatin Diabetes Study; CHD=coronary heart disease; CIMT=carotid intima-media thickness test; CRP=C-reactive protein; CV=cardiovascular; CVD=cardiovascular disease; DBP=diastolic blood pressure; DM=diabetes mellitus; ECG=electrocardiogram; HDL-C=high-density lipoprotein-cholesterol; HOPE-3= Heart Outcomes Prevention Evaluation; HYRIM=Hypertension High Risk Management; IGF=insulin-like growth factor; IGT=impaired glucose tolerance; JUPITER=Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; KAPS=Kuopio Atherosclerosis Prevention Study; LDL-C=low-density lipoprotein-cholesterol; MEGA=Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese; METEOR=Measuring Effects on Intima-Media Thickness: an Evaluation of Rosuvastatin; MI=myocardial infarction; n=sample size; NR=not reported; PREVEND-IT=Prevention of Renal and Vascular Endstage Disease Intervention Trial; PROSPER= Prospective Study of Pravastatin in the Elderly at Risk; PVD= peripheral vascular disease; RA=rheumatoid arthritis; SBP=systolic blood pressure; TC=total cholesterol; TG=triglyceride; TIA=transient ischemic attack; TRACE-RA=Trial of Atorvastatin for the Primary Prevention of Cardiovascular Events in Patients with Rheumatoid Arthritis; ULN=upper limit of normal; WOSCOPS=West of Scotland Coronary Prevention Study Group.

* Duration of followup for ASPEN is for all patients (primary and secondary population); followup was shorter for the primary prevention population due to later recruitment, but not reported separately.

Most trials were conducted in the United States or Canada (6 trials^67,76,79–81,87^) and Europe (11 trials^73–75,77,82,84,86,89–92^). One trial^88^ was conducted in Japan, and four^66,78,85,93^ trials were multinational. The number of participants ranged from 95 to 17,802 (mean 4,119; N=90,624). Mean age ranged from 52 to 66 years in all trials except for one: PROSPER,^91^ which restricted enrollment to persons 70 to 82 years of age (mean 75 years). Ten trials restricted enrollment to persons ≤75 years of age; three trials^66,80,93^ had no upper age limit. Three trials enrolled only males,^73,89,92^ and one trial enrolled only females.^76^ In 18 other trials, females were 15 to 75 percent of the population. In 15 trials that reported race and/or ethnicity, White persons were the most common group in 14 trials (41 to 99 percent).^66,67,74–81,84,85,87,90^ The proportion of Black participants, reported in five trials, ranged from less than one percent to 37 percent;^66,80,84,85,93^ data for other races/ethnicities were limited to one or two trials. One trial (MEGA)^88^ did not report race or ethnicity but was conducted in Japan. The multinational HOPE-3 trial, conducted in 21 countries, was the only trial in which White participants were not the largest group (29% Chinese, 15% South Asian, 21% other Asian, 28% Hispanic, 20% White, 2% Black, 2% other race).^93^ Across all trials, mean LDL-C ranged from 108 to 191 mg/dL, HDL-C ranged from 36 to 62 mg/dL, total cholesterol ranged from 195 to 271 mg/dL, triglycerides ranged from 111 to 217 md/dL, SBP ranged from 129 to 157 mm Hg and DBP ranged from 71 to 88 mm Hg. The proportion of participants with a history of smoking ranged from four to 47 percent.

Criteria for enrollment varied across trials (Table 4; Appendix B1); however, all trials enrolled persons with cardiovascular risk factors at baseline. In six trials, presence of dyslipidemia (variably defined) was the main criterion for enrollment.^76,79,87–89,92^ In these trials, mean baseline LDL-C levels ranged from 150 to 191 mg/dL and HDL-C levels ranged from 36 to 62 mg/dL. Four trials restricted enrolled to persons with diabetes;^75,77,82,85^ of these, three trials excluded persons with diabetes with severe dyslipidemia (LDL-C <160 mg/dL or TC level of 155 to 267 mg/dL required for inclusion). Two trials restricted enrollment to persons with hypertension,^73,80^ three trials required presence of early asymptomatic carotid atherosclerosis,^78,81,86^ and one trial each focused on patients with aortic stenosis,^67^ microalbuminuria,^74^ or rheumatoid arthritis.^84^ Three trials^66,90,91^ required presence of multiple cardiovascular risk factors (including dyslipidemia, elevated CRP, elevated blood pressure, family history, mild renal dysfunction, smoking status or elevated cardiovascular risk score) and one trial (HOPE-3)^93^ enrolled patients with at least one cardiovascular risk factor (elevated waist-to-hip ratio, low HDL-C, current or recent tobacco use, dysglycemia, family history of premature CHD, or mild renal dysfunction).

Two mixed primary and secondary prevention trials (ASCOT-LLA and PREVEND-IT)^74,90^ met inclusion criteria because fewer than 10 percent of participants had prior CVD events.

The statins evaluated in the trials were pravastatin (7 trials^74,80,86,88,89,91,92^), atorvastatin (5 trials^76,77,84,85,90^), rosuvastatin (4 trials^66,67,78,93^), simvastatin (3 trials),^75,82,87^ lovastatin (2 trials^79,81^) and fluvastatin (1 trial^73^). Cerivastatin was initially used in one trial but later replaced with simvastatin when cerivastatin was withdrawn from the market due to reports of fatal rhabdomyolysis.^129^ No trial evaluated pitavastatin. Among 17 studies that utilized fixed-dose statins, dose intensity was high in 4 trials,^66,67,78,84^ moderate in 12 trials,^74,75,77,80,82,85,86,89–93^ and low in 1 trial,^73^ according to ACC/AHA criteria (see Table 1). Two other trials that used fixed-dosing randomized patients to one of four doses of atorvastatin, ranging from 10 mg/day (moderate intensity) to 80 mg/day (high intensity)^76^ or simvastatin 10 mg/day (low intensity) to 40 mg/day (moderate intensity).^87^ Three trials performed dose titration based on target LDL-C or total cholesterol levels. In two trials^79,81^ lovastatin was titrated from 20 to 40 mg/day (low to moderate intensity) and in one trial^88^ pravastatin was titrated from 10 to 20 mg/day (low intensity). Two trials^73,88^ included diet or lifestyle interventions in the statin arms. Nineteen trials compared a statin versus placebo, one trial^80^ compared statin therapy versus usual care (which could include cholesterol-lowering therapy), and one trial^88^ compared a statin plus a cholesterol-lowering diet versus diet alone. Five trials used a two-by-two factorial design in addition to randomization to statin therapy versus placebo, patients were also randomized to treatment with warfarin versus placebo,^81^ different antihypertensive regimens,^90,109^ lifestyle interventions versus usual care,^119^ or fosinopril versus placebo.^74^

The duration of followup was one to six years (mean 3.3 years) in all trials except for one,^87^ which followed patients for 6 months. Three trials with planned 5-year followup (ASCOT-LLA^90^, JUPITER^66^ and TRACE-RA^84^) were stopped early. ASCOT-LLA and JUPITER were stopped after three and two years, respectively, due to interim analyses indicating cardiovascular benefits among patients randomized to statins. TRACE-RA, which enrolled patients with rheumatoid arthritis, was stopped after two years due to low cardiovascular event rates (0.7% per year versus the expected 1.6% per year). One other trial, CARDS, had a planned four-year followup but was stopped after two years due to observed cardiovascular benefits.^77^ However, median duration of followup in CARDS was close to the planned followup (3.9 years, IQR 3.0 to 4.7 years). Methods for assessing and reporting adherence to statin therapy varied (Appendix A8); in the five largest trials (ALLHAT-LLT, ASCOT-LLA, HOPE-3, JUPITER, and WOSCOPS),^66,81,90,93,125^ the proportion of patients randomized to statin therapy who remained on statin therapy at the end of the trial ranged from 70 percent to 87 percent.

Seven trials^66,67,77,89,91–93^ were rated good-quality and 15 trials^73–76,78–82,84–88,90^ fair-quality (Appendix B3). Methodological limitations in the fair-quality trials included unclear randomization or allocation concealment methods and open-label design or unclear blinding of outcome assessors, care providers, and/or study participants. Only three trials^80,84,87^ did not report any industry funding; the remaining trials were either fully or partially industry-funded.

Results of individual trials of statins versus placebo or no statin are shown in Table 5. All-cause mortality was reported in 18 trials, cardiovascular mortality in 12 trials, stroke in 15 trials, myocardial infarction in 12 trials, revascularization in 10 trials and composite cardiovascular outcomes (variably defined) in 15 trials.

Table 5 Clinical Outcomes and Pooled Risk Estimates From Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Study name; Author, Year^*^; Followup; Quality | All-Cause Mortality | CV Mortality | Stroke | MI | Revascularization | Composite CV Outcomes
ACAPS; Furberg, 1994^81^; 3 years; Fair | 0.2% (1/460) vs. 1.7% (8/459); RR 0.12 (95% CI, 0.02 to 0.99); ARD −1.53% (95% CI, −2.80 to −0.25); NNT 65 | 0% (0/460) vs. 1.3% (6/459); RR 0.08 (95% CI, 0.004 to 1.36); ARD −1.31% (95% CI, −2.43 to −0.19); NNT 76 | Fatal and nonfatal stroke:; 0% (0/460) vs. 1.1% (5/459); RR 0.09 (95% CI, 0.01 to 1.64); ARD, −1.09% (95% CI −2.13 to −0.05); NNT 92 | Nonfatal MI:; 1.1% (5/460) vs. 1.1% (5/459); RR 1.00 (95% CI, 0.29 to 3.42); ARD 0% (95% CI, −1.34 to 1.34); NNT not estimable | NR | Major CV event:; 1.1% (5/460) vs. 3.1% (14/459); RR 0.36 (95% CI, 0.13 to 0.98); ARD −1.96 (95% CI, −3.80 to −0.13); NNT, 51
AFCAPS/TexCAPS; Downs, 1998^79^; 5 years; Fair | 2.4% (80/3304) vs. 2.3% (77/3301); RR 1.04 (95% CI, 0.76 to 1.41); ARD 0.09% (95% CI, −0.64 to 0.82); NNH 1111 | 0.5% (17/3304) vs. 0.8% (25/3301); RR 0.68 (95% CI, 0.37 to 1.26); ARD −0.24% (95% CI, −0.63 to 0.14); NNT 417 | NR | Fatal and nonfatal MI:; 1.7% (57/3304) vs. 2.9% (95/3301); RR 0.60 (95% CI, 0.43 to 0.83); ARD, −1.15% (95% CI, −1.88 to −0.43); NNT 87 | 3.2% (106/3304) vs. 4.8% (157/3301); RR 0.67 (95% CI, 0.53 to 0.86); ARD −1.55% (95% CI, −2.49 to −0.61); NNT 65 | Major coronary event:; 3.5% (116/3304) vs. 5.5% (183/3301); RR 0.63 (95% CI, 0.50 to 0.80); ARD, −2.03% (95% CI, −3.03 to −1.03); NNT 45
ALLHAT-LLT; Furberg 2002^80^; 6 years; Fair | 12.3% (549/4475) vs. 13.9% (542/4405); RR 1.00 (95% CI, 0.89 to 1.11); ARD −0.04 (95% CI, −1.40 to 1.33); NNH 2500 | 5.6% (252/4475) vs. 5.6% (248/4405); RR 1.00 (95% CI, 0.84 to 1.19); ARD 0.00 (95% CI, −0.96 to 0.96); NNT not calculable | Fatal or nonfatal stroke:; 4.0% (178/4475) vs. 4.3% (189/4405); RR 0.93 (95% CI, 0.76 to 1.13); ARD −0.31 (95% CI, −1.14 to 0.52); NNT 322; Fatal stroke:; 1.1% (50/4475) vs. 1.1% (50/4405); RR 0.98 (95% CI, 0.67 to 1.45); ARD −0.05 (95% CI, −0.14 to 0.04); NNT 2000 | Fatal or nonfatal MI:; 4.0% (180/4475) vs. 4.9% (216/4405); RR 0.82 (95% CI, 0.68 to 1.00); ARD −0.88 (95% CI, −1.74 to −0.02); NNT 114; Fatal MI:; 1.5% (67/4475) vs. 1.5% (65/4405); RR 1.01 (95% CI, 0.72 to 1.42); ARD 0.02 (95% CI, −0.48 to 0.52); NNH 5000; Nonfatal MI:; 2.6% (118/4475) vs. 3.5% (154/4405); RR 0.75 (95% CI, 0.60 to 0.96); ARD −0.86 (95% CI, −1.58 to −0.14); NNT 116 | 5.1% (228/4475) vs. 5.8% (256/4405); RR 0.88 (95% CI, 0.74 to 1.04); ARD −0.72 (95% CI, −1.66 to 0.23); NNT 139 | NR
ASCOT-LLA; Sever, 2003^90^; 3 years; Fair | 3.6% (185/5168) vs. 4.1% (212/5137); HR 0.87 (95% CI, 0.71 to 1.06); RR 0.87 (95% CI, 0.71 to 1.05); ARD −0.55% (95% CI, −1.29 to 0.20); NNT 182 | 1.4% (74/5168) vs. 1.6% (82/5137); HR 0.90 (95% CI, 0.66 to 1.23); RR 0.90 (95% CI, 0.66 to 1.23); ARD −0.16% (95% CI, −0.64 to 0.31); NNT 625 | Fatal and nonfatal stroke:; 1.7% (87/5168) vs. 2.3% (121/5137); HR 0.73 (95% CI, 0.59 to 0.96); RR 0.73 (95% CI, 0.56 to 0.96); ARD −0.63% (95% CI −1.18 to −0.09); NNT 159 | Fatal and nonfatal MI:; 2.2% (114/5168) vs. 3.3% (171/5137); RR 0.66 (95% CI, 0.52 to 0.84); ARD −1.10% (95% CI, −1.73 to −0.47); NNT 91 | NR | Fatal CHD, nonfatal MI, chronic stable angina, unstable angina, or fatal and nonfatal heart failure:; 3.4% (178/5168) vs. 4.8% (247/5137); HR 0.71 (95% CI, 0.59 to 0.86); RR 0.72 (95% CI, 0.59 to 0.87); ARD −1.36% (95% CI, −2.13 to −0.60); NNT, 74
ASPEN; Knopp, 2006^85^; 4 years^†^; Fair | 4.6% (44/959) vs. 4.3% (41/946); RR 1.06 (95% CI, 0.70 to 1.60); ARD 0.25% (95% CI, −1.60 to 2.11); NNH 400 | NR | Fatal and nonfatal stroke:; 2.8% (27/959) vs. 3.1% (29/946); RR 0.92 (95% CI, 0.55 to 1.54); ARD −0.25% (95% CI, −1.77 to 1.27); NNT 400 | Fatal and nonfatal MI:; 2.9% (28/959) vs. 3.6% (34/946); RR 0.81 (95% CI, 0.50 to 1.33); ARD −0.67% (95% CI, −2.27 to 0.92); NNT 149 | NR | CV event:; 10.4% (100/959) vs.10.8% (102/946); HR 0.97 (95% CI, 0.74 to 1.28); RR 0.97 (95% CI, 0.75 to 1.26); ARD −0.35% (95% CI, −3.12 to 2.41); NNT 286
ASTRONOMER; Chan, 2010^67^; 4 years; Good | NR | 1.5% (2/134) vs. 3.7% (5/135); RR 0.40 (95% CI, 0.08 to 2.04); ARD −2.21% (95% CI, −6.00 to −1.58); NNT 45 | Fatal and nonfatal stroke:; 0% (0/134) vs. 0.7% (1/135); RR 0.34 (95% CI, 0.01 to 8.17); ARD −0.74% (95% CI, −2.77 to 1.29); NNT 135 | Fatal and nonfatal MI:; 0% (0/134) vs. 2.2% (3/135); RR 0.14 (95% CI, 0.01 to 2.76); ARD −2.22% (95% CI, −5.07 to 0.63); NNT 45 | NR | NR
Beishuizen, 2004^75^; 2 years; Fair | 2.9% (3/103) vs. 5.1% (4/79); RR 0.58 (95% CI, 0.13 to 2.50); ARD −2.15% (95% CI, −7.79 to 3.67); NNT 47 | NR | NR | NR | NR | Unspecified CV events: ,; 1.9% (2/103) vs. 15.1% (12/79); RR 0.13 (95% CI, 0.03 to 0.55); ARD 13.25% (95% CI −21.60 to −4.90); NNT 8
Bone, 2007^76^; 1 year; Fair | 0% (0/485) vs. 0% (0/119); RR 0.25 (95% CI, 0.005 to 12); ARD 0% (95% CI −1.19 to 1.19); NNT not estimable | NR | NR | NR | NR | NR
CAIUS; Mercuri, 1996^86^; 3 years; Fair | NR | NR | NR | Fatal and nonfatal MI:; 1% (2/151) vs. 1% (2/154); RR 1.02 (95% CI, 0.15 to 7.15); ARD −0.03% (95% CI, −2.53 to 2.58); NNT 3,333; Fatal MI:; 0.6% (1/151) vs. 0% (0/154); RR 3.06 (95% CI, 0.13 to 75); ARD −0.04% (95% CI, −0.20 to 0.12); NNT 2,500; Nonfatal MI:; 0.6% (1/151) vs. 1% (2/154);; RR 0.51 (95% CI, 0.05 to 5.56); ARD −0.47 (95% CI, −0.63 to −0.31); NNT 213 | 2% (3/151) vs. 1% (2/154); RR 1.53 (95% CI, 0.26 to 9.03); ARD −0.59 (95% CI, −0.77 to −0.41); NNT 169 | NR
CARDS; Colhoun, 2004^77^; 4 years; Good | 4.3% (61/1428) vs. 5.8% (82/1410); HR 0.73 (95% CI, 0.52 to 1.01); RR 0.73 (95% CI, 0.53 to 1.01); ARD −1.54% (95% CI, −3.15 to 0.07); NNT 65 | NR | Fatal and nonfatal stroke: ,; 1.5% (21/1428) vs. 2.5% (35/1410); RR 0.59 (95% CI, 0.35 to 1.01); ARD −1.01% (95% CI, −2.04 to 0.01); NNT 99; Fatal stroke:; 0.07% (1/1428) vs. 0.3% (5/1410); RR 0.20 (95% CI, 0.02 to 1.69); ARD −0.28% (95% CI, −0.52 to 0.05); NNT 357; Nonfatal stroke:; 1% (20/1428) vs. 2% (30/1410); RR 0.66 (95% CI, 0.38 to 1.15); ARD −0.73% (95% CI, −1.70 to 0.24); NNT 137 | Fatal and nonfatal MI:; 2.3% (33/1428) vs. 4.3% (61/1410); RR 0.53 (95% CI, 0.35 to 0.81); ARD −2.02% (95% CI, −3.33 to −0.70); NNT 50; Fatal MI:; 0.6% (8/1428) vs. 1.4% (20/1410); RR 0.40 (95% CI, 0.17 to 0.89); ARD, −0.86% (95% CI, −1.59 to −0.13); NNT 116; Nonfatal MI:; 1.8% (25/1428) vs. 2.9% (41/1410); RR 0.60 (95% CI, 0.37 to 0.98); ARD 0.33% (95% CI, −0.59 to 1.25); NNH, 303 | 1.7% (24/1428) vs. 2.4% (34/1410); RR 0.70 (95% CI, 0.42 to 1.17); ARD −0.73% (95% CI, −1.77 to 0.31); NNT 137 | MI, unstable angina, CHD death, or resuscitated cardiac arrest:; 3.6% (51/1428) vs. 5.5% (77/1410); HR 0.64 (95% CI, 0.45 to 0.91); RR 0.65 (95% CI, 0.46 to 0.92); ARD −1.89% (95% CI, −3.42 to −0.36); NNT 53
Heljić, 2009^82^; 1 year; Fair | NR | NR | Fatal and nonfatal stroke:; 8.9% (4/45) vs. 18.0% (9/50); RR 0.49 (95% CI, 0.16 to 1.49); ARD, −9.11% (95% CI, −22.62 to 4.40); NNT 11 | NR | NR | Unspecified coronary event:; 6.7% (3/45) vs. 14.0% (7/50); RR 0.48 (95% CI, 0.13 to 1.73); ARD −7.33% (95% CI, −19.40 to 4.73); NNT 14
HOPE-3; Yusuf, 2016^93^; 6 years; Good | 5.3% (334/6361) vs. 5.6% (357/6344); RR 0.93 (95% CI, 0.81 to 1.08); ARD −0.38% (95% CI, −1.17 to 0.41); NNT 263 | 2.4% (154/6361) vs. 2.7% (171/6344); RR 0.90 (95% CI, 0.72 to 1.11); ARD −0.27% (95% CI, −0.82 to 0.27); NNT 370 | Fatal or nonfatal stroke:; 1.1% (70/6361) vs. 1.6% (99/6344); RR 0.71 (95% CI, 0.52 to 0.96); ARD −0.46% (95% CI, −0.86 to −0.06); NNT 217 | Fatal or nonfatal MI:; 0.7% (45/6361) vs. 1.1% (69/6344); RR 0.65 (95% CI, 0.45 to 0.95); ARD, −0.38% (95% CI, −0.71 to −0.05); NNT 263 | 0.9% (56/6361) vs. 1.3% (82/6344); RR 0.68 (95% CI, 0.49 to 0.96); ARD −0.41% (95% CI, −0.77 to −0.05); NNT 244 | CV mortality, nonfatal MI, or nonfatal stroke:; 3.7% (235/6361) vs. 4.8% (304/6344); RR 0.77 (95% CI, 0.65 to 0.91); ARD −1.10% (95% CI, −1.80 to −0.40); NNT 91
HYRIM; Anderssen, 2005^73^; 4 years; Fair | 1.4% (4/283) vs. 1.8% (5/285); RR 0.81 (95% CI, 0.22 to 2.97); ARD −0.34% (95% CI, −2.39 to 1.71); NNT 294 | NR | NR | NR | NR | MI, sudden death, angina, CVA, TIA, or heart failure:; 3.9% (11/283) vs. 5.3% (15/285); RR 0.74 (95% CI, 0.35 to 1.58); ARD −1.38% (95% CI, −4.81 to 2.06); NNT 72
JUPITER; Ridker, 2008^66^; 2 years; Good | 2.2% (198/8901) vs. 2.8% (247/8901); HR 0.80 (95% CI, 0.67 to 0.97); RR 0.80 (95% CI, 0.67 to 0.96); ARD −0.55% (95% CI, −1.01 to −0.09); NNT 182 | 0.3% (29/8,901) vs. 0.4% (37/8,901); RR 0.78 (95% CI, 0.48 to 1.27); ARD −0.09% (95% CI, −0.27 to 0.09); NNT 1,111 | Fatal or nonfatal stroke: ,; 0.4% (33/8901) vs. 0.7% (64/8901); HR 0.52 (95% CI, 0.34 to 0.79); RR 0.52 (95% CI, 0.34 to 0.78); ARD, −0.35% (95% CI, −0.56 to −0.13); NNT 286; Fatal stroke:; 0.03% (3/8901) vs. 0.06% (6/8901); RR 0.50 (95% CI, 0.13 to 2.00); ARD, −0.03% (95% CI, −0.10 to 0.03); NNT 3333; Nonfatal stroke:; 0.3% (30/8901) vs. 0.7% (58/8901); RR 0.52 (95% CI, 0.33 to 0.80); ARD −0.31% (95% CI −0.52 to −0.11); NNT 323 | Fatal and nonfatal MI:; 0.3% (31/8901) vs. 0.8% (68/8901); HR 0.35 (95% CI, 0.22 to 0.58); RR 0.46 (95% CI, 0.30 to 0.70); ARD −0.43% (95% CI, −0.65 to −0.21); NNT 233; Fatal MI:; 0.1% (9/8901) vs. 0.07% (6/8901); RR 1.50 (95% CI, 0.53 to 4.21); ARD 0.04% (95% CI, −0.20 to 0.13); NNH 2500; Nonfatal MI:; 0.2% (22/8901) vs. 0.7% (62/8901); HR 0.35 (95% CI, 0.22 to 0.58); RR 0.35 (95% CI, 0.22 to 0.58); ARD −0.45% (95% CI, 0.65 to −0.25); NNT 222 | 0.8% (71/8901) vs. 1.5% (131/8901); HR 0.54 (95% CI, 0.41 to 0.72); RR 0.54 (95% CI, 0.41 to 0.72); ARD −0.67% (95% CI, −0.99 to −0.36); NNT 149 | Nonfatal MI, nonfatal CVA, hospitalization for unstable angina, arterial revascularization or CV mortality:; 2% (142/8901) vs. 3% (251/8901); HR 0.56 (95% CI, 0.46 to 0.69); RR 0.57 (95% CI, 0.46 to 0.69); ARD −1.16% (95% CI, −1.59 to −0.72); NNT 86
KAPS; Salonen, 1995^89^; 3 years; Good | 1.4% (3/214) vs. 1.9% (4/212); RR 0.74 (95% CI, 0.17 to 3.28); ARD −0.48% (95% CI −2.90 to 1.93); NNT 208 | 0.9% (2/214) vs. 0.9% (2/212); RR 0.99 (95% CI, 0.14 to 6.97)^‡^; ARD −0.01% (95% CI, −1.84 to 1.82); NNT 1000 | Fatal and nonfatal stroke:; 0.9% (2/214) vs. 1.9% (4/212); RR 0.50 (95% CI, 0.09 to 2.68); ARD −0.95% (95% CI −3.19 to 1.29); NNT 105 | Fatal and nonfatal MI:; 1.4% (3/214) vs. 3.8% (8/212); RR 0.37 (95% CI, 0.10 to 1.38); ARD −2.37% (95% CI, −5.38 to 0.64); NNT 42; Fatal MI:; 0% (0/214) vs. 0.9% (2/212); RR 0.20 (95% CI, 0.01 to 4.14); ARD −0.94% (95% CI, −2.53 to 0.64); NNT 106; Nonfatal MI:; 1.4% (3/214) vs. 2.8% (6/212); RR 0.50 (95% CI, 0.13 to 1.95); ARD −1.43% (95% CI, −4.16 to 1.30); NNT 70 | 1.9% (4/214) vs. 2.4% (5/212); RR 0.79 (95% CI, 0.22 to 2.91); ARD −0.49% (95% CI, −3.22 to 2.24); NNT 204 | NR
MEGA; Nakamura, 2006^88^; 5 years; Fair | 1.4% (55/3866) vs. 2.0% (79/3966); HR 0.72 (95% CI, 0.51 to 1.01); RR 0.71 (95% CI, 0.51 to 1.00); ARD −0.57% (95% CI, −1.14 to 0.00); NNT 175 | 0.3% (11/3866) vs. 0.5% (18/3966); HR 0.63 (95% CI, 0.30 to 1.33); RR 0.63 (95% CI, 0.30 to 1.33); ARD −0.17% (95% CI, −0.44 to 0.10); NNT 588 | Fatal and nonfatal stroke (nonhemorrhagic only):; 0.9% (34/3866) vs. 1.2% (48/3966); RR 0.73 (95% CI, 0.47 to 1.13); ARD, −0.33% (95% CI, −0.78 to 0.12); NNT 303; Fatal and nonfatal stroke (nonhemorrhagic or hemorrhagic):; 1.3% (50/3866) vs.1.6% (62/3966); RR 0.83 (95% CI, 0.57 to 1.20); ARD −0.27% (95% CI, −0.80 to 0.26); NNT 370 | Fatal and nonfatal MI:; 0.5% (18/3866) vs. 0.8% (33/3966); HR 0.52 (95% CI, 0.29 to 0.94); RR 0.53 (95% CI, 0.29 to 0.95); ARD −0.39% (95% CI, −0.74 to −0.04); NNT 256; Fatal MI:; 0.05% (2/3866) vs. 0.07% (3/3966); RR 0.68 (95% CI, 0.11 to 4.09); ARD −0.02% (95% CI, −0.14 to 0.09); NNT 5000; Nonfatal MI:; 0.4% (16/3866) vs. 0.7% (30/3966); RR 0.55 (95% CI, 0.30 to 1.00); ARD −0.34% (95% CI, −0.68 to −0.01); NNT 294 | 1.0% (39/3866) vs. 1.7% (66/3966); HR 0.60 (95% CI, 0.41 to 0.89); RR 0.61 (95% CI, 0.41 to 0.90); ARD −0.66% (95% CI, −1.16 to −0.15); NNT 152 | Fatal and nonfatal MI, cardiac and sudden death, coronary revascularization or angina:; 1.7% (66/3866) vs. 2.5% (101/3966); HR 0.67 (95% CI, 0.40 to 0.91); RR 0.67 (95% CI, 0.49 to 0.91); ARD −0.84% (95% CI, −1.48 to −0.20); NNT 119
METEOR; Crouse, 2007^78^; 2 years; Fair | 0.1% (1/700) vs. 0% (0/281); RR 1.21 (95% CI, 0.05 to 29.54); ARD 0.14% (95% CI, −0.46 to 0.74); NNH 714 | NR | NR | NR | NR | NR
Muldoon, 2004^87^; 6 months; Fair | NR | NR | Nonfatal stroke:; 0.5% (1/206) vs. 0% (0/102); RR 1.49 (95% CI, 0.06 to 36.32); ARD 0.49% (95% CI, −1.29 to 2.26); NNH 204 | NR | NR | NR
PREVEND-IT; Asselbergs, 2004^74^; 4 years; Fair | 3.0% (13/433) vs. 2.8% (12/431); RR 1.08 (95% CI, 0.50 to 2.34); ARD 0.22% (95% CI, −2.02 to 2.45); NNH 455 | 0.9% (4/433) vs. 0.9% (4/431); RR 1.00 (95% CI, 0.25 to 3.95); ARD 0% (95% CI, −1.28 to 1.27); NNT not estimable | Fatal and nonfatal stroke:; 1.6% (7/433) vs. 0.9% (4/431); RR 1.74 (95% CI, 0.51 to 5.91); ARD 0.69% (95% CI, −0.80 to 2.18); NNH 145 | NR | NR | CV mortality or hospitaliza-tion for CV morbidity:; 4.8% (21/433) vs. 5.6% (24/431); RR 0.87 (95% CI, 0.49 to 1.54); ARD −0.72% (95% CI, −3.68 to 2.24); NNT 139
PROSPER – Primary Prevention Population; Shepherd, 2002^91^; 3 years; Good | 8.8% (139/1585) vs. 8.2% (135/1654); RR 1.07 (95% CI, 0.86 to 1.35); ARD 0.61 (95% CI, −1.13 to 2.53); NNH 164 | NR | Fatal or nonfatal stroke:; 3.8% (61/1585) vs. 3.7% (62/1654); RR 1.03 (95% CI, 0.73 to 1.45); ARD 0.10 (95% CI, −1.22 to 1.42); NNH 1000 | NR | NR | CHD mortality, nonfatal MI, fatal or nonfatal stroke:; 11.4% (181/1585) vs. 12.1% (200/1654); RR 0.94 (95% CI, 0.78 to 1.14); ARD −0.67 (95% CI, −2.89 to 1.55); NNT 149
TRACE-RA; Kitas, 2019^84^; 2 years; Fair | 1.7% (25/1504) vs. 1.8% (27/1498); RR 0.89 (95% CI, 0.51 to 1.53); ARD −0.21 (95% CI, −1.13 to 0.72); NNT 476 | 0.3% (4/1504) vs. 0.2% (3/1498); RR 1.33 (95% CI, 0.30 to 5.92); ARD 0.07 (95% CI, −0.28 to 0.41); NNH 1428 | Fatal or nonfatal stroke:; 0.4% (6/1504) vs. 0.8% (12/1498); RR 0.50 (95% CI, 0.19 to 1.32); ARD −0.40 (95% CI, −0.95 to 0.15); NNT 250 | Nonfatal MI:; 0.7% (11/1504) vs. 1.3% (20/1498); RR 0.55 (95% CI, 0.26 to 1.14); ARD −0.60 (95% CI, −1.33 to 0.12); NNT 167 | 0.7% (11/1504) vs. 1.00% (15/1498); RR 0.73 (95% CI, 0.34 to 1.58); ARD −0.27% (95% CI, −0.93 to 0.39); NNT 370 | Nonfatal MI, nonfatal presumed ischemic stroke, transient ischemic attack. any coronary or non-coronary revascularization, or cardiovascular death (excluding cerebral hemorrhage and non-coronary cardiac death):; 1.6% (24/1504) vs. 2.4% (36/1498); RR 0.66 (95% CI, 0.40 to 1.11); ARD −0.81 (95% CI, −1.81 to 0.19); NNT 123
WOSCOPS; Vallejo-Vaz 2017^92^; 5 years; Good | 3% (80/2762) vs. 3% (92/2767); RR 0.87 (95% CI, 0.65 to 1.17); ARD −0.43% (95% CI, −1.34 to 0.49); NNT 233 | 1% (37/2762) vs. 2% (44/2767); RR 0.84 (95% CI, 0.55 to 1.30); ARD −0.25% (−0.88 to 0.38); NNT 400 | Fatal or nonfatal stroke:; 2% (58/2762) vs. 2% (61/2767); RR 0.95 (95% CI, 0.67 to 1.36); ARD −0.10 (95% CI, −0.87 to 0.66); NNT 1000 | Fatal or nonfatal MI; 5.6% (155/2762) vs. 7.6% (211/2767); RR 0.70 (95% CI, 0.58 to 0.84); ARD −2.26 (95% CI, −3.44 to −1.08); NNT 44 | 1% (37/2762) vs. 2% (51/2767); RR 0.73 (95% CI, 0.48 to 1.11); ARD −0.50 (95% CI, −1.16 to 0.16); NNT 200 | CV mortality, nonfatal MI or nonfatal stroke: 7% (183/2762) vs. 9% (240/2767); RR 0.76 (95% CI, 0.63 to 0.92); ARD −2.05% (95% CI, −3.45 to −0.65); NNT 40
Pooled risk estimate | 18 trials (N=85,186); RR 0.92 (95% CI, 0.87 to 0.98; I^2^=0%); ARD −0.35% (95% CI, −0.57 to −0.14); NNT 286 | 12 trials (N=75,138); RR 0.91 (95% CI, 0.81 to 1.02; I^2^=0%); ARD, −0.13% (95% CI, −0.25 to −0.02); NNT 769 | 15 trials (N=76,610); RR 0.78 (95% CI, 0.68 to 0.90; I^2^=22%); ARD, −0.39% (95% CI, −0.54 to −0.25); NNT 256 | 12 trials (N=75,401); RR 0.67 (95% CI, 0.60 to 0.75; I^2^=14%); ARD, −0.85% (95% CI, −1.22 to −0.47); NNT 118 | 10 trials (N=65,924); RR 0.71 (95% CI, 0.63 to 0.80; I^2^=15%); ARD, −0.59% (95% CI, −0.77 to −0.41); NNT 169 | 15 trials (N=74,390); RR 0.72 (95% CI, 0.64 to 0.81; I^2^=51%); ARD −1.28% (95% CI, −1.61 to −0.95); NNT 78

Abbreviations: ACAPS=Asymptomatic Carotid Artery Progression Study; AFCAPS/TexCAPS=Air Force/Texas Coronary Atherosclerosis Prevention Study; ALLHAT-LLT=Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial–Lipid-Lowering Trial; ARD=absolute risk difference; ASCOT-LLA=Anglo-Scandinavian Cardiac Outcomes Trial–Lipid Lowering Arm; ASPEN=Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in Non-insulin Dependent Diabetes Mellitus; ASTRONOMER=Aortic Stenosis Progression Observation: Measuring Effects of Rosuvastatin; CAIUS=Carotid Atherosclerosis Italian Ultrasound Study; CARDS=Collaborative Atorvastatin Diabetes Study; CHD=coronary heart disease; CI=confidence interval; CV=cardiovascular; CVA=cerebrovascular accident; HOPE-3= Heart Outcomes Prevention Evaluation; HR=hazard ratio; HYRIM=Hypertension High Risk Management; JUPITER=Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; KAPS=Kuopio Atherosclerosis Prevention Study; MEGA=Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese; METEOR=Measuring Effects on Intima-Media Thickness: an Evaluation of Rosuvastatin; MI=myocardial infarction; n=sample size; NNT=number needed to treat; NNH=number needed to harm; NR=not reported; PREVEND-IT=Prevention of Renal and Vascular Endstage Disease Intervention Trial; PROSPER= Prospective Study of Pravastatin in the Elderly at Risk; RR=relative risk; TIA=transient ischemic attack; TRACE-RA=Trial of Atorvastatin for the Primary Prevention of Cardiovascular Events in Patients with Rheumatoid Arthritis; WOSCOPS=West of Scotland Coronary Prevention Study Group.

* Primary publication.

† Duration of followup for ASPEN is for all patients (primary and secondary population); followup was shorter for the primary prevention population due to later recruitment, but not reported separately.

‡ Composite of fatal MI and other CV mortality.

#### All-Cause Mortality

Eighteen trials (N=85,186) reported all-cause mortality (Table 5; Appendix B1).^66,73–81,84,85,88–93^ Two trials found statin therapy associated with a statistically significant reduction in risk of all-cause mortality versus placebo. The large (n=17,802) JUPITER trial,^66^ which enrolled patients with elevated CRP levels and LDL-C levels of less than 130 mg/dL, found rosuvastatin 20 mg/day (high intensity) associated with decreased risk of all-cause mortality versus placebo at 2 years (RR 0.80, 95% CI, 0.67 to 0.96; ARD −0.55%, 95% CI, −1.01 to −0.09; NNT 182). The smaller ACAPS trial (n=919), which enrolled persons with early carotid atherosclerosis, found lovastatin 20 to 40 mg/day (low to moderate intensity) associated with decreased risk of all-cause mortality versus placebo at 3 years (RR 0.12, 95% CI, 0.02 to 0.99; ARD −1.09%, 95% CI, −2.13 to −0.05; NNT 92). Pooling results from all trials, statins were associated with decreased risk of all-cause mortality versus placebo or no statin at one to six years (RR 0.92, 95% CI, 0.87 to 0.98; I^2^=0%; ARD −0.35%, 95% CI, −0.57 to −0.14; NNT 286) (Appendix C1; Table 5). The benefit associated with statin therapy was slightly smaller than the pooled estimate from the prior USPSTF review (15 trials, RR 0.86, 95% CI, 0.80 to 0.93, I^2^=0%; ARD −0.40%, 95% CI, −0.64 to −0.17; NNT 250),^3^ primarily due to the addition of primary prevention data from ALLHAT-LLT (RR 1.00, 95% CI, 0.89 to 1.11)^80^ and PROSPER (RR 1.07, 95% CI, 0.86 to 1.35).^91^ As previously described, PROSPER enrolled older participants compared to the other primary prevention trials, which could have resulted in a reduced effect of statin therapy due to competing mortality or decreased effectiveness in this age group for other reasons. ALLHAT-LLT was open-label and reported a small differential between the statin therapy and usual care arms in final LDL-C levels (14.2%), likely related to high loss to followup in the statin therapy arm (22%), high crossover from the usual care arm (29%), or increased use of other (non-statin) therapies to address lipids or cardiovascular risk in the usual care arm. By comparison, the difference between the statin and placebo arms in LDL-C levels was 49.6% in JUPITER,^66^ 26.3% in AFCAPS/TexCAPS,^79^ and 26.5% in HOPE-3.^93^ The estimate for primary prevention participants in WOSCOPS (0.87, 95% CI, 0.65 to 1.17)^92^ was slightly smaller than for the entire (primary or secondary prevention) sample utilized in the prior USPSTF review (RR 0.78, 95% CI, 0.61 to 1.01),^125^ but very close to the overall pooled estimate. The new TRACE-RA trial also reported results (RR 0.89, 95% CI, 0.51 to 1.53) consistent with the pooled estimate.^84^

Results were similar when the analysis was limited to good-quality trials (6 RCTs; RR 0.89, 95% CI, 0.81 to 0.99; I^2^=13%), when two trials^74,90^ that included some secondary prevention participants were excluded (16 RCTs; RR 0.92, 95% CI, 0.86 to 0.99; I^2^=8%) and when trials that enrolled patients with mean or median baseline LDL-C less than 160 mg/dL^89,92^ were excluded (16 RCTs; RR 0.92, 95% CI, 0.85 to 0.99; I^2^=10%). Pooled estimates for all-cause mortality were no longer statistically significant when the analysis excluded trials stopped early^66,77,84,90^ (14 RCTs; RR 0.96, 95% CI, 0.90 to 1.04; I^2^=0%) or excluded trials with less than three years followup^66,75,76,78,84^ (13 trials; RR 0.94, 95% CI, 0.87 to 1.01; I^2^=6%) (Table 6). JUPITER,^66^ the largest primary prevention trial, had the greatest impact on both of these sensitivity analyses; excluding JUPITER alone resulted in non-statistically significant pooled estimates.

Table 6 Sensitivity Analyses for Pooled Estimates of Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Analysis | All-Cause Mortality | CV Mortality | Stroke | Myocardial Infarction | Revascularization | Composite CV Outcomes
All trials
RR (95% CI) | 0.92 (0.87 to 0.98; I^2^=0%) | 0.91 (0.81 to 1.02; I^2^=0%) | 0.78 (0.68 to 0.90; I^2^=22%) | 0.67 (0.60 to 0.75; I^2^=14%) | 0.71 (0.63 to 0.80; I^2^=15%) | 0.72 (0.64 to 0.81; I^2^=51%)
ARD (95% CI) | −0.35 (−0.57 to −0.14) | −0.13 (−0.25 to −0.02) | −0.39 (−0.54 to −0.25) | −0.85 (−1.22 to −0.47) | −0.59 (−0.77 to −0.41) | −1.28 (−1.61 to −0.95)
Number of trials | 18 | 12 | 15 | 12 | 10 | 15
Excluding trials stopped early
RR (95% CI) | 0.96 (0.90 to 1.04; I^2^=0%) | 0.92 (0.80 to 1.04; I^2^=0%) | 0.87 (0.77 to 0.99; I^2^=0%) | 0.73 (0.65 to 0.81; I^2^=0%) | 0.76 (0.67 to 0.86; I^2^=0%) | 0.76 (0.66 to 0.87 I^2^=49%)
ARD (95% CI) | −0.24 (−0.51 to 0.04) | −0.23 (−0.41 to −0.04) | −0.37 (−0.61 to −0.13) | −0.82 (−1.28 to −0.35) | −0.60 (−0.89 to −0.31) | −1.39 (−2.00 to −0.79)
Number of trials | 14 | 9 | 11 | 9 | 7 | 11
Good-quality trials
RR (95% CI) | 0.89 (0.81 to 0.99; I^2^=13) | 0.87 (0.72 to 1.03; I^2^=0%) | 0.75 (0.61 to 0.92; I^2^=34%) | 0.61 (0.50 to 0.75; I^2^=26%) | 0.63 (0.53 to 0.76; I^2^=0%) | 0.74 (0.62 to 0.88; I^2^=71%)
ARD (95% CI) | −0.51 (−0.85 to −0.16) | −0.12 (−0.28 to 0.04) | −0.37 (−0.53 to −0.20) | −1.03 (−1.69 to −0.37) | −0.56 (−0.78 to −0.35) | −1.26 (−1.61 to −0.92)
Number of trials | 6 | 5 | 7 | 6 | 5 | 5
Followup >3 years
RR (95% CI) | 0.94 (0.87 to 1.01; I^2^=6%) | 0.92 (0.82 to 1.03; I^2^=0%) | 0.83 (0.74 to 0.94; I^2^=4%) | 0.70 (0.64 to 0.78; I^2^=0%) | 0.76 (0.67 to 0.85; I^2^=0%) | 0.76 (0.69 to 0.84; I^2^=33%)
ARD (95% CI) | −0.42 (−0.70 to −0.13) | −0.22 (−0.39 to −0.05) | −0.44 (−0.65 to −0.22) | −0.99 (−1.45 to −0.53) | −0.60 (−0.85 to −0.35) | −1.28 (−1.61 to −0.95)
Number of trials | 13 | 10 | 12 | 10 | 7 | 11
Patients with prior CV disease excluded
RR (95% CI) | 0.92 (0.86 to 0.99; I^2^=8%) | 0.91 (0.81 to 1.03; I^2^=0%) | 0.78 (0.67 to 0.91; I^2^=25%) | 0.67 (0.58 to 0.76; I^2^=22%) | 0.71 (0.63 to 0.80; I^2^=15%) | 0.71 (0.62 to 0.82; I^2^=58%)
ARD (95% CI) | −0.34 (−0.57 to −0.11) | −0.13 (−0.25 to −0.01) | −0.39 (−0.54 to −0.23) | −0.80% (−1.18 to −0.41) | −0.59% (−0.77 to −0.41) | −1.30 (−1.70 to −0.90)
Number of trials | 16 | 10 | 13 | 11 | 10 | 13
Baseline mean LDL-C <160 mg/dL
RR (95% CI) | 0.92 (0.85 to 0.99; I^2^=10%) | 0.91 (0.82 to 1.03; I^2^=0%) | 0.77 (0.66 to 0.90; I^2^=31%) | 0.65 (0.56 to 0.75; I^2^=29%) | 0.69 (0.59 to 0.81; I^2^=39%) | 0.72 (0.63 to 0.82; I^2^=57%)
ARD (95% CI) | −0.35 (−0.57 to −0.13) | −0.13 (−0.25 to −0.01) | −0.40 (−0.55 to −0.25) | −0.72 (−1.05 to −0.39) | −0.61 (−0.84 to −0.39) | −1.23 (−1.57 to −0.90)
Number of trials | 16 | 10 | 12 | 9 | 7 | 13

Abbreviations: ARD=absolute risk difference; CI=confidence interval; CV=cardiovascular; LDL-C=low-density lipoprotein cholesterol; RR=relative risk.

#### Cardiovascular Mortality

Twelve trials (N=75,138) reported cardiovascular mortality (Table 5; Appendix B1).^66,67,74,79–81,84,88–90,92,93^ Only the WOSCOPS trial (n=6,595) reported a statistically significant difference between statin (pravastatin 40 mg/day; moderate intensity) versus placebo in risk of cardiovascular mortality (RR 0.68 at 6 years, 95% CI, 0.48 to 0.98; ARD −0.70%, 95% CI, −1.36 to −0.05; NNT 143).^125^ In the other trials, RR estimates for statin therapy versus placebo or no statin and cardiovascular mortality ranged from 0.08 to 1.33 without statistically significant differences. When all trials were pooled, statin therapy was associated with a slight reduction in cardiovascular mortality risk at two to six years that was not statistically significant (RR 0.91, 95% CI, 0.81 to 1.02; I^2^=0%; ARD −0.13%, 95% CI, −0.25 to −0.02; NNT 769) (Appendix C2). This differs from the prior USPSTF review, which reported a larger, statistically significant reduction in cardiovascular mortality risk (10 trials, RR 0.82, 95% CI, 0.71 to 0.94; I^2^=0%; ARD −0.20%, 95% CI, −0.35 to −0.05; NNT 500). The difference was primarily due to the addition of primary prevention data from ALLHAT-LLT (RR 1.00, 95% CI, 0.84 to 1.19).^80^ Without ALLHAT-LLT, the pooled estimate (RR 0.85, 95% CI, 0.73 to 0.98, I^2^=0%; ARD −0.13%, 95% CI, −0.25 to −0.02; NNT 769) was very similar to the prior USPSTF review. Results from WOSCOPS primary prevention participants were very similar to the prior pooled estimate (RR 0.84, 95% CI, 0.55 to 1.30)^92^ and the new TRACE-RA trial reported a very imprecise estimate (RR 1.33, 95% CI, 0.30 to 5.92).^84^ PROSPER did not report cardiovascular mortality in primary prevention participants and did not contribute to the meta-analysis.

Including ALLHAT-LLT, pooled results were similar when the analysis excluded trials that were stopped early^66,84,90^ (9 RCTs; RR 0.92, 95% CI, 0.80 to 1.04; I^2^=0%) or excluded trials that included some secondary prevention participants^74,90^ (10 RCTs; RR 0.91, 95% CI, 0.81 to 1.03; I^2^=0%). Results were also similar when the analysis was limited to good-quality trials^66,67,89,92,93^ (5 RCTs; RR 0.87, 95% CI, 0.72 to 1.03; I^2^=0%), trials with more than three years followup^67,74,79–81,88–90,92,93^ (10 RCTs; RR 0.92, 95% CI, 0.82 to 1.03; I^2^=0%) and trials that enrolled participants with mean or median baseline LDL-C <160 mg/dL^66,67,74,79–81,84,88,90,93^ (10 RCTs; RR 0.91, 95% CI, 0.82 to 1.03; I^2^=0%) (Table 6).

#### Stroke

Fifteen trials (N=76,610) reported fatal or nonfatal stroke (Table 5; Appendix B1).^66,67,74,77,80–82,84,85,88–93^ Thirteen trials found statin therapy associated with reduced risk of stroke versus placebo or no statin, although some estimates were imprecise due to low event rates. Differences were statistically significant in three trials: ASCOT-LLA (n=10,305)^90^, RR 0.73, 95% 0.56 to 0.96; ARD, −0.63% (95% CI, −1.18 to −0.09; NNT 159 at 3 years); HOPE-3 (n=12,705)^93^ (n=12,705), RR 0.71, 95% CI, 0.52 to 0.96; ARD −0.46%, 95% CI, −0.86 to −0.06; NNT 217 at 6 years; and JUPITER (n=17,802)^66^, RR 0.52, 95% CI, 0.34 to 0.78; ARD, −0.35%, 95% CI, −0.56 to −0.13; NNT 286 at 2 years). When all trials were pooled, statin use was associated in significantly reduced risk of fatal or nonfatal stroke at 1 to 6 years (RR 0.78, 95% CI, 0.68 to 0.90; I^2^=22%; ARD −0.39%, 95% CI, −0.54 to −0.25; NNT 256) (Appendix C3; Table 5). The pooled estimate was similar to the pooled estimate in the prior USPSTF review (13 trials, RR 0.71, 95% CI, 0.62 to 0.82; I^2^=0%; ARD −0.38%, 95% CI, −0.53 to −0.23; NNT 263),^3^ despite the addition of primary prevention data from ALLHAT-LLT (RR 0.93, 95% CI, 0.76 to 1.13)^80^ and PROSPER (RR 1.03, 95% CI, 0.73 to 1.45)^91^ that each found no association between statin therapy and decreased risk of stroke.

Results were consistent in sensitivity analyses based on exclusion of trials stopped early^66,77,84,90^ (11 RCTs; RR 0.87, 95% CI, 0.77 to 0.99; I^2^=0%), restriction to good-quality trials (7 RCTs; RR 0.75, 95% CI, 0.61 to 0.92; I^2^=34%),^66,67,77,88,91–93^ restriction to trials with more than three years followup (12 RCTs; 0.83, 95% CI, 0.74 to 0.94; I^2^=4%),^67,74,77,80,81,85,88–93^ exclusion of trials that included some secondary prevention patients (13 RCTs; RR 0.78, 95% CI, 0.67 to 0.91; I^2^=25%),^74,90^ and restriction to trials that enrolled patients with mean or median baseline LDL-C less than 160 mg/dL (RR 0.77, 95% CI, 0.66 to 0.90; I^2^=31%).^66,67,74,77,80,81,84,85,88,90,91,93^

Four trials reported separate results for fatal or nonfatal stroke (Table 5; Appendix B1).^66,77,80,87^ Statin use was associated with a reduction in risk of nonfatal stroke (3 RCTs; RR 0.57, 95% CI, 0.41 to 0.81; I^2^=0%; ARD −0.32%, 95% CI, −0.52 to −0.12);^66,77,87^ the estimate for fatal stroke was imprecise (3 RCTs; RR 0.73, 95% CI, 0.35 to 1.50; I^2^=29%; ARD −0.05%, 95% CI, −0.14 to 0.04)^66,77,80^ (Appendixes C4 and C5).

#### Myocardial Infarction

Twelve trials (N=75,401) reported fatal or nonfatal MI (Table 5; Appendix B1, Appendixes C6 to C8).^66,67,77,79,80,85,86,88–90,92,93^ Eleven trials consistently found statin therapy associated with reduced risk of fatal or nonfatal MI versus placebo or no statin, with relative risk estimates that ranged from 0.14 to 0.82, though some estimates were imprecise. The remaining trial was small (n=305) and very imprecise (RR 1.02, 95% CI, 0.15 to 7.15).^86^ Statin therapy was associated with decreased risk of fatal or nonfatal MI at two to six years (12 RCTs; RR 0.67, 95% CI, 0.60 to 0.75; I^2^=14%; ARD −0.85%, 95% CI, −1.22 to −0.47; NNT 118). The result was similar to the pooled estimate in the prior USPSTF review (12 trials, RR 0.64, 95% CI, 0.57 to 0.71; I^2^=0%; ARD −0.81%, 95% CI, −1.19 to −0.43%; NNT 123), which did not include primary prevention data from ALLHAT-LLT (RR 0.82, 95% CI, 0.68 to 1.00).^80^ PROSPER did not report fatal or nonfatal MI in primary prevention participants.^91^

Results were consistent in sensitivity analyses in which trials stopped early were excluded^66,77,90^ (8 RCTs; RR 0.73, 95% CI, 0.65 to 0.81; I^2^=0%), when the analysis was restricted to good quality trials^66,67,77,89,92,93^ (6 RCTs; RR 0.61, 95% CI, 0.50 to 0.75; I^2^=26%), when the analysis was restricted to trials with three years or more of followup^67,77,79,80,85,88–90,92,93^ (10 RCTs; RR 0.70, 95% CI, 0.64 to 0.78; I^2^=0%), when one trial that included some secondary prevention patients was excluded^90^ (11 RCTs; RR 0.67, 95% CI, 0.58 to 0.76; I^2^=22%) and when the analysis was restricted to trials that enrolled a population with mean or median baseline LDL-C less than 160 mg/dL^66,67,77,79,80,85,88,90,93^ (9 RCTs; RR 0.65, 95% CI, 0.56 to 0.75; I^2^=29%) (Table 6).

Separate results for fatal and/or nonfatal MI were reported in eight trials (Table 6).^66,77,80,81,84,86,88,89^ Statin therapy was associated with decreased risk of nonfatal MI (RR 0.60, 95% CI, 0.47 to 0.75; I^2^=19%; ARD −0.47%, 95% CI, −0.63 to −0.31; NNT 213) (Appendix C8).^66,77,80,81,84,86,88,89^ For fatal MI, the pooled estimate favored statin therapy, but was imprecise (RR 0.83, 95% CI, 0.51 to 1.37; I^2^=28%) (Appendix C7).

#### Revascularization

Ten trials (N=65,924) reported incidence of revascularization.^66,77,79,80,84,88,89,92,93^ Nine trials consistently found statin therapy associated with decreased risk of revascularization versus placebo or no statin, with relative risk estimates that ranged from 0.54 to 0.88, though some estimates were imprecise (Table 5). The two largest trials, JUPITER (n=17,802; RR 0.54, 95% CI, 0.41 to 0.72 at 2 years; ARD −0.67%, 95% CI, −0.99 to −0.36; NNT 149)^66^ and HOPE-3 (n=12,705; RR 0.54, 95% CI, 0.41 to 0.72 at 6 years; ARD −0.41%, 95% CI, −0.77 to −0.05; NNT 244),^93^ each found statin therapy associated with a statistically significant decreased risk of revascularization. One other small (n=351) trial reported an imprecise estimate (RR 1.53, 95% CI, 0.26 to 9.03).^86^ When all trials were pooled, statin therapy was associated with decreased risk of revascularization versus placebo or no statin therapy at two to six years (RR 0.71, 95% CI, 0.63 to 0.80; I^2^=15%; ARD −0.59%, 95% CI, −0.77 to −0.41; NNT 169) (Appendix C9). The analysis incorporated primary prevention data from ALLHAT-LLT (RR 0.88, 95% CI, 0.74 to 1.04)^80^ and the pooled estimate was similar to the result in the 2016 USPSTF review (7 trials, RR 0.63, 95% CI, 0.56 to 0.72; ARD −0.66%, 95% CI, −0.87 to −0.43; NNT 152).^3^ Results for revascularization were consistent in sensitivity analyses (Table 6).

#### Composite Cardiovascular Outcomes

Fifteen trials (N=74,390) reported incidence of composite cardiovascular outcomes.^66,73–75,77,79,81,82,84,85,88,90–93^ In two trials, the composite outcome was not well defined.^75,82^ In the other trials, the composite outcome definition varied (Table 5 and Appendix B1). Across trials, composite cardiovascular outcome event rates ranged from one to 11 percent in the statin arms, depending in part on how the composite outcome was defined, but all trials found statin therapy associated with lower rates of composite outcomes versus placebo or no statin (ARD ranged from −0.35% to −13.25%) (Table 5). When all trials were pooled, statin therapy was associated with decreased risk of composite cardiovascular outcomes versus placebo or no statin at one to six years (RR 0.72, 95% CI, 0.64 to 0.81; I^2^=51%; ARD −1.28%, 95% CI, −1.61 to −0.95; NNT 78) (Appendix C10). The result, which included primary prevention data from PROSPER (RR 0.94, 95% CI, 0.78 to 1.14),^91^ was very similar to the pooled estimate in the prior USPSTF review (13 trials, RR 0.70, 95% CI, 0.63 to 0.78, I^2^=36%; ARD −1.39%, 95% CI, −1.79 to −0.99; NNT 72). Although statistical heterogeneity was present, results were consistent in sensitivity analyses based on exclusion of trials stopped early, restriction to good quality trials, restriction to trials with more than three years followup, exclusion of trials that included some secondary prevention patients, and restriction to trials with mean or median baseline LDL-C less than 160 mg/dL (Table 6).

#### Assessment for Publication Bias

There was no indication of small sample effects based on funnel plots or the Egger test for all-cause mortality, fatal and nonfatal stroke, or fatal and nonfatal MI (Appendixes C11 to C16). For cardiovascular mortality, the Egger test was statistically significant (p=0.03), but the funnel plot is difficult to interpret because there were few small sample size trials.

## Key Question 1b Do the Benefits of Statin Treatment Vary in Groups Defined by Demographic, Clinical, or Socioeconomic Characteristics?

### Summary

Ten trials (3 trials added for this update) stratified results according to demographic or clinical characteristics. There was no clear evidence of a differential effect of statin therapy based on demographic or clinical characteristics for any outcome. Based on within-study stratified analyses, evidence did not indicate a differential effect of statin therapy based on age (9 trials), sex (6 trials), race/ethnicity (2 trials), lipid parameters (6 trials), presence of hypertension (3 trials), cardiovascular risk score (3 trials), presence of renal dysfunction (3 trials), presence of metabolic syndrome (2 trials), or presence of diabetes (2 trials); findings for presence of elevated C-reactive protein were inconsistent (2 trials). Meta-analyses based on data from three trials that reported results for participants over age 70 were imprecise but generally consistent with overall estimates. None of the trials reported how benefits of statin therapy vary according to socioeconomic characteristics.

### Evidence

The 2016 USPSTF review included seven primary prevention trials that stratified results according to demographic or clinical characteristics, including age, sex, race/ethnicity, lipid parameters, hypertension, diabetes, metabolic syndrome, cardiovascular risk score, renal impairment, and CRP levels.^66,77,79,88,90,93,125^ The review found that relative risk estimates for statin versus placebo or no statin appeared similar in groups stratified according to demographic or clinical factors, though absolute benefits were greater in higher-risk groups.

In addition to the seven previously included trials,^66,77,79,88,90,93,125^ age-stratified data from ASCOT-LLA (<65 versus ≥65 years of age, n=10,305)^96^ and from the primary prevention population of ALLHAT-LLT (65 to 74 versus ≥75 years of age, n=2,867)^106^ were added for this update (Table 7; Appendix B1). In addition, primary prevention data from PROSPER (n=3,239), which was restricted to persons 70 to 82 years of age, were added.^91^

Table 7 Effects of Statins vs. Placebo or No Statin Based on Demographic Characteristics

Study Name; Quality; Outcome | Age | Sex | Race/Ethnicity
AFCAPS/TexCAPS^79^; Fair
Acute major coronary events | <65 years; RR 0.58 (95% CI, NR); ≥65 years; RR 0.71 (95% CI, NR); Interaction described as not significant | Men; RR 0.63 (95% CI, 0.50 to 0.81); Women; RR 0.54 (95% CI, 0.22 to 1.35) | NR
ALLHAT-LLT^80^; Fair
All-cause mortality | Age <65 years; RR 0.91 (95% CI, 0.79 to 1.05); Age 65-74 years; RR 1.03 (95% CI, 0.83 to 1.29); adjusted HR 1.05 (95% CI, 0.82 to 1.33); Age ≥75 years; RR 1.32 (95% CI, 1.00 to 1.76); adjusted HR 1.36 (95% CI, 0.98 to 1.89); p for interaction=0.24 | NR | NR
CV mortality | Age <65 years; RR 0.94 (95% CI, 0.75 to 1.16); Age 65-74 years; RR 0.99 (95% CI, 0.71 to 1.39); Age ≥75 years; RR 1.39 (95% CI, 0.85 to 2.25) | NR | NR
Fatal or nonfatal stroke | Age <65 years; RR 0.86 (95% CI, 0.67 to 1.11); Age 65-74 years; RR 1.01 (95% CI, 0.67 to 1.52); Age ≥75 years; RR 1.10 (95% CI, 0.64 to 1.88) | NR | NR
Fatal CHD or nonfatal MI | Age <65 years; RR 0.88 (95% CI, 0.70 to 1.12); Age 65-74 years; RR 0.82 (95% CI, 0.61 to 1.10); Age ≥75 years; RR 0.74 (95% CI, 0.48 to 1.17) | NR | NR
ASCOT-LLA^90^; Fair
All-cause mortality | Age <65 years: HR 0.70 (95% CI, 0.49 to 1.01); Age ≥65 years: HR 0.98 (95% CI, 0.77 to 1.23); p for interaction 0.14 | NR | NR
CV mortality | Age <65 years: HR 0.72 (95% CI, 0.42 to 1.23); Age ≥65 years: HR 1.03 (95% CI, 0.70 to 1.59); p for interaction 0.29 | NR | NR
Fatal or nonfatal stroke | Age <65 years: HR 0.63 (95% CI, 0.38 to 1.03); Age ≥65 years: HR 0.80 (95% CI, 0.58 to 1.11); p for interaction 0.43 | NR | NR
Fatal or nonfatal MI | <65 years; HR 0.67 (95% CI, 0.46 to 0.96); ≥65 years; HR 0.64 (95% CI, 0.47 to 0.86); p for interaction=0.82 | Men; HR 0.59 (95% CI, 0.44 to 0.77); Women; HR 1.10 (95% CI, 0.57 to 2.12) | NR
CARDS,^77^; Good
CHD event, stroke and revascularization | <65 vs. ≥65 years; p=0.58 for interaction | Men vs. women; p=0.59 for interaction | NR
Acute coronary events | <65 years; RR 0.62 (95% CI, 0.38 to 1.02); ≥65 years; RR 0.68 (95% CI, 0.42 to 1.11) | NR | NR
Coronary revascularization | <65 years; RR 0.85 (95% CI, 0.46 to 1.59); ≥65 years; RR 0.45 (95% CI, 0.17 to 1.17) | NR | NR
Stroke | <65 years; RR 0.53 (95% CI, 0.23 to 1.24); ≥65 years; RR 0.53 (95% CI, 0.27 to 1.03) | NR | NR
HOPE-3^93^; Good
CV events | Age ≤65.3 years; HR 0.78 (95% CI, 0.59 to 1.05); Age >65.3 years; HR 0.75 (95% CI, 0.61 to 0.93); p for interaction=0.83 | Men; HR 0.72 (95% CI, 0.58 to 0.90); Women; HR 0.83 (95% CI, 0.64 to1.09); p for interaction=0.43 | European descent; HR 0.60 (95% CI, 0.40 to 0.92); Chinese; HR 0.76 (95% CI, 0.53 to 1.08); Other Asian; HR 0.83 (95% CI, 0.59 to 1.16); Latin American; HR 0.84 (95% CI, 0.61 to 1.15); Other race/ethnicity; HR 0.75 (95% CI, 0.39 to 1.43); p for interaction=0.78
JUPITER^66^; Good
CV events | ≤65 vs. >65 years; CV events: no difference by age; p=0.32 for interaction; <70 years; HR 0.51 (95% CI, 0.38 to 0.69); ≥70 years; HR 0.61 (95% CI, 0.46 to 0.82) | Men; HR 0.58 (95% CI, 0.45 to 0.73); Women; HR 0.54 (95% CI, 0.37 to 0.80); p=0.80 for interaction | White; HR 0.55 (95% CI, 0.43 to 0.69); Nonwhite; HR 0.63 (95% CI, 0.41 to 0.99) p=0.57 for interaction
All-cause mortality | <70 years; HR 0.80 (95% CI, 0.60 to 1.04); ≥70 years; HR 0.80 (95% CI, 0.62 to 1.04) | Men; HR, 0.82 (95% CI, 0.66 to 1.03); Women; HR, 0.77 (95% CI, 0.55 to 1.06); p=0.74 for interaction | NR
CV mortality | <70 years; HR 0.79 (95% CI, 0.39 to 1.58); ≥70 years; HR 0.83 (95% CI, 0.47 to 1.48) | Men; HR 0.44 (95% CI, 0.31 to 0.61); Women; HR 0.73 (95% CI, 0.48 to 1.13); p=0.06 for interaction | NR
Stroke | <70 years; HR 0.45 (95% CI, 0.22 to 0.91); ≥70 years; HR 0.55 (95% CI, 0.33 to 0.93) | Men; HR 0.37 (95% CI, 0.21 to 0.67); Women; HR 0.77 (95% CI, 0.42 to 1.42); p=0.09 for interaction | White; HR 0.45 (95% CI, 0.38 to 0.69); Nonwhite; HR 0.67 (95% CI, 0.33 to 1.35)
Nonfatal Stroke | NR | Men; HR 0.33 (95% CI, 0.17 to 0.63); Women; HR 0.84 (95% CI, 0.45 to 1.58); p=0.04 for interaction | NR
MI | <70 years; HR 0.37 (95% CI, 0.20 to 0.69); ≥70 years; HR 0.55 (95% CI, 0.31 to 1.00) | Men; HR 0.42 (95% CI, 0.26 to 0.71); Women; HR 0.54 (95% CI, 0.25 to 1.18); p=0.60 for interaction | White; HR 0.42 (95% CI, 0.26 to 0.67); Nonwhite; HR 0.68 (95% CI, 0.24 to 1.91)
Nonfatal MI | NR | Men; HR 0.29 (95% CI, 0.16 to 0.54); Women; HR 0.56 (95% CI, 0.24 to 1.33); p=0.24 for interaction | NR
Revascularization/hospitalization | <70 years; HR 0.54 (95% CI, 0.38 to 0.77); ≥70 years; HR 0.51 (95% CI, 0.33 to 0.80) | Men; HR 0.63 (95% CI, 0.46 to 0.86); Women; HR 0.24 (95% CI, 0.11 to 0.51); p=0.01 for interaction | NR
MEGA^88^; Fair
CHD | <60 years; HR 0.81 (95% CI, 0.49 to 1.32); ≥60 years; HR 0.59 (95% CI, 0.40 to 0.88) | Men vs. women; HR 0.63 (95% CI, 0.42 to 0.95); Women; HR 0.71 (95% CI, 0.44 to 1.14); p for interaction=0.71 | NR
Stroke | Age <55 years; HR 1.70 (95% CI, 0.65 to 4.40); Age ≥55 to <60 years; HR 0.89 (95% CI, 0.35 to 2.25); Age ≥60 to <65 years; HR 0.47 (95% CI, 0.21 to 1.03); Age ≥65 years; HR 0.43 (95% CI, 0.21 to 0.91) | Men; HR 0.66 (95% CI, 0.37 to 1.20); Women; HR 0.63 (95% CI, 0.36 to 1.10); p for interaction=0.90 | NR
WOSCOPS^92^; Good
Nonfatal MI + fatal CHD | <55 years; RR 0.57 (95% CI, 0.59 to 0.94); >55 years; RR 0.57 (95% CI, 0.42 to 0.79) | NR | NR

Abbreviations: AFCAPS/TexCAPS=Air Force/Texas Coronary Atherosclerosis Prevention Study; ASCOT=Anglo-Scandinavian Cardiac Outcomes Trial; CARDS=Collaborative Atherosclerosis Italian Ultrasound Study; CHD=coronary heart disease; CI=confidence interval; CV=cardiovascular; HOPE-3=Heart Outcomes Prevention Evaluation; HR=hazard ratio; JUPITER=Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; MEGA=Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese; MI=myocardial infarction; NR=not reported; RR=relative risk; WOSCOPS=West of Scotland Prevention Study Group.

#### Demographic Characteristics

##### Age

Seven trials included in the 2016 USPSTF review found no evidence indicating that effects of statin on all-cause mortality or cardiovascular outcome risk estimates vary according to age (stratified as younger or older than 55, 60, 65, or 70 years of age) (Table 7; Appendix B1).^66,77,79,88,90,93,125^ None of the trials reported results for persons over 75 years of age and only one trial (JUPITER)^66^ reported results for persons over 70 years of age.

Additional data added for this update from ALLHAT-LLT^106^ and ASCOT-LLA^96^ also showed no statistically significant differences in benefits of statin therapy in groups stratified by age, though results favored younger persons for some outcomes. In ALLHAT-LLT, statin therapy was associated with higher risk of all-cause and cardiovascular mortality in persons ≥75 years of age than those 65 to 74 years of age, but estimates for the ≥75 years group were imprecise and the difference was not statistically significant.^106^ For all-cause mortality, the adjusted HRs were 1.36 (95% CI, 0.98 to 1.89) for persons ≥75 years of age and 1.05 (95% CI, 0.82 to 1.33) for those 65 to 74 years of age (p for interaction=0.24). Results were similar for cardiovascular mortality (RR 1.39, 95% CI, 0.85 to 2.25 versus 0.99, 95% CI, 0.71 to 1.39, respectively). All-cause and cardiovascular mortality in persons younger than 65 years of age were similar to those 65 to 74 years of age (calculated based on the primary prevention population minus persons ≥65years of age). For stroke and MI, estimates were similar across age groups (Table 7; Appendix B1). As previously described, ALLHAT-LLT used an open-label design and had methodological limitations (attrition and crossover) and reported a small effect of statin therapy on cholesterol levels, complicating interpretation of results. The ASCOT-LLA trial found statin therapy associated with decreased all-cause and cardiovascular mortality in persons <65 years of age and no benefit among those ≥65 years of age, but differences were not statistically significant. For all-cause mortality, the HRs were 0.98 (95% CI, 0.77 to 1.23) for those older than 65 years of age and 0.70 (95% CI, 0.49 to 1.01) for those less than 65 years of age (p for interaction 0.14) and for cardiovascular mortality, the HRs were 1.03 (95% CI, 0.70 to 1.59) and 0.72 (95% CI, 0.42 to 1.23), respectively (p for interaction=0.29). Age-stratified estimates in ASCOT-LLA were similar for fatal or nonfatal stroke (p for interaction=0.43) and fatal or nonfatal MI (p for interaction=0.82) (Table 7; Appendix B1).^96^

Three trials reported results for persons >70 years of age: ALLHAT-LLT (≥75 years),^106^ JUPITER (≥70 years),^66^ and PROSPER (≥70 years).^91^ Pooled estimates for persons >70 years of age were generally consistent with the overall pooled estimates: for all-cause mortality (3 trials), RR 0.96 (95% CI, 0.62 to 1.48; I^2^=89%); for fatal or nonfatal stroke (3 trials), RR 0.87 (95% CI, 0.58 to 1.30; I^2^=55%), for fatal or nonfatal MI (2 trials), RR 0.67 (95% CI, 0.47 to 0.96; I^2^=0%); and for composite cardiovascular outcomes (3 trials), RR 0.77 (95% CI, 0.57 to 1.04; I^2^=68%) (Appendix C17). However, analyses were limited by imprecision and statistical heterogeneity, with JUPITER (which used a high-intensity statin) tending to report substantially better results than ALLHAT-LLT or PROSPER (both used a moderate intensity statin).

##### Sex

The 2016 USPSTF review included six trials that evaluated how effects of statins varied according to sex (Table 7; Appendix B1).^66,77,79,88,90,93^ Based primarily on composite cardiovascular outcomes, relative effects of statins appeared similar in men and women. No new evidence on how benefits of statins varied according to sex was identified.

As reported in the 2016 USPSTF review, the JUPITER trial also reported sex-stratified estimates for statins versus placebo on all-cause mortality and specific cardiovascular outcomes.^66,112^ Statin therapy was associated with greater reduction in risk of revascularization or hospitalization in females than males (hazard ratio [HR] 0.24, 95% CI, 0.11 to 0.51 versus HR 0.63, 95% CI, 0.46 to 0.86, p for interaction=0.01) but smaller reduction in risk of nonfatal stroke (HR 0.84, 95% CI, 0.45 to 1.58 vs. HR 0.33, 95% CI, 0.17 to 0.63, respectively; p for interaction=0.04). However, the difference in risk of any (fatal or nonfatal) stroke was not statistically significant (p=0.09) and estimates for other outcomes (all-cause mortality, CV mortality, or MI) were similar in females and males (Table 7). One other trial (MEGA) found statin therapy associated with similar effects in females and males on incidence of CHD (p for interaction 0.71) or stroke (p for interaction=0.90).^113,128^

##### Race and Ethnicity

In fourteen of fifteen trials that reported race or ethnicity, White race was the most common. In ten of the trials^67,74,76,77,79,81,84,85,87,90^ the proportion of White participants was over 85 percent. HOPE-3 was the only trial that did not enroll a White majority population.^93^

Two trials (JUPITER and HOPE-3) evaluated how benefits of statin therapy varied according to race or ethnicity (Table 7; Appendix B1). In JUPITER, statin therapy was associated with similar estimates for risk of composite cardiovascular events in White (HR 0.55, 95% CI, 0.43 to 0.69) and nonwhite participants (HR 0.63, 95% CI, 0.41 to 0.99; p for interaction=0.57).^66^ A JUPITER subgroup analysis reported risk of specific cardiovascular outcomes (e.g. all-cause mortality, cardiovascular mortality, MI, stroke, and revascularization) stratified according to White or Black race and Hispanic ethnicity, but many estimates were imprecise to low event rates and there were no clear differences between groups.^97^ In HOPE-3, statin therapy was associated with similar effects on risk of cardiovascular events in groups stratified by European descent (HR 0.60, 95% CI, 0.40 to 0.92), Chinese (HR 0.76, 95% CI, 0.53 to 1.08), other Asian (HR 0.83, 95% CI, 0.59 to 1.16), Latin American (HR 0.84, 95% CI, 0.61 to 1.15), or other race/ethnicity (HR 0.75, 95% CI, 0.39 to 1.43; p for interaction =0.78).^93^

#### Clinical Characteristics

##### Lipid Parameters

Six trials included in the 2016 USPSTF review reported within-study analyses stratified according to baseline lipid levels.^66,77,79,88,93,125^ Statin therapy was associated with reduced risk of cardiovascular outcomes in groups with lower or higher lipid (TC, LDL-C, HDL-C, or TG) levels, with no statistically significant interactions between baseline lipid level and effects of statin therapy (Table 8). An across-study analysis also found no difference in risk estimates when trials were stratified according to mean baseline LDL-C level greater than or less than 160 mg/dL (Table 6). Two trials (WOSCOPS^92^ and KAPS^89^) enrolled patients with higher mean baseline LDL-C (~190 mg/dL). WOSCOPS (n=5,529) reported results consistent with trials that enrolled patients with lower baseline LDL-C; KAPS was a smaller (n=447) trial with imprecise estimates (Table 5).

Table 8 Effects of Statins vs. Placebo or No Statin Based on Clinical Characteristics

Study name, Quality Outcome | Lipid parameters | Hypertension | Cardiovascular risk score | Renal dysfunction | Diabetes | Metabolic syndrome | Other characteristics
AFCAPS/TexCAPS^79^; Fair
Acute major coronary events | LDL-C <149.1 mg/dL; RR 0.74 (95% CI, 0.49 to 1.11); LDL-C ≥149.1 mg/dL; RR 0.53 (95% CI, 0.37 to 0.77) | NR | Low, mild, or moderate risk (<20% 10-year CHD risk) 5.18 vs. 8.47 events/ 1000 person-years (RR 0.61, 95% CI, 0.45 to 0.82); High or very high risk (>20% 10-year CHD risk) 12.99 vs. 19.63 events/1000 person-years (RR 0.66, 95% CI, 0.45 to 0.97) | Mild CKD (eGFR <60 ml/minute/1.73 m^2^); ARR 0.32 (95% CI, 0.10 to 1.11) | NR | NR | LDL-C ≥149.1 mg/dL and CRP <0.16 vs. >0.16 mg/dL; RR 0.38 (95% CI, 0.21 to 0.70) vs. 0.68 (95% CI, 0.42 to 1.10); LDL-C <149.1 mg/dL and CRP <0.16 vs. >0.16 mg/dL; RR 1.08 (95% CI, 0.56 to 2.08) vs. 0.58 (95% CI, 0.34 to 0.98)
ASCOT^90^; Fair
Nonfatal MI + fatal CHD | NR | NR | NR | Renal dysfunction; HR 0.61 (95% CI, 0.44 to 0.84); No renal dysfunction; HR 0.70 (95% CI, 0.47 to 1.04) | Diabetes; HR 0.84 (95% CI, 0.55 to 1.29); No diabetes; HR 0.56 (95% CI, 0.41 to 0.77); p=0.14 for interaction | Metabolic syndrome; HR 0.77 (95% CI, 0.52 to 1.12); No metabolic syndrome; HR 0.56 (95% CI, 0.40 to 0.79) | Smoker; HR 0.56 (95% CI, 0.37 to 0.85); Nonsmoker; HR 0.70 (95% CI, 0.51 to 0.96); BMI <30 kg/m^2^; HR 0.59 (95% CI, 0.39 to 0.90); BMI ≥30 kg/m^2^ HR 0.67 (95% CI, 0.49 to 0.92)
Total CV events and procedures | NR | NR | NR | NR | Diabetes; HR 0.77 (95% CI, 0.61 to 0.98); No diabetes; HR 0.80 (95% CI, 0.68 to 0.94); p=0.82 for interaction | NR | NR
Fatal and nonfatal stroke | NR | NR | NR | NR | Diabetes; HR 0.67 (95% CI, 0.41 to 1.09); No diabetes; HR 0.76 (95% CI, 0.55 to 1.06); p=0.66 for interaction | NR | NR
CARDS^77^; Good
All-cause mortality | NR | NR | NR | Renal dysfunction; aHR 0.86 (95% CI, 0.51 to 1.45); No renal dysfunction; HR 0.65 (95% CI, 0.42 to 1.00) | NR | NR | NR
CVD | NR | NR | NR | Renal dysfunction; aHR 0.57 (95% CI, 0.35 to 0.94); No renal dysfunction; HR 0.65 (95% CI, 0.47 to 0.91) | NR | NR | NR
CHD | NR | NR | NR | Renal dysfunction; aHR 0.65 (95% CI, 0.36 to 1.17); No renal dysfunction; HR 0.64 (95% CI, 0.41 to 0.99) | NR | NR | NR
Stroke | NR | NR | NR | Renal dysfunction; aHR 0.38 (95% CI, 0.15 to 0.99); No renal dysfunction; HR 0.62 (95% CI, 0.33 to 1.18); p=0.20 for interaction | NR | NR | NR
Revasculariza-tion | NR | NR | NR | Renal dysfunction; aHR 0.40 (95% CI, 0.14 to 1.15); No renal dysfunction; HR 0.84 (95% CI, 0.45 to 1.54) | NR | NR | NR
Composite cardiovascular outcome | LDL ≥120 mg/dL; HR 0.62 (95% CI, 0.43 to 0.91); LDL <120 mg/dL; HR 0.63 (95% CI, 0.42 to 0.94); p for interaction=0.96; HDL ≥54 mg/dL; HR 0.59 (95% CI, 0.39 to 0.89); HDL <54 mg/dL; HR 0.66 (95% CI, 0.45 to 0.95); p for interaction=0.70; Triglycerides ≥151 mg/dL; HR 0.56 (95% CI, 0.38 to 0.82); Triglycerides <151 mg/dL; HR 0.71 (95% CI, 0.48 to 1.05); p for interaction=0.40; Total cholesterol ≥209 mg/dL; HR 0.59 (95% CI, 0.41 to 0.86); Total cholesterol <209 mg/dL; HR 0.67 (95% CI, 0.45 to 1.01); p for interaction=0.67 | NR | NR | NR | NR | NR | NR
HOPE-3^93^; Good
CV events | LDL-C ≤112.3 mg/dL; HR 0.70 (95% CI, 0.56 to 0.96); LDL-C 112.4–141.7 mg/dL; HR 0.76 (95% CI, 0.56 to 1.03); LDL-C >141.7 mg/dL; HR 0.96 (95% CI, 0.71 to 1.29); p=0.16 for interaction | SBP ≤131.5 mm Hg; HR 0.64 (95% CI, 0.46 to 0.91); SBP 131.6–143.5 mm Hg; HR 0.80 (95% CI, 0.59 to 1.09); SBP >143.5 mm Hg; HR 0.81 (95% CI, 0.63 to 1.05); p=0.35 for interaction | INTERHEART risk score ≤12 (low risk); HR 0.66 (95% CI, 0.47 to 0.92); INTERHEART risk score 13–16 (moderate risk); HR 0.85 (95% CI, 0.63 to 1.15); INTERHEART risk score >16 (high risk); HR 0.77 (95% CI, 0.59 to 0.99); p=0.57 for interaction | NR | NR | NR | CRP ≤2.0 mg/dL; HR 0.82 (95% CI, 0.64 to 1.06); CRP >2.0 mg/dL; HR 0.77 (95% CI, 0.60 to 0.98); p for interaction=0.69
JUPITER^66^; Good
All-cause mortality | NR | NR | NR | Moderate CKD (eGFR <60 ml/minute/1.73 m^2^); HR 0.56 (95% CI, 0.37 to 0.85); No CKD (eGFR ≥60 ml/minute/1.73 m^2^); HR 0.88 (95% CI, 0.72 to 1.09) | NR | NR | NR
Fatal or nonfatal stroke | NR | NR | NR | Moderate CKD (eGFR <60 ml/minute/1.73 m^2^); HR 0.71 (95% CI, 0.31 to 1.59); No CKD (eGFR ≥60 ml/minute/1.73 m^2^); 0.46 (95% CI, 0.28 to 0.76) | NR | NR | NR
Fatal or nonfatal MI | NR | NR | NR | Moderate CKD (eGFR <60 ml/minute/1.73 m^2^); HR 0.40 (95% CI, 0.17 to 0.90); No CKD (eGFR ≥60 ml/minute/1.73 m^2^); 0.48 (95% CI, 0.29 to 0.79) | NR | NR | NR
Revascular-ization | NR | NR | NR | Moderate CKD (eGFR <60 ml/minute/1.73 m^2^); HR 0.48 (95% CI, 0.28 to 0.83); No CKD (eGFR ≥60 ml/minute/1.73 m^2^); HR 0.57 (95% CI, 0.40 to 0.80) | NR | NR | NR
CV events | LDL-C ≤100 mg/dL; HR 0.65 (95% CI, 0.46 to 0.91); LDL-C >100 mg/dL; HR 0.52 (95% CI, 0.40 to 0.67); p for interaction=0.30; HDL-C <40 mg/dL; HR 0.50 (95% CI, 0.33 to 0.76); HDL-C ≥40 mg/dL; HR 0.58 (95% CI, 0.46 to 0.74); p for interaction=0.51; TG <200 mg/dL; HR 0.56 (95% CI, 0.45 to 0.71); TG ≥200 mg/dL; HR 0.56 (95% CI, 0.34 to 0.91); p for interaction=0.97 | Hypertension vs. no hypertension No difference; p=0.53 for interaction | Framingham risk score ≤10% vs. >10% No difference; p=0.99 for interaction | Moderate CKD (eGFR <60 ml/minute/1.73 m^2^); HR 0.55 (95% CI, 0.38 to 0.82); No CKD (eGFR ≥60 ml/minute/1.73 m^2^); HR 0.57 (95% CI, 0.45 to 0.72) | NR | Metabolic syndrome vs. no metabolic syndrome No difference; p=0.14 for interaction | Smoker vs. nonsmoker; No difference; p=0.63 for interaction; BMI <25 vs. 25–29 vs. ≥30 kg/m^2^; No difference; p=0.70 for interaction; Elevated CRP with no other risk factors other than older age; HR 0.63 (95% CI, 0.44 to 0.92)
MEGA^88^; Fair
CHD | LDL-C <155 mg/dL; HR 0.90 (95% CI, 0.56 to 1.44); LDL-C >155 mg/dL; HR 0.54 (95% CI, 0.35 to 0.81); p for interaction=0.11; HDL-C <54.9 mg/dL; HR 0.69 (95% CI, 0.47 to 1.01); HDL-C >54.9 mg/dL); HR 0.64 (95% CI, 0.38 to 1.10); p for interaction=0.84; TG <119.6 mg/dL; HR 0.58 (95% CI, 0.33 to 1.01); TG >119.6 mg/dL; HR 0.72 (95% CI, 0.49 to 1.04); p for interaction=0.53; TC <240 mg/dL; HR 0.63 (95% CI, 0.39 to 1.01); TC>240 mg/dL; HR 0.70 (95% CI, 0.46 to 1.05); p for interaction=0.75 | Hypertension; HR 0.75 (95% CI, 0.51 to 1.11); No hypertension; HR 0.56 (95% CI, 0.33 to 0.93); p=0.37 for interaction | NR | Moderate CKD (eGFR 30 to <60 ml/min/1.73 m^2^) *; HR 0.52 (95% CI, 0.31 to 0.89) | Diabetes; HR 0.64 (95% CI, 0.41 to 1.01); No diabetes; HR 0.69 (95% CI, 0.45 to 1.05); p for interaction=0.82 | NR | Current or past smoker; HR 0.69 (95% CI, 0.42 to 1.13); No history of smoking; HR 0.64 (95% CI, 0.43 to 0.96); p for interaction=0.82; BMI <24 kg/m^2^; HR 0.69 (95% CI, 0.45 to 1.06); BMI ≥24 kg/m^2^; HR 0.65 (95% CI, 0.42 to 1.01); p for interaction=0.87
Stroke | NR | Hypertension; HR 0.57 (95% CI, 0.27 to 1.19); No hypertension; HR 0.68 (95% CI, 0.42 to 1.11) | NR | Moderate CKD (eGFR 30 to <60 ml/min/1.73 m^2^) *; HR 0.27 (95% CI, 0.12 to 0.59) | Diabetes; HR 0.69 (95% CI, 0.35 to 1.36) vs.; No diabetes; HR 0.63 (95% CI, 0.38 to 1.04) | NR | Smoker; HR 0.62 (95% CI, 0.27 to 1.42); Nonsmoker; HR 0.67 (95% CI, 0.42 to 1.06)
CVD | NR | NR | NR | Moderate CKD (eGFR 30 to <60 ml/min/1.73 m^2^) *; HR 0.45 (95% CI, 0.30 to 0.69) | NR | NR | NR
All-cause mortality | NR | NR | NR | Moderate CKD (eGFR 30 to <60 ml/min/1.73 m^2^) *; HR 0.49 (95% CI, 0.27 to 0.89) | NR | NR | NR
WOSCOPS^92^; Good
Nonfatal MI + fatal CHD | Cholesterol >269 mg/dL; RRR 27% (95% CI, 4 to 44); Cholesterol <269 mg/dL; RRR 36% (95% CI, 15 to 51); LDL-C >189 mg/dL; RRR 27% (95% CI, 6 to 43); LDL-C <189 mg/dL; RRR 37% (95% CI, 15 to 53); HDL-C <43 mg/dL; RRR 31% (95% CI, 11 to 46); HDL-C >43 mg/dL; RRR 33% (95% CI, 9 to 51); TG >148 mg/dL; RRR 32% (95% CI, 12 to 47); TG <148 mg/dL; RRR 29% (95% CI, 4 to 48) | NR | NR | NR | NR | NR | Smoker; RRR 31% (95% CI, 12 to 47); Nonsmoker; RRR 31% (95% CI, 6 to 48)

Abbreviations: AFCAPS/TexCAPS=Air Force/Texas Coronary Atherosclerosis Prevention Study; AHR=adjusted hazard ratio; ASCOT-LLA=Anglo-Scandinavian Cardiac Outcomes Trial–Lipid Lowering Arm; BMI=body mass index; CARDS=Collaborative Atorvastatin Diabetes Study; CHD=coronary heart disease; CI=confidence interval; CKD=chronic kidney disease; CRP=C-reactive protein; CV=cardiovascular; CVD=cardiovascular disease; eGFR= estimated glomerular filtration rate; HDL=high-density lipoprotein; HOPE-3=Heart Outcomes Prevention Evaluation; HR=hazard ratio; JUPITER=Justification for the Use of Statins in Prevention and Intervention Trial Evaluating Rosuvastatin; LDL-C= low-density lipoprotein-cholesterol; MEGA=Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese; MI=myocardial infarction; NR=not relevant; RR=relative risk; RRR=relative risk reduction; SBP=systolic blood pressure; TC=total cholesterol; TG=triglyceride; WOSCOPS=West of Scotland Prevention Study Group.

* No comparison for non-CKD subjects reported.

##### Hypertension

Three trials included in the 2016 USPSTF review found no differences in effects of statin therapy on cardiovascular outcomes in within-study analyses stratified according to presence of hypertension at baseline (Table 8).^66,88,93^

Two trials included in the 2016 USPSTF review (ASCOT-LLA^90^ and HYRIM^73^) and primary prevention data from one additional trial (ALLHAT-LLT^80^) restricted enrollment to patients with hypertension. There were no differences in pooled estimates from trials that restricted enrollment to patients with hypertension and trials not restricted to patients with hypertension for all-cause mortality (p for interaction=0.27), cardiovascular mortality (p for interaction=0.17), fatal or nonfatal stroke (p for interaction=0.46) fatal or nonfatal MI (p for interaction=0.16) and composite cardiovascular outcomes (p for interaction=0.99). However, findings were limited by variability in cardiovascular risk factor eligibility criteria among trials not restricted to patients with hypertension and some inconsistency among the hypertension trials.

##### Cardiovascular Risk Score

Three trials included in the 2016 USPSTF review found no differences in relative effects of statin therapy on cardiovascular outcomes when patients were stratified according to baseline cardiovascular risk score (Table 8).^93,104,120^ In the JUPITER and HOPE-3 trials, there were no differences in risk of cardiovascular outcomes between patients with a Framingham 10-year risk of less than or greater than 10 percent (p=0.99 for interaction)^120^ or an INTERHEART low, moderate or high risk score (p=0.57 for interaction).^93^ In AFCAPS/TexCAPs, risk estimates were very similar when patients were stratified as <20% 10-year CHD risk (RR 0.61, 95% CI, 0.45 to 0.82) or >20% 10-year CHD risk (RR 0.66, 95% CI, 0.45 to 0.97).^104^

Although relative risk estimates were similar across groups, absolute benefits varied according to baseline risk. For example, in the JUPITER trial, relative benefits for the primary composite outcome (cardiovascular death, MI, stroke, revascularization, or hospitalization for unstable angina) were similar in persons with Framingham risk scores >20% (HR 0.70 [95% CI, 0.43 to 1.14]) and those with Framingham risk scores <10% (HR 0.67 [95% CI, 0.42 to 1.07]), but absolute benefits were larger among those at higher risk (ARD −6.9 vs. −2.0 per 1000 person-years [CIs not provided]).^66,130^ in the HOPE-3 trial, relative benefits for the primary composite outcome (death, nonfatal MI, and nonfatal stroke) were similar for persons with higher and lower cardiovascular risk scores (HR 0.77 [95% CI, 0.59 to 0.99] for INTERHEART score >16 vs. HR 0.85 [95% CI, 0.63 to 1.15] for INTERHEART score 13 to 16), but absolute benefits were larger in those with higher cardiovascular risk score (ARD −1.43% [95% CI, −2.83% to −0.04%] vs. −0.71% [95% CI, −2.00% to 0.58%]; NNT 70 vs. 141).^93^

##### Renal Dysfunction

Five trials reported effects of statins on cardiovascular outcomes in patients with baseline renal dysfunction (Table 8).^79,88,90,120,128,131^ Four trials were included in the 2016 USPSTF review and one trial was added.^127^ In all trials, point estimates in patients with baseline renal dysfunction favored statin therapy, although some estimates were imprecise. In three trials that reported within-study analyses stratified according to presence or absence of renal dysfunction, there were no clear differences in risk estimates.^90,120,131^

##### Diabetes

Two trials included in the prior USPSTF review reported effects of statins versus placebo or no statin on cardiovascular outcomes in within-study analyses stratified according to diabetes status at baseline (Table 8).^88,90^ In both trials, estimates favored statin therapy in persons with or without diabetes, with no statistically significant interactions between diabetes status and effects of statin therapy.

Four trials of statin therapy restricted inclusion to patients with diabetes^75,77,82,85^ and five trials specifically excluded patients with diabetes;^66,76,78,79,87^ all were included in the 2016 USPSTF review. Pooled estimates were similar in the trials that restricted inclusion to persons with diabetes and those that excluded persons with diabetes for all-cause mortality (3 trials; RR 0.84, 95% CI, 0.64 to 1.09; I^2^=5% and 4 trials; RR 0.86, 95% CI, 0.73 to 1.01; I^2^=1%, respectively), fatal or nonfatal stroke (3 trials; RR 0.71, 95% CI, 0.50 to 1.01; I^2^=0% and 2 trials; RR 0.52, 95% CI, 0.35 to 0.80; I^2^=0%, respectively), and fatal or nonfatal MI (2 trials; RR 0.64, 95% CI, 0.43 to 0.97; I^2^=38% and 2 trials; RR 0.54, 95% CI, 0.42 to 0.70; I^2^=1%, respectively).

##### Metabolic Syndrome

Two trials included in the prior USPSTF review reported effects of statins on cardiovascular outcomes in patients stratified according to presence of metabolic syndrome (Table 8).^66,90^ In both trials, within-study analyses found favored statin therapy in persons with or without metabolic syndrome, with no clear differences in risk estimates.

##### Other Clinical Characteristics

Two trials included in the prior USPSTF review, AFCAPS/TexCAPS and HOPE-3, conducted subgroup analyses exploring the relationship between statin use, CRP levels (alone or in conjunction with LDL-C levels) and cardiovascular outcomes (Table 8; Appendix B1).^93,121^ In AFCAPS/TexCAPS, among participants with an LDL-C level of less than 149 mg/dL, statin therapy was associated with decreased risk of acute major coronary events in those with a CRP level greater than 0.16 mg/dL (RR 0.58, 95% CI, 0.34 to 0.98) but not in those with a CRP level less than 0.16 mg/dL (RR 1.08 95% CI, 0.56 to 2.08; p for interaction=0.06).^121^ In the same study, statin therapy was associated with reduced risk of major coronary events in participants with an LDL-C level of 149 mg/dL or greater and either CRP level less than 0.16 mg/dL (RR 0.38, 95% CI, 0.21 to 0.70) or CRP level greater than 0.16 mg/dL (RR 0.68, 95% CI, 0.42 to 1.10). Results from the HOPE-3 trial (mean baseline LDL-C level, 128 mg/dL) were discordant with AFCAPS/TexCAPS: it found no difference in effects of statins on composite cardiovascular events when patients were stratified according to a CRP level of 2.0 mg/L or less (HR 0.82, 95% CI, 0.64 to 1.06) or greater than 2.0 mg/L (HR 0.77, 95% CI, 0.60 to 0.98; p=0.70 for interaction).^93^ The JUPITER trial found statin therapy associated with decreased risk of all-cause mortality (RR 0.80, 95% CI, 0.67 to 0.96), cardiovascular mortality (RR 0.53, 95% CI, 0.41 to 0.69), and other cardiovascular outcomes versus placebo, but restricted inclusion to persons with an elevated CRP level (≥2.0 mg/L) and an LDL-C level of less than 130 mg/dL (Table 5).^66^

Three trials included in the prior USPSTF review reported no interaction between effects of statins versus placebo and body mass index,^90,107,108^ and four trials reported similar risks of cardiovascular events in current or former smokers and nonsmokers (Table 8).^66,88,90,125^

One trial limited enrollment to participants with rheumatoid arthritis.^84^ Results for all-cause mortality and cardiovascular events from the trial were similar to other primary prevention trials, though estimates were imprecise due to low incidence of outcomes (Table 5).

#### Socioeconomic Characteristics

None of the trials reported how benefits of statin therapy vary according to socioeconomic characteristics.

## Key Question 1c What Are the Benefits of Statin Treatment Titrated to Achieve Target Low-Density Lipoprotein Cholesterol Levels vs. a Fixed Dose Strategy?

### Summary

As in the 2016 USPSTF review, no study directly compared treatment with statins titrated to attain target cholesterol levels versus other (e.g., fixed-dose) treatment strategies. In indirect comparisons, there were no statistically significant group differences in risk of all-cause or cardiovascular mortality, MI, or stroke between three trials of statins versus placebo or no statin therapy that permitted limited dose titration and 19 trials of fixed-dose statin therapy.

### Evidence

As in the 2016 USPSTF review, no trial directly compared a strategy of titrating statin doses to achieve target LDL-C levels versus other (e.g., fixed statin dose) treatment strategies. Three primary prevention trials included in the 2016 USPSTF review (ACAPS,^81^ AFCAPS/TexCAPS,^79^ and MEGA^88^) permitted limited dose titration of statins, enabling indirect comparisons against 19 trials that utilized fixed doses (Table 4). In ACAPS (n=919), patients randomized to statin therapy were started on lovastatin 20 mg/day and could be titrated up to 40 mg/day or down to 10 mg/day to achieve a target LDL-C level of 90 to 110 mg/dL. In AFCAPS/TexCAPS (n=6,605), patients randomized to statin therapy were started on lovastatin at 20 mg/day, with titration to 40 mg/day to achieve a target LDL-C less than 110 mg/dL. In MEGA (n=7,832), patients randomized to statin therapy were started on pravastatin 10 mg/day, with titration to 20 mg/day to achieve a target total cholesterol level of less than 220 mg/dL.

There were no clear differences between trials that permitted limited dose titration to achieve target cholesterol levels compared with those that used fixed dose therapy. Although some pooled estimates favored dose titration, there were no statistically significant differences in pooled estimates when trials were stratified according to dosing strategy. However, estimates for trials that permitted dose titration were imprecise and primarily based on two trials^79,88^ (there were few events in the third trial^81^), with some statistical heterogeneity. Differences in pooled estimates between dose titrated and fixed dose statin therapy were somewhat more pronounced for all-cause mortality (RR 0.78, 95% CI, 0.48 to 1.28; I^2^=66% for dose titrated vs. RR 0.93, 95% CI, 0.87 to 0.99; I^2^=0% for fixed dose; p for interaction=0.50) and cardiovascular mortality (RR 0.61, 95% CI, 0.37 to 1.02; I^2^=9% vs. RR 0.93, 95% CI, 0.83 to 1.04; I^2^=0%, respectively; p for interaction=0.12). Dose titrated and fixed dose statin therapy were associated with similar risk estimates for fatal or nonfatal MI (RR 0.58, 95% CI, 0.44 to 0.77; I^2^=0% vs. RR 0.68, 95% CI, 0.60 to 0.77; I^2^=18%, respectively; p for interaction=0.32), revascularization (RR 0.66, 95% CI, 0.52 to 0.80; I^2^=0% vs. RR 0.73, 95% CI, 0.62 to 0.85; I^2^=23%; p for interaction=0.45) and composite cardiovascular events (RR 0.63, 95% CI, 0.53 to 0.76; I^2^=0% vs. RR 0.75, 95% CI, 0.66 to 0.85; I^2^=55%; p for interaction=0.15). For fatal or nonfatal stroke, the estimate for dose titrated statin therapy was imprecise (RR 0.42, 95% CI, 0.07 to 2.59; I^2^=50% vs. RR 0.79, 95% CI, 0.69 to 0.91; I^2^=23% for fixed dose therapy; p for interaction=0.50). Among the dose titrated trials, AFCAPS/TexCAPS did not report fatal or nonfatal stroke and ACAPS only reported five events, all of which occurred in the placebo arm.

## Key Question 2a What Are the Harms of Statins in Adults Without Prior CVD Events?

### Summary

Based on 19 trials (two added for this report),^66,67,73–79,81,84,86–90,93,96,101,106,116,125^ statin therapy was not associated with increased risk of study withdrawal due to adverse events (10 trials; N=43,783; RR 0.97, 95% CI, 0.78 to 1.19; I^2^=84%; ARD, 0.03%), serious adverse events (10 trials; N=55,419; RR 0.97, 95% CI, 0.93 to 1.01; I^2^=0%; ARD, 0.09%), any cancer (13 trials; N=71,733; RR 0.98, 95% CI, 0.91 to 1.04; I^2^=0%; ARD, −0.10%), cancer mortality (6 trials; N=45,064; RR 0.89, 95% CI, 0.66 to 1.19; I^2^=56%; ARD, −0.13%), myalgia (9 trials; N=46,388; RR 0.98, 95% CI, 0.86 to 1.11; I^2^=30%; ARD, 0.02%), elevated alanine aminotransferase (ALT) (10 trials; N=48,149; RR 0.94, 95% CI, 0.78 to 1.13; I^2^=0%; ARD, −0.03%), or elevated aspartate aminotransferase (AST) (4 trials; N=17,534; RR 1.30, 95% CI, 0.78 to 2.17; I^2^=35%; ARD, 0.21%). As in the 2016 USPSTF review, there was no association between statin therapy and increased risk of incident diabetes (6 trials; N=59,083; RR 1.04, 95% CI, 0.92 to 1.19; I^2^=52%; ARD, 0.11%), though statistical heterogeneity was present and one trial found high-intensity statin therapy associated with increased risk. Evidence on the association between statins and renal or cognitive harms remains sparse and did not indicate increased risk. One trial in the 2016 USPSTF review found statin therapy associated with increased risk of cataract surgery (3.8% vs. 3.1% after 6 years; RR 1.24, 95% CI, 1.03 to 1.49; ARD, 0.73%); no new primary prevention trial reported this outcome. Few serious adverse events were reported.

### Evidence

Nineteen trials (reported in 22 publications, N=75,005) and three observational studies (N=417,523) reported harms of statin therapy versus placebo or no statin therapy in adults without prior CVD events (Appendix B1).^66,67,73–79,81,84,86–90,93,94,96,101,106,116,125,132,133^ Two trials^84,106^ and one cohort study^94^ were added for this report; additional harms data from the previously included ASCOT-LLA trial were also added.^96^ Among the trials, sample sizes ranged from 250 to 17,802, and mean age ranged from 52 to 71 years. Mean LDL-C levels at baseline ranged from 108 to 191 mg/dL. Most trials (9 of 19) evaluated moderate-intensity statin therapy;^74,75,77,86,89,90,93,106,125^ three trials assessed low-intensity statin therapy,^73,81,88^ four trials assessed high-intensity statin therapy,^66,67,78,84^ two assessed both low and moderate-intensity statins,^79,87^ and one assessed both moderate and high-intensity statins.^76^ With the exception of cancer incidence reported for primary prevention participants in ALLHAT-LLT,^106^ ALLHAT-LLT and PROSPER were excluded from analysis of harms because more than 10 percent of patients had prior CVD events and harms were not reported separately for the primary prevention population, The observational studies were conducted in the United Kingdom (n=2,651),^133^ the United States (n=153,840),^132^ and Israel (n=261,032).^94^

#### Study Withdrawal Due to Adverse Events

Ten trials (N=43,783) reported risk of study withdrawal due to adverse events (Table 9).^74,78,79,81,87–89,93,96,116^ The pooled estimate indicated no difference in risk (10 trials; RR 0.97, 95% CI, 0.78 to 1.19; I^2^=84%; ARD, 0.03%, 95% CI, −1.21. to 1.26), though statistical heterogeneity was present (Appendix C18). In MEGA, statin therapy was associated with increased likelihood of withdrawal due to adverse events than placebo (11.0% vs. 8.4%; RR 1.31, 95% CI, 1.15 to 1.51)^88^ and in HOPE-3, statin therapy was associated with decreased risk (6.4% vs. 9.1%; RR 0.70, 95% CI, 0.62 to 0.79).^93^ The other eight trials found no difference between statin therapy versus placebo in risk of withdrawal due to adverse events.

Table 9 Harms of Statins vs. Placebo or No Statin in Randomized, Controlled Trials

Study name; Author, Year^*^; Followup; Quality | Withdrawals Due to Adverse events | Any Serious Adverse Events | Cancer | Diabetes | Muscle-related Harms | Other Serious Harms
ACAPS; Furberg, 1994^81^; 3 years; Fair | 0.7% (3/460) vs. 0.4% (2/459); RR 1.79 (95% CI, 0.30 to 11) | NR | Fatal cancer:; 0% (0/460) vs. 0.7% (3/459); RR 0.14 (95% CI, 0.007 to 2.75) | NR | NR | ALT elevation ≥2 times ULN:; 1.3% (6/460) vs. 1.3% (6/459); RR 1.00 (95% CI, 0.32 to 3.07)
AFCAPS/TexCAPS; Downs, 1998^79^; 5 years; Fair | 13.6% (449/3,304) vs. 13.8% (455/3301); RR 1.01 (95% CI, 0.98 to 1.14) | 34.2% (1,131/3,304) vs. 34.1% (1,126/3,301); RR 1.00 (95% CI, 0.94 to 1.07) | Any cancer; 7.6% (252/3,304) vs. 7.8% (259/3301); RR 0.97 (95% CI, 0.82 to 1.15); Fatal cancer; 1% (48/3,304) vs. 1% (34/3,301); RR 1.41 (95% CI, 0.91 to 2.19) | 2.3% (72/3094) vs. 2.4% (74/3117); RR 0.98 (95% CI, 0.71 to 1.35)^†^ | Myalgia; 0.3% (10/3304) vs. 0.3% (10/3301); RR 1.00 (95% CI, 0.42 to 2.40); Rhabdomyolysis; 0.03% (1/3304) vs. 0.06% (2/3301); RR 0.50 (95% CI, 0.05 to 5.51) | ALT or AST elevation ≥3 times ULN on consecutive visits:; 0.6% (18/3242) vs. 0.3% (11/3248); RR 1.64 (95% CI, 0.78 to 3.47)
ALLHAT-LLT; Han, 2017^106^; Primary prevention population ≥65 years | NR | NR | Fatal and nonfatal cancer; 8.9% (131/1467) vs. 6.2% (113/1400); RR 1.11 (95% CI, 0.87 to 1.41) | NR | NR | NR
ASCOT-LLA; Sever, 2003^90^; Collier, 2011^96^; 3 years; Fair | 3% (136/5,168) vs. 3% (131/5,137); RR 1.03 (95% CI, 0.81 to 1.31) | 22% (1,124/5,168) vs. 24% (1,218/5,137); RR 0.92 (95% CI, 0.85 to 0.98) | Any cancer; 5% (347/5,168) vs. 5% (352/5,137); RR 0.98 (95% CI, 0.85 to 1.1); Fatal cancer; 2% (79/5,168) vs. 2% (86/5,137); RR 0.91 (95% CI, 0.67 to 1.24) | 4% (201/5,168) vs. 3% (179/5,137); RR 1.12 (95% CI, 0.92 to 1.36) | Myalgia; 3% (143/5,168) vs. 3% (155/5,137); RR 0.92 (95% CI, 0.73 to 1.15); Rhabdomyolysis; 0.02% (1/5168) vs. 0% (0/5137); RR 3.00 (95% CI, 0.12 to 74) | Renal impairment; 0.6% (32/5158) vs. 0.5% (24/5137); HR 1.29 (95% CI, 0.76 to 2.19)
ASTRONOMER; Chan, 2010^67^; 4 years; Good | NR | 30.6% (41/134) vs. 35.6% (48/135); RR 0.86 (95% CI, 0.61 to 1.21) | Any cancer; Statin, 1.5% (2/134); Comparator, 2.2% (3/135); RR, 0.67 (95% CI, 0.11 to 3.96) | NR | NR | ALT elevation ≥3 times ULN:; Statin, 1.5% (2/134); Comparator, 2.2% (3/135); RR, 0.67 (95% CI, 0.11 to 3.96); AST elevation ≥3 times ULN:; Statin, 0.7% (1/134); Comparator, 0.7% (1/135); RR, 1.01 (95% CI, 0.06 to 16)
Beishuizen, 2004^75^; 2 years; Fair | NR | NR | Any cancer:; Statin, 3.9% (4/103); Comparator, 5.1% (4/79); RR, 0.77 (95% CI, 0.20 to 2.97) | NR | Myalgia:; Statin, 17.5% (18/103); Comparator, 32.9% (26/79); RR, 0.53 (95% CI, 0.31 to 0.90) | ALT elevation ≥3 times ULN:; Statin, 1.0% (1/103); Comparator, 0% (0/79); RR, 2.31 (95% CI, 0.10 to 56)
Bone, 2007^76^; 1 year; Fair | NR | Statin, 1.9% (9/485); Comparator, 2.5% (3/119); RR, 0.73 (95% CI, 0.20 to 2.68) | NR | NR | Myalgia:; Statin, 12.6% (61/485); Comparator, 6.7% (8/119); RR, 1.87 (95% CI, 0.92 to 3.80); Rhabdomyolysis:; Statin, 0% (0/485); Comparator, 0% (0/119); RR, 0.25 (95% CI, 0.005 to 12) | ALT or AST elevation ≥3 times ULN:; Statin, 0.4% (2/485); Comparator, 0% (0/119); RR, 1.23 (95% CI, 0.06 to 26)
CAIUS; Mercuri, 1996^86^; 3 years; Fair | NR | NR | Any cancer:; Statin, 2.0% (3/151); Comparator, 2.6% (4/154); RR, 0.76 (95% CI, 0.17 to 3.36) | NR | NR | NR
CARDS; Colhoun, 2004^77^; Newman, 2008^116^; 4 years; Good | Statin, 8.5% (122/1428); Comparator, 10.3% (145/1410); RR, 0.83 (95% CI, 0.66 to 1.04) | Statin, 1.3% (19/1428); Comparator, 1.4% (20/1410); RR, 0.94 (95% CI, 0.50 to 1.75) | Any cancer:; Statin, 4.8% (69/1428); Comparator, 5.1% (72/1410); RR, 0.95 (95% CI, 0.69 to 1.31); Fatal cancer:; Statin, 1.4% (20/1428); Comparator, 2.1% (30/1410); RR, 0.66 (95% CI, 0.38 to 1.15) | NR | Myalgia:; Statin, 4.3% (61/1428); Comparator, 5.1% (72/1410); RR, 0.83 (95% CI, 0.60 to 1.17); Rhabdomyolysis:; Statin, 0% (0/1428); Comparator, 0% (0/1410); RR, 0.99 (95% CI, 0.02 to 50); Myopathy:; Statin, 0.07% (1/1428); Comparator, 0.07% (1/1410); RR, 0.99 (95% CI, 0.06 to 16) | ALT elevation ≥3 times ULN:; Statin, 1.2% (17/1428); Comparator, 1.0% (14/1410); RR, 1.20 (95% CI, 0.59 to 2.42); AST elevation ≥3 times ULN:; Statin, 0.4% (6/1428); Comparator, 0.3% (4/1410); RR, 1.48 (95% CI, 0.42 to 5.24)
HOPE-3; Yusuf, 2016^93^; 6 years; Good | Statin, 6.4% (406/6361); Comparator, 9.1% (578/6344); RR, 0.70 (95% CI, 0.62 to 0.79) | Statin, 1.4% (91/6361); Comparator, 1.4% (92/6344); RR, 0.99 (95% CI, 0.74 to 1.32) | Statin, 4.1% (267/6361); Comparator, 4.5% (286/6344); RR, 0.93 (95% CI, 0.79 to 1.10) | Statin, 3.6% (232/6361); Comparator, 3.6% (226/6344); RR, 1.02 (95% CI, 0.86 to 1.23) | Rhabdomyolysis:; Statin, 0.02% (1/6361); Comparator, 0% (0/6344); RR, 2.99 (95% CI, 0.12 to 73); Myopathy:; Statin, 0.02% (1/6361); Comparator, 0.02% (1/6344); RR, 1.00 (95% CI, 0.06 to 16) | Need for cataract surgery:; Statin, 3.8% (241/6361); Comparator, 3.1% (194/6344); RR 1.24 (95% CI, 1.03 to 1.49)
HYRIM; Anderssen, 2005^73^; 4 years; Fair | NR | Serious adverse event rates were similar between groups; data not reported | NR | NR | NR | NR
JUPITER; Ridker, 2008^66^; 2 years; Good | NR | Statin, 15.2% (1352/8901); Comparator, 15.5% (1377/8901); RR, 0.98 (95% CI, 0.92 to 1.05) | Any cancer:; Statin, 3.3% (298/8901); Comparator, 3.5% (314/8901); RR, 0.95 (95% CI, 0.81 to 1.11); Fatal cancer:; Statin, 0.4% (35/8901); Comparator, 0.7% (58/8901); RR, 0.60 (95% CI, 0.40 to 0.92) | Statin, 3.0% (270/8901); Comparator, 2.4% (216/8901); RR, 1.25 (95% CI, 1.05 to 1.49) | Myalgia:; Statin, 16.0% (1421/8901); Comparator, 15.4% (1375/8901); RR, 1.03 (95% CI, 0.97 to 1.11); Rhabdomyolysis:; Statin, <0.1% (1/8901); Comparator, 0% (0/8901); Myopathy:; Statin, 0.1% (10/8901); Comparator, 0.1% (9/8901); RR, 1.11 (95% CI, 0.45 to 2.73) | Renal disorder:; Statin, 6.0% (535/8901); Comparator, 5.4% (480/8901); RR, 1.11 (95% CI, 0.99 to 1.26); Hepatic disorder:; Statin, 2.4% (216/8901); Comparator, 2.1% (186/8901); RR, 1.16 (95% CI, 0.96 to 1.41); ALT elevation ≥3 times ULN on consecutive visits:; Statin, 0.3% (23/8901); Comparator, 0.2% (17/8901); RR, 1.46 (95% CI, 0.95 to 2.25)
KAPS; Salonen, 1995^89^; 3 years; Good | Statin, 3.6% (8/224); Comparator, 5.4% (12/223); RR, 0.66 (95% CI, 0.28 to 1.59) | NR | Any cancer:; Statin, 0.5% (1/212); Comparator, 0% (0/212); RR, 3.00 (95% CI, 0.12 to 73) | NR | Myalgia:; Statin, 22.8% (49/214); Comparator, 20.2% (43/212); RR, 1.13 (95% CI, 0.78 to 1.62) | ALT ≥3 times ULN:; Statin, 1.8% (4/212); Comparator, 1.3% (3/212); RR, 1.45 (95% CI, 0.96 to 2.20)
MEGA; Nakamura, 2006^88^; 5 years; Fair | Statin, 11.0% (425/3866); Comparator, 8.4% (332/3966); RR, 1.31 (95% CI, 1.15 to 1.51) | NR | Any cancer:; Statin, 3.1% (119/3866); Comparator, 3.2% (126/3966); HR, 0.97 (95% CI, 0.76 to 1.25) | Statin, 5.7% (172/3013); Comparator, 5.3% (164/3073); RR, 1.07 (95% CI, 0.87 to 1.32)^†^ | Rhabdomyolysis:; Statin, 0%; Comparator, 0% | ALT >100 IU/L:; Statin, 2.8% (107/3866); Comparator, 2.8% (104/3966); RR, 1.06 (95% CI, 0.81 to 1.38); AST >100 IU/L:; Statin, 1.3% (50/3866); Comparator, 1.4% (55/3966); RR, 0.93 (95% CI, 0.64 to 1.36)
METEOR; Crouse, 2007^78^; 2 years; Fair | Statin, 11.3% (79/700); Comparator, 7.8% (22/281); RR, 1.44 (95% CI, 0.92 to 2.27) | Statin, 0.9% (6/700); Comparator, 0% (0/281); RR, 5.23 (95% CI, 0.30 to 93) | NR | NR | Myalgia:; Statin, 12.7% (89/700); Comparator, 12.1% (34/281); RR, 1.05 (95% CI, 0.73 to 1.52); Rhabdomyolysis:; Statin, 0%; Comparator, 0% | ALT ≥3 times ULN on at least 2 occasions:; Statin, 0.6% (4/700); Comparator, 0.4% (1/281); RR, 1.61 (95% CI, 0.18 to 14)
Muldoon, 2004^87^; 6 months; Fair | Statin, 3.9% (4/103); Statin, 2.9% (3/103); Comparator, 0% (0/102) | Serious adverse event leading to withdrawal:; Statin, 0.5% (1/206); Comparator, 0% (0/102) | NR | NR | NR | Cognitive adverse events; Performance improved in the placebo group but not the statin-exposed group on the Elithorn Maze (p=0.02), Recurrent Words (p=0.04), and 4-Word Short-Term Memory (p=0.05) tests. Groups differed at baseline on the Recurrent Words test.
PREVEND-IT; Asselbergs, 2004^74^; Fair | Statin, 3.0% (13/433); Comparator, 5.1% (22/431); RR, 0.59 (95% CI, 0.30 to 1.15) | NR | NR | NR | NR | NR
TRACE-RA; Kitas, 2019^84^; Fair | NR | Statin, 2.7%, (41/1504); Comparator 2.8% (42/1498); RR, 0.97 (95% CI, 0.64 to 1.49) | Any cancer:; 1.9% (28/1504) vs. 2.0% (30/1498); RR, 0.93 (95% CI, 0.56 to 1.55) | NR | NR | NR
WOSCOPS; Shepherd, 1995^125^; 5 years; Good | NR | NR | Any cancer:; Statin, 3.5% (116/3302); Comparator, 3.2% (106/3293); RR, 1.09 (95% CI, 0.84 to 1.41); Fatal cancer; Statin, 1.5% (49/3302); Comparator, 1.3% (44/3293); RR 1.11 (95% CI, 0.74 to 1.66) | Diabetes:; Statin, 1.9% (57/2999); Comparator, 2.8% (82/2975); HR, 0.70 (95% CI, 0.50 to 0.98) | Myalgia:; Statin, 0.6% (19/3302); Comparator, 0.6% (20/3293); RR, 0.95 (95% CI, 0.51 to 1.77) | ALT elevation ≥3 times ULN:; Statin, 0.5% (16/3302); Comparator, 0.6% (20/3293); RR 1.08 (95% CI, 0.41 to 1.54); AST elevation ≥3 times ULN:; Statin, 0.8% (26/3302); Comparator, 0.4% (12/3293); RR, 1.18 (95% CI, 0.92 to 1.50)
Pooled risk estimate | 10 trials; N=43,783; RR 0.97 (95% CI, 0.78 to 1.19; I^2^=84%) ARD, 0.03% (95% CI, −0.21 to 1.26) | 10 trials; N=55,419; RR 0.97 (95% CI, 0.93 to 1.01; I^2^=0%) ARD, 0.09% (95% CI, −0.67 to 0.49) | Any cancer; 13 trials; N=71,733; RR 0.98 (95% CI, 0.91 to 1.09; I^2^=0%) ARD, −0.10% (95% CI, −0.38 to 0.18); Fatal cancer; 6 trials; N=45,064; RR 0.89 (95% CI, 0.66 to 1.19); I^2^=56%; ARD, −0.13% (95% CI, −0.42 to 0.17) | 6 trials^†^; N=59,083; RR 1.04 (95% CI, 0.92 to 1.19); I^2^=52%; ARD, 0.11% (95% CI, −0.32 to 0.55) | Myalgia:; 9 trials; N=46,388; RR 0.98 (95% CI, 0.86 to 1.11); I^2^=30%; ARD, 0.02% (95% CI, −0.44 to 0.40); Rhabdomyolysis:; 8 trials; N=59,672; RR 1.54 (95% CI, 0.36 to 6.64); I^2^=0%; ARD, −0.03% (95% CI, −0.01 to 0.03); Myopathy:; 3 trials; N=33,345; RR 1.09 (95% CI, 0.48 to 2.47); I^2^=0%; ARD, 0.00% (95% CI, −0.04 to 0.04) | ALT elevation; 10 trials; N=48,149; RR 0.94 (95% CI, 0.78 to 1.13); I^2^=0%; ARD, −0.03% (95% CI, −0.20 to 0.014)

Abbreviations: ACAPS=Asymptomatic Carotid Artery Progression Study; AFCAPS/TexCAPS=Air Force/Texas Coronary Atherosclerosis Prevention Study; ALLHAT-LLT=Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial–Lipid-Lowering Trial; ALT=aspartate aminotransferase; ASCOT-LLA=Anglo-Scandinavian Cardiac Outcomes Trial–Lipid Lowering Arm; AST=alanine aminotransferase; ASTRONOMER=Aortic Stenosis Progression Observation=Measuring Effects of Rosuvastatin; CAIUS=Carotid Atherosclerosis Italian Ultrasound Study; CARDS=Collaborative Atorvastatin Diabetes Study; CI=confidence interval; HOPE-3=Heart Outcomes Prevention Evaluation; HR=hazard ratio; HYRIM=Hypertension High Risk Management; JUPITER=Justification for the Use of Statins in Prevention and Intervention Trial Evaluating Rosuvastatin; KAPS=Kuopio Atherosclerosis Prevention Study; MEGA=Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese; METEOR=Measuring Effects on Intima-Media Thickness: an Evaluation of Rosuvastatin; NR=not reported; PREVEND-IT=Prevention of Renal and Vascular Endstage Disease Intervention Trial; RR=relative risk; TRACE-RA=Trial of Atorvastatin for the Primary Prevention of Cardiovascular Events in Patients with Rheumatoid Arthritis; ULN=upper limit of normal; WOSCOPS=West of Scotland Prevention Study Group.

* Primary publication.

† Including unpublished data from Sattar et al.^134^

#### Serious Adverse Events

Ten trials (N=55,419) reported risk of serious adverse events (Table 9).^66,67,73,76,78,79,84,93,96,116^ There were no significant differences between treatment and placebo in risk of serious adverse events in any trial or when trials were pooled, based on seven trials (RR 0.97, 95% CI, 0.93 to 1.01; I^2^=0%; ARD, 0.09%, 95% CI, −0.67 to 0.49), (Appendix C19). Rates of serious adverse events with statin therapy varied substantially (0.9%^78^ to 34%^79^), due to differences in how serious adverse events were defined, methods used to ascertain adverse events, duration of followup, and other factors.

#### Cancer

Fourteen trials (reported in 15 publications, N=72,652) reported risk of cancer (Table 9).^66,67,75,77,79,81,84,86,88,89,93,96,106,116,125^ In pooled analyses, there were no difference between statin therapy and placebo or no statin in risk of any cancer (13 trials; RR 0.98, 95% CI, 0.91 to 1.04; I^2^=0%; ARD, −0.10%, 95% CI, −0.38 to 0.18)^66,67,75,77,79,84,86,88,89,93,96,106,125^ (Appendix C20) or fatal cancer (6 trials; RR 0.89, 95% CI, 0.66 to 1.19; I^2^=56%; ARD, −0.13%, 95% CI, −0.42 to 0.017)^66,77,79,81,96,125^ (Appendix C20). No trial found a difference between statins versus placebo in risk of any incident cancer. Rates of any cancer with statin therapy ranged from 0.5 to 7.6 percent. In JUPITER statins were associated with lower risk of fatal cancer versus placebo (0.4% vs. 0.7%; RR 0.60, 95% CI, 0.40 to 0.92).^66^ Five other trials that reported risk of fatal cancer reported no differences.^77,79,81,96,125^

#### New-Onset Diabetes

Six trials (reported in eight publications, N=59,083) and three observational studies (N=417,523) reported risk of new-onset diabetes (Tables 9 and 10; Appendix B4).^66,90,93,94,96,101,132,133^ Unpublished data on risk of diabetes from two other trials of statins in adults without prior cardiovascular events (MEGA and AFCAPS/TexCAPS) reported in a systematic review were also added.^134^ Based on a pooled analysis, there was no difference between statins versus placebo or no statin in risk of diabetes (6 trials; RR 1.04, 95% CI, 0.92 to 1.19; I^2^=52%; ARD, 0.11%, 95% CI, −0.32 to 0.55), though statistical heterogeneity was present (Appendix C21). Results using the profile likelihood method resulted in a similar estimate (RR 1.06, 95% CI, 0.89 to 1.19). The JUPITER trial was the only trial to find statin therapy associated with increased risk of diabetes (3.0% vs. 2.4%; RR 1.25, 95% CI, 1.05 to 1.49).^66^ The other five trials found no association between statin use and increased risk of diabetes. The WOSCOPS trial found that statin use was associated with reduced risk of diabetes (1.9% vs. 2.8%; HR 0.70, 95% CI, 0.50 to 0.98),^101^ and the ASCOT-LLA (3.9% vs. 3.4%; RR 1.12, 95% CI, 0.92 to 1.36)^96^ and HOPE-3 (3.6% vs. 3.6%; RR 1.02, 95% CI, 0.86 to 1.22, respectively)^93^ trials found little difference in risk. Both trials (MEGA and AFCAPS/TexCAPS) for which unpublished data on risk of diabetes were obtained found no association between statin use and diabetes (5.7% vs. 5.3%; RR 1.07, 95% CI, 0.87 to 1.32; and 2.3% vs. 2.3%; RR 0.98, 95% CI, 0.71 to 1.35).^134^

Table 10 Incident Diabetes in Observational Studies of Statin Use for Primary Prevention

Author, Year; Study/Database Name; Quality Rating | Sample Size Comparison | Factors Adjusted for in Analysis | Results
Culver, 2012^132^; U.K. General Practice Research Database; Moderate | 2,651; A) Diabetes cases (n=588); B) Matched controls (n=2,063) | BMI, hypertension, steroid use, smoking history, and number of visits to a general practitioner within 3 years | Statins vs. Nonstatins; Adjusted HR 1.48 (95% CI, 1.38 to 1.59)
Jick, 2004^133^; Women’s Health Initiative; Moderate | 153,840; A) Statin use (n=10,834); B) No statins (n=143,006) | Age, race/ethnicity, education, smoking history, BMI, physical activity, alcohol use, energy intake, family history of diabetes, and use of hormone therapy | Overall: HR 1.48 (95% CI, 1.38 to 1.59); High-intensity statin: HR 1.45 (95% CI, 1.36 to 1.61); Low-intensity statin: HR 1.48 (95% CI, 1.36 to 1.61)
Porath, 2018^94^; Maccabi Healthcare Services Database; Moderate | 261,032; A) Statins (n=43,229); B) No Statins (n=217,803) | Age, gender, total cholesterol, cardiovascular SCORE risk, adherence, and intensity level of the initial statin therapy | ≥5% 10-year CVD mortality risk:; <50% adherence: 9.0%; >50% adherence: 11.1%; No Statin: 10.6%; 1% to 5% 10-year CVD mortality risk:; <50% adherence: 5.6%; >50% adherence: 8.2%; No statin: 6.2%

Abbreviations: BMI=body mass index; CI=confidence interval; CVD=cardiovascular disease; HR=hazard ratio; SCORE = Systematic COronary Risk Evaluation.

Potential reasons for the discrepancy in estimates of diabetes risk include differences in the methods used to diagnose diabetes and differences in statin therapy intensity. In JUPITER, diagnosis of diabetes was based on physician report.^95^ In WOSCOPS,^101^ diagnosis of diabetes was based on a fasting plasma glucose level of greater than 126 mg/dL on at least two occasions, with an increase of at least 36 mg/dL from baseline; in ASCOT-LLA,^90^ as a fasting plasma glucose level of greater than 126 mg/dL; and in HOPE-3, as a fasting plasma glucose level of greater than 126 mg/dL or a hemoglobin A1c level greater than 110% the upper limit of normal.^93^ Methods for diagnosing diabetes in the MEGA and AFCAPS/TexCAPS trials were physician report, use of medication, or fasting plasma glucose of level of greater than 126 mg/dL.^134^ The pooled estimate was similar in a sensitivity analysis in which WOSCOPS diabetes incidence was based on less stringent alternative criteria for diabetes that excluded the requirement for an increase of at least 36 mg/dL from baseline (RR 1.07, 95% CI, 0.95 to 1.19; I^2^=33%).^134^ JUPITER was the only trial to use high-intensity statin therapy (see Key Question 3).

Three large observational studies also reported somewhat mixed findings regarding the association between statin use and incident diabetes, but differed in study design and methods for identifying diabetes (Table 10).^94,132,133^ A matched case-control study that used the U.K. General Practice Research Database to identify 588 diabetes cases and 2,063 matched controls (patients with prior MI excluded) found an odds ratio (OR) of 1.01 (95% CI, 0.80 to 1.40) with statin use versus nonuse, after adjustment for BMI, hypertension, steroid use, smoking history, and number of visits to a general practitioner within 3 years.^133^ The study did not control for statin intensity. An analysis from the Women’s Health Initiative of postmenopausal women (10,834 using statins and 143,006 not using statins) with no history of self-reported CVD found statin use associated with increased risk of incident diabetes (adjusted HR, 1.48, 95% CI, 1.38 to 1.59),^132^ after adjustment for age, race/ethnicity, education, smoking history, BMI, physical activity, alcohol use, energy intake, family history of diabetes, and use of hormone therapy. Results were similar when analyses were stratified according to use of high-intensity (HR 1.45, 95% CI, 1.36 to 1.61) or low-intensity statin therapy (HR 1.48, 95% CI, 1.36 to 1.61). A retrospective cohort study from Israel (n=261,032) assessed the incidence of new-onset diabetes among patients who newly started a low-intensity statin. Maximum followup was 5 years. Among persons at ≥5 percent 10-year cardiovascular mortality risk (based on the SCORE instrument), the risk of incident diabetes was similar among persons taking a statin (9.0% with adherence <50% and 11.1% for those with adherence >50%) and those not taking a statin (10.6%). Among persons at 1 percent to 5 percent 10-year cardiovascular mortality risk, the risk of incident diabetes was 8.2 percent among those taking a statin with adherence >50%, compared with 6.2 percent among those not taking a statin and 5.6 percent for those taking a statin with adherence <50%.

#### Muscle-Related Harms

Myalgia was reported in nine trials (N=46,388),^66,75–79,89,96,125^ myopathy in four trials, (N=39,950),^66,77,79,93^ and rhabdomyolysis in eight trials (N=59,672) (Table 9).^66,76–79,88,90,93^ There was no difference between statin therapy versus placebo or no statin in risk of myalgia (9 trials; RR 0.98, 95% CI, 0.86 to 1.11; I^2^=30%; ARD, 0.02%, 95% CI, −0.44 to 0.40) (Appendix C22). Rates of myalgia with statin therapy ranged from 0.3 to 22.8 percent. There was also no increased risk of myalgia in two trials that evaluated high-potency statin therapy (RR 1.03, 95% CI, 0.97 to 1.11^66^ and RR 1.05, 95% CI, 0.73 to 1.52^78^). Three trials found no difference between statin therapy versus placebo in risk of myopathy (RR 1.09, 95% CI, 0.48 to 2.47; I^2^=0%; ARD, 0.00%, 95% CI, −0.04 to 0.04) (Appendix C22),^66,77,93^ and another trial reported no cases of myopathy.^79^ No trial found statin therapy associated with increased risk versus placebo in risk of rhabdomyolysis, although the number of events was very small (3 events in one study,^79^ 1 event in three studies,^66,90,93^ and none in four studies^76–78,88^). The pooled estimate also indicated no association between statin therapy and increased risk of rhabdomyolysis, but the estimate was imprecise and only four trials reported events (RR 1.54, 95% CI, 0.36 to 6.64; I^2^=0%; ARD, 0.01%, 95% CI, −0.01 to 0.03) (Appendix C22).

#### Liver-Related Harms

Twelve trials (N=55,358) reported no difference between statin therapy versus placebo in risk of elevation in aminotransferase levels, although definitions varied with regard to degree of elevation, evaluation of aspartate and/or alanine aminotransferase, and requirement for single or repeatedly elevated levels (Table 8).^66,67,75–79,81,88,89,96,125^ There was no difference between statin therapy versus placebo or no statin in risk of ALT elevation (10 trials, N=48,149; RR 0.94, 95% CI, 0.78 to 1.13; I^2^=0%; ARD, −0.03%, 95% CI, −0.20 to 0.014), AST elevation (4 trials, N=17,534; RR 1.30, 95% CI, 0.78 to 2.17, I^2^=35%; ARD, 0.21%, 95% CI, −0.05 to 0.46), or elevation of either ALT or AST (2 trials, N=7,209; RR 1.61, 95% CI, 0.78 to 3.33, I^2^=0%; ARD, 0.22%, 95% CI, −0.09 to 0.53) (Appendix C23). One trial reported no difference between statins versus placebo in risk of (undefined) hepatic disorders (RR 1.16, 95% CI, 0.96 to 1.41).^66^ Very few serious liver-related harms were reported.

#### Other Harms

Two primary prevention trials (one using high-intensity rosuvastatin [n=17,802]^66^ and one using moderate-intensity atorvastatin [n=10,305]^90^) found no statistically significant differences between statin therapy versus placebo in risk of renal impairment (HR, 1.29, 95% CI, 0.76 to 2.19)^90^ and (RR 1.11, 95% CI, 0.99 to 1.26)^66^ (Table 9).

One trial reported the effect of statin treatment on scores on a series of cognitive tests.^87^ Statin-treated patients showed less improvement on tests previously shown to be sensitive to statin treatment (group difference in mean change of summary z-scores, 0.18, 95% CI, 0.07 to 0.29; p=0.002) and on several other tests (group difference in mean change of summary z-scores, 0.17, 95% CI, 0.05 to 0.29; p=0.007) but not on tests previously shown to be statin-insensitive (group difference in mean change of summary z-scores 0.02, 95% CI, −0.07 to 0.10; p=0.72), although the clinical importance of these findings is difficult to interpret (Table 9).

In HOPE-3, statin therapy was associated with increased risk of cataract surgery, which was unanticipated and not a predetermined outcome of the trial (3.8% vs. 3.1%; RR 1.24, 95% CI, 1.03 to 1.49).^93^ No other primary prevention trials reported this outcome.

## Key Question 2b Do the Harms of Statin Treatment Vary in Groups Defined by Demographic, Clinical, or Socioeconomic Characteristics?

### Summary

Evidence regarding how harms of statin therapy vary according to demographic or clinical characteristics was limited. There were no differences in harms of statin therapy based on within-study analyses stratified according to age (4 trials), sex (2 trials), or race/ethnicity (1 trial). In one trial, high intensity statin therapy was associated with increased risk of incident diabetes in persons with one or more diabetes risk factors, but not in those without any diabetes risk factor.

### Evidence

Four trials (in seven publications, N=38,806) reported harms of statin therapy versus placebo or no statin for primary prevention in groups defined by demographic and clinical characteristics (Appendix B1).^95–97,102,106,112,114^ The 2016 USPSTF review did not include a Key Question on how harms varied in groups. Three trials assessed harms varied by age,^96,102,106^ one by sex,^112^ and one by both age and sex;^114^ one of these trials (JUPITER)^95,97,102,112^ also evaluated how harms varied according to race/ethnicity^97^ and diabetes risk^95^ (Table 11). No trial analyzed how harms varied according to socioeconomic characteristics.

Table 11 Harms of Statins vs. Placebo or No Statin Based on Demographic and Clinical Characteristics

Study Name; Author, Year | Characteristic | Serious Adverse Events | Cancer | Diabetes | Muscle-Related Harms | Other Serious Harms
ALLHAT-LLT; Han, 2017^106^ | Age | NR | Cancer incidence; Age 65-74 years: 9.6% (105/1092) vs. 8.3% (87/1049); RR 1.16 (95% CI, 0.88 to 1.52); Age ≥75 years: 6.9% (26/375) vs. 7.4% (26/351); RR 0.94 (95% CI, 0.55 to 1.58) | NR | NR | NR
ASCOT-LLA; Collier, 2011^96^ | Age | Age <65 years: 18% (548/2,979) vs. 21% (602/2,881); RR 0.88 (95% CI, 0.79 to 0.98); Age ≥65 years: 26% (576/2,189) vs. 27% (616/2,256); RR 0.96 (95% CI, 0.87 to 1.06) | Cancer incidence; Age <65 years: 5% (137/2,9279) vs. 5% (138/2,881); RR 0.96 (95% CI, 0.76 to 1.21); Age ≥65 years: 10% (210/2,189) vs. 10% (214/2,256); RR 1.01 (95% CI, 0.84 to 1.21); Cancer mortality; Age <65 years: 0.6% (18/2,979) vs. 0.8% (23/2,881); RR 0.76 (95% CI, 0.41 to 1.40); Age ≥65 years: 3% (61/2,189) vs. 3% (63/2,256); RR 1.00 (95% CI, 0.70 to 1.41) | Age <65 years: 5% (140/2,979) vs. 4% (109/2,881); RR 1.24 (95% CI, 0.97 to 1.59); Age ≥65 years: 3% (61/2,189) vs. 3% (70/2,256); RR 0.90 (95% CI, 0.64 to 1.26) | Myalgia; Age <65 years: 3% (57/2,189) vs. 3% (74/2,256); RR 1.03 (95% CI, 0.76 to 1.38); Age ≥65 years: 3% (86/2,979) vs. 3% (81/2,881); RR 0.79 (95% CI, 0.56 to 1.11) | Renal impairment:; Age <65 years: 5% (140/2,979) vs. 4% (109/2,881); RR 1.24 (95% CI, 0.97 to 1.59); Age ≥65 years: 3% (61/2,189) vs. 3% (70/2,256); RR 0.90 (95% CI, 0.64 to 1.26); ALT elevation >3 times ULN:; Age <65 years: 1% (33/2,979) vs. 2% (55/2,881); RR 0.58 (95% CI, 0.38 to 0.89); Age ≥65 years: 0.5% (11/2,189) vs. 0.7% (16/2,256); RR 0.71 (95% CI, 0.33 to 1.52)
JUPITER; Glynn, 2010^102^ | Age | <70 years: HR 0.93 (95% CI, 0.84 to 1.03); ≥70 years: HR, 1.05 (95% CI, 0.93 to 1.17) | Cancer incidence; <70 years: HR 0.98 (95% CI, 0.79 to 1.22); ≥70 years: HR 0.91 (95% CI, 0.73 to 1.14); Cancer mortality; <70 years: HR 0.63 (95% CI, 0.35 to 1.16); ≥70 years: HR 0.58 (95% CI, 0.32 To 1.03) | <70 years: HR 1.26 (95% CI, 1.02 to 1.56); ≥70 years: HR 1.25 (95% CI, 0.90 to 1.74) | Myopathy; <70 years: HR 1.01 (95% CI, 0.33 to 3.14); ≥70 years: HR 1.31 (95% CI, 0.29 to 5.84); Rhabdomyolysis; No events reported in either age group | Renal impairment; <70 years: HR 1.10 (95% CI, 0.94 to 1.29); ≥70 years: HR 1.14 (95% CI, 0.94 to 1.39)
JUPITER; Mora, 2010^112^ | Sex | Women: 14.7% (503/3,426) vs 14.2% (481/3,375); RR 1.03 (95% CI, 0.91 to 1.15); Men: 15.5% (849/5,475) vs. 16.2% (896/5,526); RR 0.96 (95% CI, 0.88 to 1.05) | Cancer incidence; Women: 2.9% (100/3,426) vs. 2.8% (94/3,375); RR 1.05 (95% CI, 0.79 to 1.38); Men: 3.6% (198/5,475) vs. 4.0% (220/5,526); RR 0.91 (95% CI, 0.76 to 1.10); Cancer mortality; Women: 0.4% (12/3,426) vs. 0.5% (17/3,375); RR 0.70 (95% CI, 0.33 to 1.46); Men: 0.4% (23/5,475) vs. 0.7% (41/5,526); RR 0.57 (95% CI, 0.34 to 0.94) | Women: 3.2% (108/3,426) vs. 2.1% (71/3,375); RR 1.48 (95% CI, 1.10 to 1.99); Men: 1.67% (162/5,475) vs. 2.6% (145/5,526); RR 1.12 (95% CI, 0.90 to 1.40) | Myopathy; Women: 0.1% (5/3,426) vs. 0.1% (4/3,375); RR 1.23 (95% CI, 0.33 to 4.58); Men: 0.1% (5/5,475) vs. 0.1% (5/5,526); RR 1.01 (95% CI, 0.29 to 3.48); Rhabdomyolysis; 1 event reported in men receiving statin therapy | Renal impairment; Women: 4.8% (166/3,426) vs. 4.0% (135/3,375); RR 1.21 (95% CI, 0.96 to 1.50); Men: 6.7% (369/5,475) vs. 6.2% (345/5,526); RR 1.07 (95% CI, 0.93 to 1.24); Hepatic disorder; Women: 1.7% (57/3,426) vs.1.9% (63/3,375); RR 0.89 (95% CI, 0.62 to 1.27); Men: 2.9% (159/5,475) vs. 2.2% (123/5,526); RR 1.30 (95% CI, 1.03 to 1.64); ALT >3x ULN; Women: 0.001% (3/3,426) vs. 0.1% (5/3,375); RR 0.59 (95% CI, 0.14 to 2.47); Men: 0.4% (20/5,475) vs. 0.2% (12/5,526); RR 1.68 (95% CI, 0.82 to 3.43)
MEGA; Nakaya, 2011^114^ | Sex and age | Age < 45; - Men: 7% (10/141) vs. 4% (5/141); p=0.18; - Women: 12% (2/17) vs. 0% (0/6); p=0.38; Age 45 to 49; - Men: 7% (16/223) vs. 4% (8/220); p=0.10; - Women: 9% (11/128) vs. 5% (5/110); p=0.21; Age 50 to 54; - Men: 11% (25/227) vs. 7% (17/231); p=0.18; - Women: 6% (27/454) vs. 7% (31/476); p=0.72; Age 55-59; - Men: 10% (19/199) vs. 14% (28/208); p=0.22; - Women: 9% (61/659) vs. 7% (52/701); p=0.22; Age 60-64; - Men: 14% (32/235) vs. 18% (41/230); p=0.21; - Women: 10% (68/696) vs. 9% (62/716); p=0.47; Age ≥65; - Men: 25% (50/203) vs. 25% (54/218); p=0.97; - Women: 12% (83/684) vs. 13% (92/709); p=0.64 | NR | NR | NR | NR
JUPITER; Albert, 2011^97^ | Race/ethnicity | Event rate per 100-person years; White: 8.43 vs. 8.73; p=0.41; Black: 4.93 vs. 5.07; p=0.92; Hispanic: 4.75 vs. 4.55; p=0.80 | NR | Event rate per 100-person years; White: 1.34 vs. 1.13; p=0.09; Black: 1.81 vs. 0.94; p=0.02; p for interaction=0.10; Hispanic: 1.19 vs. 1.16; p=0.89; p for interaction=0.63; Black participants vs. White participants receiving statins: HR 1.38 (95% CI, 1.04 to 1.85) | Event rate per 100-person years Myopathy; White: 0.002 vs. 0.004; p=0.31; Black: 0.26 vs. 0.10; p=0.22; Hispanic: 0.10 vs. 0 | Event rate per 100-person years ALT >3X ULN; White:0.08 vs. 0.10; p=0.69; Black: 0.36 vs. 0.10; p=0.08; Hispanic: 0.10 vs. 0.05; p=0.55
JUPITER; Ridker, 2012^95^ | Diabetes | NR | NR | ≥1 diabetes risk factor: HR 1.28 (95% CI, 1.07 to 1.54); No diabetes risk factor: HR 0.99 (95% CI, 0.45 to 2.21) | NR | NR

Abbreviations: ALLHAT-LLT= Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial–Lipid-Lowering Trial; ALT= aspartate aminotransferase; ASCOT-LLA= Anglo-Scandinavian Cardiac Outcomes Trial–Lipid Lowering Arm; CI=confidence interval; HR=hazard ratio; JUPITER= Justification for the Use of Statins in Prevention and Intervention Trial Evaluating Rosuvastatin; MEGA= Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese; NR=not reported; RR=relative risk; ULN=upper limit of normal.

#### Age

Three trials found no difference in harms of statin therapy according to age^96,102,106^ (Table 11). ASCOT-LLA (n=10,305) found that statin therapy was not associated with increased risk of any harm versus placebo in groups stratified according to age (older or younger than 65 years), though harms incidence was higher in the older age group with or without statin therapy.^96^ JUPITER (n=17,802) also found no difference between statin therapy versus placebo in risk of harms when participants were stratified according to age (older or younger than 70 years), with no statistically significant interactions (p>0.10).^102^ An analysis from ALLHAT-LLT evaluated incident cancer risk among primary prevention participants 65 years or older (n=2,867) stratified by age (65 to 74 years vs. 75 years or older), but estimates were imprecise (9.6% vs. 8.3%, RR 1.16, 95% CI, 0.88 to 1.52 versus 6.9% vs. 7.4%, RR 0.94, 95% CI, 0.55 to 1.58, respectively).^106^

#### Sex

Two trials assessed harms stratified by sex (Table 11).^112,114^ JUPITER (n=17,802) found statin therapy associated with increased risk of incident diabetes versus placebo in women (3.2% vs. 2.1%, HR 1.49, 95% CI, 1.11 to 2.01), but not in men (3.0% vs. 2.6%, HR 1.14, 95% CI, 0.91 to 1.43).^112^ However, the interaction between sex and effects of statin therapy on incident diabetes risk was not statistically significant (p=0.16). The risk of other harms in JUPITER were similar in men and women. MEGA (n=7,832) found no differences between men and women in risk of harms of statin therapy versus placebo when participants were further stratified into six different age categories.^114^ There were also no differences in harms based on age.

#### Race and Ethnicity

JUPITER (n=17,168 included in this analysis) assessed how risk of harms of statin therapy versus placebo varied according to race/ethnicity, categorized as Black, White, or Hispanic (Table 11).^97^ Statin therapy was associated with increased risk of incident diabetes versus placebo among Black persons (1.81 vs. 0.94 per 100 person-years, p=0.02), but there were no statistically significant interactions between race/ethnicity and effects of statins on incident diabetes risk (p for interaction=0.10 for Black vs. White and 0.63 for Hispanic vs. White). For other adverse events (serious adverse events, myopathy, renal dysfunction, alanine aminotransferase elevation) there were no differences between statin therapy versus placebo in any of the racial/ethnic groups, though some estimates were imprecise.

#### Clinical Characteristics

In a stratified analysis of data from JUPITER (n=17,802), statin therapy was associated with higher risk of incident diabetes versus placebo among participants with one or more diabetes risk factors (including metabolic syndrome, impaired fasting glucose, BMI >30 kg/m^2^, and a hemoglobin A1c level of >6.0%), with no increased risk among those without diabetes risk factors (Table 11; HR, 1.28, 95% CI, 1.07 to 1.54 vs. HR, 0.99, 95% CI, 0.45 to 2.21, respectively).^95^

## Key Question 3 How Do the Benefits and Harms of Statin Treatment Vary According to Its Intensity?

### Summary

Direct evidence comparing different intensity statins remains limited. One new trial found no difference between higher versus lower intensity statin therapy (based on LDL-C target) in risk of cardiovascular outcomes, but differences between groups in LDL-C levels and statin doses at the end of the trial were small. Based on across-study comparisons of placebo-controlled trials of statin therapy, there was no association between higher statin intensity for primary prevention and greater benefits or harms.

### Evidence

In 18 trials of statins versus placebo or no statin for primary prevention, statin intensity (based on 2018 ACC/AHA guideline^64^ categories) was low (<30% estimated average LDL-C reduction) in two trials,^73,88^ moderate (30% to 49% average LDL-C reduction) in 12 trials (two^80,91^ added for this update)^74,^ ^75,^ ^77,80,82,85,86,89–91,93,125^ and high (≥50% LDL-C reduction) in four trials (one^84^ added for this update)^66,67,78,84^ (Table 4). Two trials^76,87^ included in the 2016 USPSTF review evaluated fixed-dose statin regimens in multiple categories. Among three trials that permitted dose titration, two trials started patients with a low-intensity statin but permitted dose titration to moderate intensity if target cholesterol levels were not achieved.^79,81^ and one trial permitted dose titration within the low-intensity category.^88^ One new trial (EMPATHY, n=5,144) compared more versus less intensive statin therapy based on LDL targets (<70 mg/dL vs. 100 to 120 mg/dL).^83^

#### Benefits

Direct evidence on clinical outcomes associated with differential intensity of statin therapy remains extremely limited. The new EMPATHY trial (n=5,144) found no differences between statin therapy targeted to LDL-C <70 versus 100-120 mg/dL on cardiovascular outcomes in patients with diabetic retinopathy.^83^ However, findings are limited because there was little differential between groups in achieved LDL-C (between-group difference 27.7 mg/dL) and differences between groups in statin dosing at the end of the trial were very small. For example, among patients prescribed pravastatin, the final dose was 9.9 mg in the higher intensity arm and 7.3 mg in the lower intensity arm, both of which are low intensity according to ACC/AHA classification (Appendix B2). Two trials included in the prior USPSTF review evaluated different statin intensities, but were not adequately powered to detect differences between statin intensities and their effect on clinical outcomes.^76,87^ One trial of women (n=485 randomized to statin therapy) with moderate dyslipidemia reported no deaths in women randomized to either atorvastatin 10 or 20 mg/day (moderate-intensity) or 40 or 80 mg/day (high-intensity).^76^ The other trial, which enrolled men or women (n=206 randomized to statin therapy) with moderate dyslipidemia, reported no stroke events in patients randomized to simvastatin 10 mg/day (low-intensity) and one event in patients randomized to 40 mg/day (moderate-intensity).^87^ A third trial, which permitted dose titration from low-intensity (20 mg/day lovastatin) to moderate-intensity (40 mg/day lovastatin) did not report on differences in clinical outcomes between patients who remained on low-intensity therapy (n=1,647) versus those who were titrated to moderate-intensity therapy (n=1,657).^79^

Indirect, across-study comparisons of trials of statins versus placebo or no statin stratified according to the intensity of therapy did not indicate a dose-dependent association. For all-cause mortality, risk estimates overlapped for trials of low-intensity (2 trials; RR 0.72, 95% CI, 0.52 to 1.00; I^2^=0%; ARD −0.55%, 95% CI, −1.10 to 0.00),^73,88^ moderate-intensity (10 trials; RR 0.95, 95% CI, 0.89 to 1.02; I^2^=0%; ARD −0.40%, 95% CI, −0.79 to −0.01),^74,75,77,80,85,89–93^ and high-intensity statins (3 trials; RR 0.81, 95% CI, 0.68 to 0.97; I^2^=0%; ARD −0.23%, 95% CI, −0.78 to 0.32; p for interaction=0.08) without a dose response.^66,78,84^ Estimates for composite cardiovascular outcomes were also similar for low- (2 trials; RR 0.68, 95% CI, 0.51 to 0.90; I^2^=0%; ARD −0.86%, 95% CI, −1.48 to −0.23),^73,88^ moderate- (9 trials; RR 0.79, 95% CI, 0.70 to 0.90; I^2^=46%; ARD −1.42%, 95% CI, −2.07 to −0.76),^74,75,77,82,85,90–93^ and high-intensity statins (2 trials; RR 0.58, 95% CI, 0.48 to 0.70; I^2^=0%; ARD −1.16%, 95% CI, −1.56 to −0.76;^84,119^ p for interaction=0.03). For other clinical outcomes, evidence for the low- or high-intensity statin categories was too limited for meaningful comparisons.

A 2012 analysis from the Cholesterol Treatment Trialists’ Collaboration did not meet inclusion criteria because it included trials of statin therapy in persons with prior cardiovascular events and was based on an analysis of response to treatment (degree of LDL-C lowering), but may provide some indirect evidence about effects of statin therapy intensity.^135^ Based on data from 22 trials, it found greater LDL-C reduction with a statin associated with decreased risk of all-cause mortality (RR 0.91, 95% CI, 0.85 to 0.97 per 38 mg/dL reduction in LDL-C) and a composite outcome of nonfatal MI, CHD death, stroke, or coronary revascularization (RR 0.75, 95% CI, 0.70 to 0.80 per 38 mg/dL reduction in LDL-C) in persons without vascular disease at baseline. Results were also consistent for specific cardiovascular outcomes (including major coronary events [nonfatal MI and CHD death], fatal or nonfatal stroke, and coronary revascularization).

#### Harms

No new trial provided direct evidence on how harms of statin therapy vary according to statin intensity. Based on indirect evidence from trials included in the prior USPSTF review, there was no increased risk of diabetes in two trials of low-intensity statins (pooled RR 1.04, 95% CI, 0.88 to 1.24)^79,88^ or three trials of moderate-intensity statins (pooled RR 0.96, 95% CI, 0.75 to 1.22; I^2^=67%).^90,93,125^ The JUPITER trial found high-intensity statin therapy associated with increased risk of incident diabetes (RR 1.25, 95% CI, 1.05 to 1.49);^66,95^ no other trial of high intensity statin therapy reported incident diabetes. There were also no differences in risk of any cancer when studies were stratified according to low- (2 trials; pooled RR 0.97, 95% CI, 0.85 to 1.11; I^2^=0%),^79,88^ moderate- (7 trials; pooled RR 1.10, 95% CI, 0.89 to 1.36; I^2^=57%),^75,77,80,86,89,93,125^ or high-intensity statins (3 trials; pooled RR 0.95, 95% CI, 0.81 to 1.10; I^2^=0%).^66,67,84^ One trial found no difference between low- and moderate-intensity statin in risk of aminotransferase elevation more than 3 times the upper limit of normal (0.7% vs. 0.4%; RR 1.64, 95% CI, 0.64 to 4.23) or creatine kinase elevations greater than 10 times the upper limit of normal (0.7% vs. 0.6%; RR 1.15, 95% CI, 0.49 to 2.70).

## Contextual Question 1 What Are the Effects of Initiating Statins for Primary Prevention at Different Cardiovascular Risk Thresholds on the Number of Persons Eligible for Treatment and Potential Benefits and Harms (Including Modeling Studies)?

Six studies compared effects of initiating statins for primary prevention based on different criteria or thresholds on the number of persons eligible for treatment (Table 12).^136–141^ The studies compared expanded versus standard guideline criteria, different guidelines, or different approaches for predicting benefit. Four studies utilized modeling to estimate benefits and harms (one modeling study estimated cost-effectiveness).^136^ In the modeling analyses, the studies assumed that benefits of statins observed in randomized primary prevention trials among persons with cardiovascular risk factors are also present in persons without cardiovascular risk factors. However, persons without cardiovascular risk factor have not been evaluated in primary prevention trials (see Key Question 1a). Two studies evaluated statin eligibility using different criteria without estimating effects on clinical outcomes.^137,140^

Table 12 Contextual Question 1: Effects of Initiating Statin Therapy at Difference Risk Thresholds

Author, Year | Study Design Database/Cohort | Sample Size Comparisons | Results
Kohli-Lynch, 2019^136^ | Modeling (cost-effectiveness); National Health and Nutritions Examination Survey | Statin treatment approach with 2013 ACC/AHA: 1) Treat all patients with ≥7.5% 10-yr risk, diabetes or LDL of ≥190 mg/dL (2013 ACC/AHA guideline); 2) Add treatment for borderline risk and LDL levels of 160 to 189 mg/dL (adds 2 million eligible adults); 3) Add treatment for borderline risk, and LDL levels of 130 to 189 mg/DL (adds 4 million eligible adults); 4) Add treatment for patients with ≥5% 10-yr risk (adds 5 million eligible adults) | Incremental costs/incremental QALYs; Treatment approach 1: $215,620,354,226/22,496,585; Treatment approach 2: Cost-saving (-$12.6 million/+1,108); Treatment approach 3: Cost-saving (-$13.5 million/+2,445); Treatment approach 4: ICER: $33,558/QALY (+$21.3 million/+3,483)
Miedema, 2018^137^ | Analysis of prospective cohort study; Multi-Ethnic Study of Atherosclerosis | 4,962; USPSTF 2016 Guidelines vs. 2013 ACC/AHA | USPSTF vs. ACC/AHA; Statin Eligibility; Baseline: 34.4% (1,709/4,962) vs. 49.1% (2,436/4,962); Followup: 39.1% (1,940/4,962) vs. 59% (2,932/4,962), 15% absolute decrease
Mortensen, 2019^138^ | Modeling; Copenhagen General Population Study | 45,750; A) Canadian Cardiovascular Society; B) ACC/AHA 2018 Guidelines; C) National Institute for Health and Care Excellence; D) US Preventive Services Task Force; E) European Society of Cardiology/European Atherosclerosis Society | A vs. B vs. C vs. D vs. E; Statin eligibility; 44% vs. 42% vs. 40% vs. 31% vs. 15%; Sensitivity/Specificity for atherosclerotic cardiovascular events; 68%/59% vs. 70%/60% vs. 68%/63% vs. 57%/72% vs. 24%/86%; NNT (moderate-intensity statin); 32 vs. 30 vs. 30 vs. 27 vs. 29; NNT (high-intensity statin); 21 vs. 20 vs. 20 vs. 18 vs. 20
Pletcher, 2017^139^ | Modeling; NHANES | 2,627 participants representing ~57.7 million statin-eligible Americans; A) >2.3% absolute benefit threshold; B) >7.5% 10-year threshold; C) >10% 10-year threshold | A vs. B vs. C; Prevented atherosclerotic cardiovascular disease events; 5.7% (95% CI, 4.8 to 6.7) vs. 4.4% (95% CI, 3.7 to 5.2) vs. 3.2% (95% CI, 2.6 to 3.7); NNT over 10 years to prevent one event; 24.2 (95% CI, 23.1 to 25.4) vs. 21.2 (95% CI, 20.4 to 22.0) vs. 19.1 (95% CI, 18.3 to 19.9)
Shah, 2017^140^ | Analysis of prospective, community-based study; Jackson Heart Study | 2,812 (100% Black race); USPSTF 2016 Guidelines vs. 2013 ACC/AHA | USPSTF vs. ACC/AHA; 38.1% (1,072/2,812) vs. 49.9% (1,404/2,812); Risk difference; 11.8% (95% CI, 10.5 to 13.1)
Thankassoulis, 2016^141^ | Modeling; NHANES | 2,134 participants representing ~71.8 million statin-eligible Americans; A) ≥2.3% 10-year absolute risk reduction benefit threshold; B) ≥7.5% 10-year threshold | 9.5 million additional individuals identified as statin eligible using ≥2.3% threshold compared with ≥7.5% threshold, and preventing of estimated 266,508 cardiovascular events over 10 years.

Abbreviations: ACC/AHA=American College of Cardiology/American Heart Association; CI=confidence interval; ICER=incremental cost-effectiveness ratio; LDL=low-density lipoprotein; NHANES=National Health and Nutrition Examination Survey; NNT=number needed to treat; QALY=quality-adjusted life-year; US=United States; USPSTF=United States Preventive Services Task Force.

One modeling study compared standard care for determining eligibility for statins for primary prevention, based on the 2013 ACC/AHA guideline (10-year risk ≥7.5%, LDL cholesterol ≥190 mg/dL, or diabetes mellitus), versus three strategies: 1) add patients with 10-year risk of 5.0% to 7.5% and LDL cholesterol of 160 to 189 mg/dL (2 million additional eligible US adults); 2) add patients with 10-year risk of 5.0% to 7.5% and LDL cholesterol of 130 to 189 mg/dL (4 million additional eligible US adults compared with strategy 1); and 3) add patients with 10-year risk of ≥5.0% regardless of LDL cholesterol level (5 million additional eligible US adults compared with strategy 2).^136^ The study found that the strategies of adding patients with 10-year risk of risk of 5.0% and 7.4% and LDL of 160 to 189 mg/dL or 130 to 159 mg/dL as eligible for statin therapy were cost savings (associated with lower costs and greater quality-adjusted life-years) compared with standard care (Table 12). The strategy of expanding statin eligibility to all persons with assessed 10-year risk of ≥5% (regardless of LDL cholesterol level) was associated with an incremental cost-effectiveness ratio of $33,558/QALY.

A study conducted using data from a Danish general population cohort (the Copenhagen General Population Study) estimated statin eligibility among 45,750 individuals according to 5 guidelines: the Canadian Cardiovascular Society (CCS), ACC/AHA (2018), National Institute for Health and Care Excellence (NICE), USPSTF, and European Society of Cardiology/European Atherosclerosis Society (ESC/EAS).^138^ Fewer patients were eligible for statin therapy according to the USPSTF guideline compared with the CCS, ACC/AHA, and NICE guidelines (31% vs. 40% to 44%). Against these guidelines, the USPSTF guideline was associated with lower sensitivity for identifying patients who subsequently experienced atherosclerotic cardiovascular events (57% vs. 68% to 70%), but higher specificity (72% vs. 59% to 63%). Modeling the effects of statin therapy, the USPSTF guideline was slightly more efficient, based on a lower number needed to treat for 10 years to prevent one atherosclerotic event (27 for moderate intensity and 18 for high intensity statin therapy vs. 30 to 32 and 20 to 21, respectively). The ESC/EAS guideline resulted in the fewest persons eligible for statin therapy (15%) and lowest sensitivity (24%), with a similar number needed to treat compared with the USPSTF guideline.

Two studies found application of USPSTF criteria associated with lower proportions of statin-eligible patients versus application of the 2013 ACC/AHA criteria.^137,140^ A study based on the Multi-Ethnic Study of Atherosclerosis (MESA) cohort (n=4,962; 38% White, 28% Black, 23% Hispanic, 12% Chinese American)^137^ found application of USPSTF criteria associated with a 15 percent absolute decrease in the proportion eligible for statin therapy compared with the 2013 ACC/AHA criteria. A study conducted using data from the Jackson Heart Study (2,812 Black persons) found application of USPSTF criteria associated with a 12 percent decrease in the proportion eligible for statin therapy.^140^ Neither study was designed to evaluate effects of different statin eligibility criteria on clinical outcomes.

Two modeling studies compared an individualized statin benefit approach versus a standard risk based approach for determining statin eligibility.^139,141^ In the standard risk-based approach, assessment of eligibility is based on assessed 10-year cardiovascular risk being above a specified threshold; relative benefits are assumed to be similar at different levels of assessed risk, resulting in higher estimated absolute benefits directly correlating with higher risk. The individualized statin benefit approach, by contrast, assumes that persons at similar estimated 10-year cardiovascular risk may experience different benefits. For example, a patient with assessed 10-year risk of 7% with high LDL-C may experience greater absolute benefit than a patient with the same assessed 10-year risk but low LDL-C. Similarly, relative benefit may vary according to baseline risk: for example, the Cholesterol Treatment Trialists’ (CTT) Collaboration individual patient data meta-analysis of statin trials found that the relative risk per 1 mmol/L reduction in LDL cholesterol was 0.68 (95% CI, 0.62 to 0.74) in persons at <10% estimated risk compared with 0.79 to 0.81 in persons at ≥10% risk.^142^ If relative benefits of statin therapy are larger in persons at lower cardiovascular risk, potential benefits of statins would be underestimated in such persons using a standard risk based approach. In an individualized statin benefit approach, statin eligibility is based on patients being above a threshold for expected benefit, rather than above a threshold for assessed risk.

Both studies found an individualized statin benefit approach associated with a greater reduction in adverse cardiovascular outcomes compared with a standard risk-based approach, though there was some loss of efficiency (higher number needed to treat with statin to prevent a cardiovascular event). The studies utilized National Health and Nutrition Examination Survey (NHANES) data, with prediction of individualized statin benefit based on 10-year risk according to the Pooled Cohort Equations and corresponding CTT relative risk reduction estimates. In one study, applying a ≥2.3% 10-year absolute risk reduction benefit threshold identified 9.5 million additional individuals eligible for statin compared with applying a ≥7.5% 10-year cardiovascular risk threshold, resulting in prevention of an additional estimated 266,508 cardiovascular events over 10 years.^141^ In the other study, applying a >2.3% absolute benefit threshold resulted in a slightly higher proportion of atherosclerotic cardiovascular disease events prevented versus a >7.5% or >10% 10-year risk threshold (5.7%, 95% CI, 4.8 to 6.7 vs. 4.4%, 95% CI, 3.7 to 5.2 or 3.2%, 95% CI, 2.6 to 3.7, respectively) but was less efficient (number needed to treat over 10 years to prevent 1 event 24.2, 95% CI, 23.1 to 25.4 vs. 21.2, 95% CI, 20.4 to 22.0 or 19.1, 95% CI, 18.3 to 19.9, respectively).^139^ Limitations of the studies include reliance on the CTT analysis^142^ (which included trials of secondary prevention and analyzed effects of statins based on degree of LDL lowering) and lack of validation of the method used to predict statin benefit. In addition, primary prevention trials did not indicate a difference in relative benefits of statins based on estimated 10-year cardiovascular risk, baseline LDL cholesterol, and other demographic and clinical factors (see Key Question 1b). No study compared an individualized statin benefit versus a risk-based approach in a clinical population.

## Contextual Question 2 How Do Patient Preferences Regarding Use of Statins for Primary Prevention Vary at Different Cardiovascular Risk Thresholds?

Evidence on how patient preference regarding use of statins for primary prevention vary at different cardiovascular risk thresholds is very limited. A cross-sectional survey of 304 individuals 40 to 75 years old not previously treated with a statin or proprotein convertase subtilisin/kexin type 9 inhibitor in the last 3 years found that patients who wanted to take statin therapy increased as their 10-year predicted cardiovascular risk increased, though preferences were relatively stable at intermediate (≥5 to ≥10% risk).^143^ In the study, patients entered data into an online calculator to estimate 10-year risk using the PCE. Patients were provided individualized information regarding their 10-year risk with and without statin therapy and potential harms, and surveyed regarding preferences for statin therapy. The proportion who would definitely or probably choose statin therapy was 30.9 percent at a 10-year risk of <5%, 54.7 percent at ≥5% risk, 58.2 percent at ≥7.5% risk, 59.2 percent at ≥10% risk, 66.7 percent at ≥15% risk, 75.0 percent at ≥20% risk, and 81.1 percent at ≥25% risk. Information regarding harms of statins were based on randomized, placebo-controlled trials, which could have resulted in stronger preferences for statins than if adverse effects that have been reported in observational studies (e.g., muscular and cognitive adverse effects) were also described. In addition, harms data were shown using a denominator of 1000 and benefits shown using a denominator of 100, which could have impacted preferences in an uncertain manner.

A systematic review of 22 studies on preferences regarding cardiovascular preventive medicines did not focus on statins or how preferences varied according to assessed cardiovascular risk, but may still provide relevant information regarding patient preferences.^144^ It found that in studies that framed benefits of preventive medicines using absolute risk reduction, 42 percent to 72 percent (average 54%) of participants would consider taking a medication that reduced 5-year cardiovascular disease risk by <3% and 50 percent to 89 percent (average 77%) would consider taking a medication that reduced 5-year cardiovascular disease risk by ≥3%. In studies that framed benefits using 5-year number needed to treat to prevent a cardiovascular event, 31 percent to 81 percent (average 60%) of participants would consider taking a medication with a number needed to treat of >30 and 46 percent to 87 percent (average 71%) would consider taking a medication with a number needed to treat of ≤30. Most studies in the systematic review were based on a single estimate of benefit and did not consider potential harms; in addition, choices were hypothetical and patients were not provided individualized cardiovascular risk information.

## Contextual Question 3 What Are the Effects on Mortality and Cardiovascular Events of Use of the Coronary Artery Calcium Score Alone or in Addition to the Pooled Cohort Equations vs. the Pooled Cohort Equations Alone to Guide Decisions Regarding Use of Statins for Primary Prevention?

No study directly compared effects on mortality or cardiovascular events of use of coronary artery calcium (CAC) scoring (a test that measures the amount of calcium in the coronary artery walls) alone or in addition to the PCE versus the PCE alone to guide decisions regarding use of statins for primary prevention. However, a relevant large, European randomized trial is currently in progress. The Dutch Risk or Benefit in Screening for Cardiovascular Disease (ROBINSCA) trial enrolled 43,447 asymptomatic subjects (men aged 45-74 years, women aged 55-74 years) with increased cardiovascular risk (waist circumference of ≥102 cm for men or ≥88 cm for women, body mass index ≥30 kg/m^2^, current smoker and/or a family history of coronary heart disease), no prior history of cardiovascular disease, and not treated with lipid-lowering or antihypertensive therapies.^145^ Patients were randomized to assessment using the CAC score versus either traditional cardiovascular risk assessment using the Systematic COronary Risk Evaluation (SCORE) instrument or usual care, with planned five-year followup of outcomes including CHD events, mortality, and other clinical outcomes. SCORE was developed using data from 12 European cohorts and is based on gender, age, total cholesterol, systolic blood pressure, and smoking status. In the trial, preventive treatments including statin therapy and angiotensin converting enzyme inhibitors were recommended according to Dutch guidelines, based on the SCORE result or CAC score. Final results from ROBINSCA are expected in 2023. A preliminary analysis found persons randomized to CAC scoring had decreased likelihood of having an indication for preventive treatments versus traditional risk factor assessment (relative reduction 37.2% for women and 28.8% for men).^146^ However, among those classified as high risk using each method, those randomized to CAC scoring were more likely to use cholesterol-lowering or blood pressure medications (77.1% vs. 43.8%).^147^

Another in-progress trial randomized 45,000 Danish men 65 to 74 years of age to multifaceted screening that included CAC scoring versus usual care, with planned 10-year followup (primary outcome all-cause mortality).^148^ However, the trial did not exclude patients with prior CHD events and it will not be possible to distinguish effects of CAC scoring from the other interventions in the screening arm (CT for aortic/iliac aneurysm, ankle brachial index, heart telemetry, and measurement of cholesterol and plasma glucose).

Two large (n=13,644 and 4,903) U.S. cohort studies of asymptomatic or primary prevention patients who underwent CAC scoring found that benefits of statin therapy were greater in patients with more advanced coronary artery calcification.^149–151^ However, it is not possible to determine effects of CAC scoring on clinical outcomes from these studies, because there was no control group of patients who did not undergo CAC scoring.

A 2018 USPSTF review found that the addition of CAC score for risk assessment can improve both discrimination (improvement in the C statistic ranged from 0.018 to 0.144) and reclassification (the net reclassification index ranged from 0.08 to 0.35), based on 19 studies.^53^ However, it noted that the CAC score could also result in reclassification in individuals who do not experience cardiovascular events into higher risk categories, potential harms related to low radiation exposure from use of computed tomography and additional testing, and the absence of studies on clinical effects of risk assessment with CAC.

## Contextual Question 4 What Are the Effects of Consideration of Coronary Artery Calcium Score, C-Reactive Protein, Ankle-Brachial Index, Lipoprotein(a), Socioeconomic Status, Race and Ethnicity, or Family History in Addition to the Pooled Cohort Equations vs. the Pooled Cohort Equations Alone on Patient Preferences Regarding Use of Statins for Primary Prevention?

Evidence addressing this Contextual Question is extremely limited. One study described for Contextual Question 2 found that among participants with assessed 10-year cardiovascular risk >10%, there was no association between level of educational attainment and likelihood of wanting statin therapy (p=0.58).^143^ However, increased literacy (38.9% for “never” needing assistance reading materials from doctor or pharmacy vs. 64.0% to 82.8% for “rarely” to “always/often” needing assistance, p=0.004), numeracy (28.6% for highest quartile vs. 60.0 to 75.0% for other quartiles, p=0.01), and knowledge (43.5% to 57.1% for 50 to 100% knowledge questions answered correctly vs. 67.9% to 84.4% for 0 to 25% answered correctly, p<0.001) were associated with decreased likelihood of wanting to take a statin.

## Contextual Question 5 In Persons With Similar Assessed Cardiovascular Risk, How Does Use of Statins for Primary Prevention Differ According to Demographic, Clinical, or Socioeconomic Characteristics?

Six recent (published in or after 2016) U.S. studies evaluated factors associated with statin utilization in persons meeting criteria for statin use based on presence of risk factors (e.g., diabetes mellitus, LDL ≥190 mg/dL), assessed 10-year cardiovascular risk (e.g., >7.5% or >10%), or meeting guideline criteria (ATP III or 2018 ACC/AHA) (Table 13).^152–157^ Three studies focused on statins for primary prevention,^152,155,156^ and three studies evaluated statins for primary or secondary prevention.^153,154,157^ One post-hoc analysis of patients enrolled in a randomized trial of individualized cardiovascular disease risk communication versus usual care evaluated likelihood of statin initiation; analyses controlled for the intervention group.^155^ The other studies evaluated prevalent statin use based on cross-sectional sampling of observational cohorts. Two studies of statins for primary or secondary prevention focused on persons with diabetes mellitus.^153,154^ All studies reported risk estimates adjusted for demographic, clinical (e.g., cardiovascular risk factors), and/or socioeconomic factors. The studies were not designed to evaluate how clinician factors (e.g., clinician demographics, specialty, years in practice) impacted statin utilization.

Table 13 Contextual Question 5: Statin Use According to Demographic, Clinical, or Socioeconomic Characteristics

Author, Year; Study Design; Dates | Sample Size; Proportion Prescribed Statin; Setting | Population | Race/Ethnicity and Statin Use | Age and Statin Use | Sex and Statin Use | Other Factors and Statin Use
Dorsch, 2019^*^,^152^; Cross-sectional; 2017 to 2018 | 9653; Statin prescribed: 29.8%; Academic health system | 40 to 79 years of age (plus 20 to 39 years if LDL cholesterol ≥190 mg/dL); no prior atherosclerotic cardiovascular disease; LDL cholesterol ≥190 mg/dL, diabetes mellitus, or 10-year atherosclerotic cardiovascular risk ≥7.5% | Adjusted OR (95% CI); reference White; Entire sample; Black: 0.58 (0.49 to 0.69); Asian: 1.09 (0.89 to 1.33); Other: 1.33 (0.97 to 1.81); Persons with diabetes mellitus; Black: 0.64 (0.49 to 0.82); Asian: 1.17 (0.88 to 1.58); Other: 0.99 (0.67 to 1.48); Atherosclerotic cardiovascular risk ≥7.5% (not diabetic and LDL ≤190 mg/dL); Black: 0.38 (0.26 to 0.54); Asian: 0.96 (0.63 to 1.46); Other: 1.35 (0.65 to 2.77) | Adjusted OR (95% CI); reference <60 years of age; Entire sample; 60 to 69: 1.09 (0.97 to 1.23); 70 to 79: 1.37 (1.19 to 1.57); Persons with diabetes mellitus; 60 to 69: 1.44 (1.19 to 1.73); 70 to 79: 1.56 (1.18 to 2.06); Atherosclerotic cardiovascular risk ≥7.5% (not diabetic and LDL ≤190 mg/dL); 60 to 69: 1.41 (1.06 to 1.88); 70 to 79: 2.03 (1.50 to 2.75); LDL ≥190 mg/dL; 60 to 69: 1.39 (1.13 to 1.69); 70 to 79: 1.56 (1.18 to 2.06) | Not assessed | Not assessed
Karmali, 2016^*^,^155^; Cohort (post-hoc secondary analysis of randomized trial); August 2012 to March 2013 (recruitment) | 646; Statin initiated: 12.1%; Federally qualified community health centers | ≥35 years (men) or ≥45 years (women); no prior atherosclerotic disease; no lipid lowering therapy at baseline; 10-year coronary heart disease risk ≥10%; LDL cholesterol ≥100 mg/dL; no diabetes mellitus | Not assessed | Adjusted OR (95% CI); per 1 standard deviation increase; Cholesterol treatment discussion: 0.84 (0.67 to 1.06); Statin prescription: 1.00 (0.79 to 1.27) | Adjusted OR (95% CI); female vs. male; Cholesterol treatment discussion: 0.93 (0.74 to 1.18); Statin prescription: 0.73 (0.47 to 1.13) | Adjusted OR (95% CI); per 1 standard deviation increase; Cholesterol treatment discussion; Systolic blood pressure: 0.80 (0.65 to 0.99); Antihypertensive medication use: 3.68 (2.35 to 5.75); Current smoking: 0.59 (0.46 to 0.77); LDL cholesterol: 1.27 (0.96 to 1.68); HDL cholesterol: 1.13 (0.86 to 1.49); Statin prescription; Systolic blood pressure: 0.98 (0.76 to 1.26); Antihypertensive medication use: 3.98 (3.30 to 4.81); Current smoking: 0.87 (0.54 to 1.40); LDL cholesterol: 1.82 (1.66 to 1.99); HDL cholesterol: 1.11 (0.82 to 1.49)
Schroff, 2017^*^,^156^; Cross-sectional (Reasons for Geographic Racial Differences in Stroke [REGARDS] study); 2003 to 2007 | 18,216; Statin use: 52.0%; Population-based | ≥45 years; statin indication for primary prevention (ATP III) | Adjusted prevalence ratio (95% CI); reference; White men; Black men: 0.82 (0.79 to 0.85); White women: 0.90 (0.86 to 0.94); Black women: 0.80 (0.77 to 0.83) | Adjusted prevalence ratio (95% CI); reference <65 years 65 to 75 years: 0.85 (0.84 to 0.89) >75 year: 1.04 (1.00 to 1.08) | Analyzed with race | Adjusted prevalence ratio (95% CI); Area-level poverty; reference <10%; - 10 to 25%: 0.96 (0.93 to 0.99); - >25%: 0.94 (0.90 to 0.98); Health insurance, no vs. yes: 0.78 (0.72 to 0.84); Number of vulnerabilities (age ≥65, being a woman, being Black, area level poverty ≥10%, or no health insurance); reference none; - 1: 0.91 (0.87 to 0.96); - 2: 0.83 (0.79 to 0.87); - 3: 0.74 (0.70 to 0.78); - ≥4: 0.68 (0.64 to 0.72)
Gamboa, 2017^153^; Cross-sectional^†^ (Reasons for Geographic Racial Differences in Stroke [REGARDS] study); 2003 to 2007 | 4,288; Statin use: 57.9%; Population-based | ≥45 years; diabetes mellitus and taking statin or LDL cholesterol ≥100 mg/dL | Adjusted prevalence ratio (95% CI); reference; White men; Black men: 0.96 (0.89 to 1.03); White women: 0.86 (0.80 to 0.92); Black women: 0.87 (0.81 to 0.93) | Adjusted prevalence ratio (95% CI); Age (per standard deviation): 1.05 (1.02 to 1.08) | Analyzed with race | Adjusted prevalence ratio (95% CI) Income; reference ≥$75,000; - $35,000 to $74,000: 1.00 (0.92 to 1.08); - $20,000 to $34,000: 0.95 (0.87 to 1.03); - <$20,000: 0.98 (0.89 to 1.08); Less than vs.at least high school completion: 0.99 (0.92 to 1.06); Health insurance vs. no health insurance: 1.18 (1.05 to 1.33); Regular source of medical care (yes vs. no): 1.00 (0.95 to 1.05); Poverty level; reference least poverty; - Intermediate poverty: 0.97 (0.91 to 1.03); - Most poverty: 0.97 (0.90 to 1.04); Imperfect vs. perfect medication adherence: 1.00 (0.95 to 1.05); Diabetes mellitus severity; reference diet-controlled; - Oral medication use: 1.45 (1.33 to 1.56); - Insulin use: 1.50 91.37 to 1.63); Current smoking (yes vs. no): 0.96 (0.89 to 1.03); Obesity vs. no obesity: 1.02 (0.97 to 1.07); Depressive vs. few/no depressive symptoms: 0.93 (0.86 to 1.00); Low vs. high HDL cholesterol: 0.98 (0.94 to 1.03); Systolic blood pressure (per standard deviation): 0.97 (0.95 to 0.99; SF-36 Physical Component Summary; Scale score (per standard deviation): 0.97 (0.95 to 1.00); Coronary heart disease history (yes vs. no): 1.22 (1.16 to 1.28)
Gu, 2018^†^,^154^; Cross-sectional (National Health and Nutrition Examination Survey); 1999 to 2014 | 4,860; Statin use: 26.2% (1999 to 20002); 49.5% (2011 to 2014); Population-based | 40 to 75 years of age; diabetes mellitus | Adjusted prevalence ratio (95% CI); reference; White; Any statin; Black: 0.84 (0.77 to 0.93); Hispanic: 0.92 (0.80 to 1.05); Atorvastatin or rosuvastatin; Black: 0.76 (0.62 to 0.94); Hispanic: 0.92 (0.75 to 1.14) | Adjusted prevalence ratio (95% CI); reference 60 to 75 years; Any statin; 40 to 49 years: 0.68 (0.58 to 0.80); 50 to 59 years: 0.92 (0.83 to 1.02); Atorvastatin or rosuvastatin; 40 to 49 years: 0.66 (0.49 to 0.88); 50 to 59 years: 0.94 (0.77 to 1.15) | Adjusted prevalence ratio (95% CI); women vs. men; Any statin; 0.90 (0.83 to 0.98); Atorvastatin or rosuvastatin; 1.00 (0.84 to 1.20) | Adjusted prevalence ratio (95% CI), any statin use; Educational attainment; reference less than high school; - High school or associate degree: 1.03 (0.94 to 1.13); - College degree or above: 1.00 (0.86 to 1.16); Poverty to income ratio; reference <100%; - 100 to 299%: 1.02 (0.92 to 1.13); - 300 to 499%: 1.20 (1.07 to 1.35); - 500% and above: 1.22 (1.06 to 1.39); Current smoker (yes vs. no): 0.94 (0.83 to 1.07); Body mass index, kg/m^2^; reference <25; - 25 to <30: 1.09 (0.95 to 1.26); - ≥30: 1.13 (1.00 to 1.28); Chronic kidney disease (present vs. absent): 1.47 (1.36 to 1.59); Hypertension (present vs. absent): 1.18 (1.06 to 1.33); Health insurance status (insured vs. uninsured): 1.60 (1.31 to 1.96); Medical visits (≥2 times vs. <2 times): 1.79 (1.38 to 2.32)
Suero-Abreu, 2020^†^,^157^; Cross-sectional; 2018 to 2019 | 464; Statin use: 82%; Urban health center (55% without insurance) | 20 to 75 years, statin-eligible based on 2018 AHA/ACC guideline | Adjusted odds ratio (95% CI); Black vs. white: 0.42 (0.23 to 0.77) | Adjusted odds ratio (95% CI); reference; 18 to 40 years; 40 to 55 years: 1.69 (0.40 to 6.09); 55 to 90 years: 4.59 (1.09 to 16.66) | Adjusted odds ratio (95% CI); Male vs. female: 1.40 (0.82 to 2.43) | Adjusted odds ratio (95% CI); Uninsured (yes vs. no): 0.84 (0.46 to 1.52); Atherosclerotic cardiovascular disease risk ≥7.5% only (yes vs. no): 0.14 (0.07 to 0.25); Hypertension (yes vs. no): 2.38 (1.29 to 4.38); Chronic kidney disease (yes vs. no): 3.95 (1.42 to 14.30)

Abbreviations: AHA/ACC=American Heart Association/American College of Cardiology; ATP-III=Adult Treatment Panel III; CI=confidence interval; HDL=high-density lipoprotein; LDL=low-density lipoprotein; OR=odds ratio; REGARDS=Reasons for Geographic and Racial Differences in Stroke; SF-36=36 item short-form survey.

* Primary population.

† Primary or secondary population.

The studies of statins for primary prevention in eligible patients found some evidence of differences in statin utilization according to demographic, clinical, or socioeconomic characteristics. One study (n=9,653) conducted in a large academic health system found Black race associated with decreased likelihood of statin utilization versus White race in the entire sample (adjusted OR 0.58, 95% CI, 0.49 to 0.69), as well as when the analysis was restricted to persons with diabetes mellitus (adjusted OR 0.64, 95% CI, 0.49 to 0.82) or assessed 10-year cardiovascular risk ≥7.5% without diabetes or LDL ≥190 mg/dL (adjusted OR 0.38, 95% CI, 0.26 to 0.54).^152^ Estimates for other racial categories (Asian or other) were imprecise. A population-based study of persons in the Reasons for Geographic Racial Differences in Stroke (REGARDS) cohort (n=18,216) found Black men and Black women both had decreased likelihood of statin utilization versus White men (adjusted prevalence ratio 0.82, 95% CI, 0.79 to 0.85 and 0.80, 95% CI, 0.77 to 0.83, respectively).^156^ White women also had decreased likelihood of statin utilization versus White men, though the difference was not as pronounced (adjusted prevalence ratio 0.90, 95% CI, 0.86 to 0.94). Having no health insurance was also associated with decreased likelihood of statin utilization (adjusted prevalence ratio 0.78, 95% CI, 0.72 to 0.84) and there was a slight association between being in a higher poverty area and decreased likelihood of statin utilization (vs. area-level poverty 10%, adjusted prevalence ratio 0.96, 95% CI, 0.93 to 0.99 for 10 to 25% and 0.94, 95% CI, 0.90 to 0.98 for >25%). There was a dose-response relationship between having more vulnerabilities (defined as age ≥65, being a woman, being Black, area level poverty ≥10%, or no health insurance) and decreased likelihood of statin utilization. Versus no vulnerabilities, the adjusted prevalence ratio was 0.91 (95% CI, 0.87 to 0.96) when one vulnerability was present and 0.68 (95% CI, 0.64 to 0.72) when ≥4 vulnerabilities were present. The third study of statin utilization for primary prevention was a post-hoc analysis of patients (n=646) in federally qualified health centers enrolled in a randomized trial of individualized cardiovascular disease risk communication.^155^ Antihypertensive medication use (adjusted OR 3.98, 95% CI, 3.30 to 4.81) and higher LDL cholesterol (adjusted OR 1.82, 95% CI, 1.66 to 1.99) were associated with increased likelihood of statin utilization. Estimates for gender and other cardiovascular risk factors (systolic blood pressure, current smoking, and HDL level) were imprecise. Across primary prevention studies, findings regarding the association between age and statin utilization were inconsistent.

Studies of statins for primary or secondary prevention also found evidence indicating differences in utilization. One study of patients (n=464) in an urban health center (55% without insurance) who met 2018 AHA/ACC statin eligibility criteria found Black race associated with decreased likelihood of statin utilization versus White race (adjusted OR 0.42, 95% CI, 0.23 to 0.77) and males with increased likelihood of utilization versus females (adjusted OR 1.40, 95% CI, 0.82 to 2.43).^157^ Having hypertension or chronic kidney disease was associated with increased likelihood of statin utilization and having only an assessed cardiovascular risk of ≥7.5% without other risk factors was associated with markedly lower likelihood (adjusted OR 0.14, 95% CI, 0.07 to 0.25). Two studies (n=4,860 and 4,288) focused on patients with diabetes.^153,154^ One study found Black race associated with decreased likelihood of statin utilization versus White race (adjusted prevalence ratio 0.84, 95% CI, 0.77 to 0.93); women had decreased likelihood of statin utilization compared with men (adjusted prevalence ratio 0.90, 95% CI, 0.83 to 0.98).^154^ The other study found White women (adjusted prevalence ratio 0.86, 95% CI, 0.80 to 0.92) and Black women (adjusted prevalence ratio 0.87, 95% CI, 0.81 to 0.93) had decreased likelihood of statin utilization versus White men, though the likelihood of utilization by Black and White men was similar.^153^ In both studies of persons with diabetes, associations were observed between older age, having health insurance and higher income and increased likelihood of statin utilization. An analysis of population-based data from the 2013-2014 National Health and Nutrition Examination Survey found that among persons eligible for statin therapy based on the 2013 ACC/AHA guideline, statin use was higher among White non-Hispanic persons (58.3%) compared with Black non-Hispanic (44.3%), Asian non-Hispanic (49.2%), or Hispanic (33.7%) persons.^158^ Details regarding analysis methods were limited, though the study reported adjustment for sex and age.