# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the U.S. Preventive Services Task Force (USPSTF),^65^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes included to assess statins’ effectiveness in primary prevention of cardiovascular disease (CVD) (Figure 1).

Figure 1 Analytic Framework

Abbreviations: CHD=coronary heart disease; CVA=cerebrovascular accident (stroke); CVD=cardiovascular disease; KQ=key question.

Key Question 1a. What are the benefits of statins in reducing the incidence of CVD-related morbidity or mortality or all-cause mortality in asymptomatic adults without prior CVD events?

Key Question 1b. Do the benefits of statin treatment vary in groups defined by demographic, clinical, or socioeconomic characteristics?

Key Question 1c. What are the benefits of statin treatment titrated to achieve target low-density lipoprotein cholesterol levels vs. a fixed dose strategy?

Key Question 2a. What are the harms of statins in adults without prior CVD events?

Key Question 2b. Do the harms of statin treatment vary in groups defined by demographic, clinical, or socioeconomic characteristics?

Key Question 3. How do the benefits and harms of statin treatment vary according to its intensity?

Figure 1 depicts the analytic framework, which outlines the evidence areas covered in the review, including the population, interventions and related harms, and outcomes. The population includes adults age 18 years and older without prior cardiovascular disease events. An arrow from the population leads to risk assessment, including cardiovascular risk factors and 10-year or lifetime individualized cardiovascular disease risk level. A line representing statin treatment then proceeds from risk assessment to the outcomes examined in the review, which include morbidity or mortality related to coronary heart disease or cerebrovascular accident (stroke) and all-cause mortality (Key Questions 1 and 3). A subsequent arrow from the intervention assesses resulting harms (Key Questions 2 and 3).

### Key Questions

1. a. What are the benefits of statins in reducing the incidence of CVD-related morbidity or mortality or all-cause mortality in asymptomatic adults without prior CVD events?
  b. Do the benefits of statin treatment vary in groups defined by demographic, clinical, or socioeconomic characteristics?
  c. What are the benefits of statin treatment titrated to achieve target low-density lipoprotein cholesterol levels vs. a fixed dose strategy?
2. a. What are the harms of statins in adults without prior CVD events?
  b. Do the harms of statin treatment vary in groups defined by demographic, clinical, or socioeconomic characteristics?
3. How do benefits and harms of statin treatment vary according to its intensity?

### Contextual Questions

Five Contextual Question were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What are the effects of initiating statins for primary prevention at different cardiovascular risk thresholds on the number of persons eligible for treatment and potential benefits and harms (including modeling studies)?
2. How do patient preferences regarding use of statins for primary prevention vary at different cardiovascular risk thresholds?
3. What are the effects on mortality and cardiovascular events of use of the coronary artery calcium score alone or in addition to the Pooled Cohort Equations vs. the Pooled Cohort Equations alone to guide decisions regarding use of statins for primary prevention?
4. What are the effects of consideration of coronary artery calcium score, C-reactive protein, ankle-brachial index, lipoprotein(a), socioeconomic status, race/ethnicity, or family history in addition to the Pooled Cohort Equations vs. the Pooled Cohort Equations alone on patient preferences regarding use of statins for primary prevention?
5. In persons with similar assessed cardiovascular risk, how does use of statins for primary prevention differ according to demographic, clinical, or socioeconomic characteristics?

Note: A Contextual Question on risk prediction instruments is currently being addressed in a separate USPSTF review on aspirin use for the primary prevention of CVD and colorectal cancer: “Are there patient populations for whom CVD risk is underestimated or overestimated using the Pooled Cohort Equations?” Patient populations include those defined by demographic, clinical, and socioeconomic characteristics.

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and Ovid MEDLINE, from May 2016 to November 12, 2021, for relevant studies with surveillance through May 20, 2022. Search strategies are available in Appendix A1. We included studies from the prior USPSTF review^3^ and reviewed reference lists of relevant articles, including systematic reviews, for additional studies.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies based on inclusion and exclusion criteria developed for each key question (Appendix A2). The population for all Key Questions was adults age 40 years or older without prior CVD events (e.g., MI, angina, revascularization, stroke, or transient ischemic attack); we also included mixed (primary and secondary prevention) studies if fewer than 10 percent of patients had prior CVD events. Mixed populations studies in which >10% had prior CVD events were excluded unless data were reported separately for the primary prevention population. We included studies that compared treatment versus no treatment or usual care without a statin (or other lipid-lowering medication) and assessed effects on risk of all-cause or cardiovascular mortality, CHD- or stroke-related events, composite outcomes (e.g., various cardiovascular events, with or without mortality), or harms (including muscle symptoms or injury, cognitive loss, diabetes, and hepatic injury). Populations of interest were defined by demographic (e.g., age, sex, or race/ethnicity), clinical (e.g., specific cardiovascular risk factors, lipid parameters, or 10-year or lifetime cardiovascular risk), and socioeconomic (e.g., income, educational attainment, deprivation index) factors. We also included studies that compared treatment strategies with statins to target LDL-C levels versus other treatment strategies (e.g., fixed-dose therapy) and that evaluated how benefits and harms vary according to intensity of statin treatment (based on expected LDL-C lowering effect or LDL-C target). For all Key Questions, we included randomized, controlled trials (RCTs) of statin therapy versus placebo or no statin. For Key Question 2 (harms), we included large studies (cohort studies with >10,000 patients or case-control studies with >500 cases) on harms of statin use compared with nonuse in primary prevention populations.

The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists included studies, and Appendix A5 lists excluded studies with reasons for exclusion.

## Data Abstraction and Quality Rating

We abstracted details about the study design, patient population, setting, statin therapy, comparison, analysis, followup, and results. Data abstraction was conducted by one investigator and verified by another team member. We contacted authors of mixed primary and secondary prevention trials for additional data on primary prevention populations and utilized otherwise unpublished trial data from the Food and Drug Administration website or previously reported in systematic reviews (i.e., obtained from trial authors for use in the review). Data sources were recorded.

Following publication of the 2016 USPSTF review, data errors were identified for two trials (ASTRONOMER and JUPITER).^66,67^ Analyses that utilized corrected data resulted in an attenuated estimate for statin therapy and cardiovascular mortality (relative risk [RR] 0.82, 95% confidence interval [CI], 0.71 to 0.94; absolute risk difference [ARD] −0.20% based on corrected data and RR 0.69, 95% CI, 0.54 to 0.88; ARD −0.43% on uncorrected data), but did not change the overall conclusions.^68^ We utilized the corrected data in this report.

Two investigators independently applied criteria developed by the USPSTF^65^ to rate the quality of each study as good, fair, or poor (Appendix A6). Discrepancies were resolved through a consensus process. When risk estimates were not reported for individual studies, we calculated the relative risk and 95 percent confidence interval if adequate data (number of events and sample size) were available.

## Data Synthesis

We conducted meta-analyses to calculate risk ratios for effects of statins on clinical outcomes using the DerSimonian and Laird random-effects model with Review Manager Version 5.4.1 software (The Cochrane Collaboration Nordic Cochrane Centre, Copenhagen, Denmark). Statistical heterogeneity was assessed using the I^2^ statistic.^69^ For stroke, we excluded hemorrhagic strokes when data permitted. When statistical heterogeneity was present, we performed sensitivity analysis with the profile likelihood method using Stata Version 10.1 (StataCorp, College Station, TX), as the DerSimonian and Laird model can result in overly narrow CIs in this situation.^70^ Results using the profile likelihood method were very similar to results using the DerSimonian and Laird model and are not discussed further. We performed additional sensitivity and stratified analyses based on study quality, exclusion of trials that enrolled patients with prior CVD events, duration of followup, intensity of statin therapy (based on the ACC/AHA guideline),^64^ mean LDL-C levels at baseline, and whether the trial was stopped early. For analyses with at least 10 trials, we constructed funnel plots and conducted the Egger test to detect small sample effects (a marker for potential publication bias).^71^

We assessed the aggregate internal validity (quality) of the body of evidence for each Key Question (good, fair, poor) using methods developed by the USPSTF, based on the number, quality, and size of studies, consistency of results between studies, and directness of evidence.^72^

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and Key Questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.

## External Review and Public Comment

The draft research plan was posted for public comment on the USPSTF website from July 9, 2020 to August 5, 2020 and modified prior to finalization. Changes to the research plan included adding quality of life as an outcome, adding cataracts as a harm, and replacing the word “potency” with “intensity.” A final research plan was posted on the USPSTF’s Web site on November 5, 2020.

A draft version of this report was reviewed by content experts, USPSTF members, Agency for Healthcare Research and Quality (AHRQ) Medical Officers, and Federal partners (Appendix A7), and edits were made for clarity. Additionally, the draft report was posted for public comment from February 22, 2022 to March 22, 2022. The comments were reviewed and minor edits were made for clarity. However, there were no changes to the studies, findings, or conclusions.