# Chapter 1 Introduction and Background

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2016 recommendation on statins for primary prevention of cardiovascular disease (CVD) in adults.^1^ Prior to 2016, in a recommendation last updated in 2008, the USPSTF recommended lipid screening in men aged 35 years and older and women aged 45 years and older,^2^ but had not issued a recommendation specifically on use of statins. In 2016, given the tremendous burden of CVD, widespread implementation of lipid screening, and uncertainty regarding optimal strategies for use of statins for primary prevention, the USPSTF commissioned a review focusing on benefits and harms of statins for primary prevention.^3^ The review found that in adults at increased CVD risk but without prior CVD events, statin therapy is associated with reduced risk of all-cause and cardiovascular mortality and CVD events, with greater absolute benefits in persons at higher baseline risk. The USPSTF recommended that clinicians initiate use of low- to moderate-dose statins in adults aged 40 to 75 years without a history of CVD with 1 or more CVD risk factors (dyslipidemia, diabetes, hypertension, or smoking) and a calculated 10-year CVD event risk of 10 percent or greater (B recommendation). In adults aged 40 to 75 years without a history of CVD with 1 or more CVD risk factors and a calculated 10-year CVD event risk of 7.5 percent to 10 percent, the USPSTF recommended that clinicians selectively offer low- to moderate-dose statins (C recommendation). The USPSTF found insufficient evidence to assess the balance of benefits and harms of initiating statin use in adults 76 years and older (I statement). The USPSTF did not make a recommendation on statins for primary prevention of CVD in adults less than 40 years of age. A separate 2016 review conducted for the USPSTF on lipid screening in adults younger than 40 years of age found insufficient evidence to determine benefits and harms.^4^ The USPSTF addresses lipid screening in children and adolescents as a separate topic.^5^

## Condition Background

### Condition Definition

In this report, the term “cardiovascular disease” refers to atherosclerotic diseases that affect the heart and blood vessels, in particular ischemic coronary heart disease (CHD), cerebrovascular disease, and peripheral vascular disease (PVD). CHD can result in myocardial infarction and cerebrovascular disease can result in stroke (cerebrovascular accident or CVA); other conditions that may result from CVD include cardiomyopathy, heart failure, cardiac dysrhythmia, valvular heart disease, and others.

### Prevalence and Burden of Disease/Illness

Cardiovascular disease is the leading cause of morbidity and death in the United States, resulting in one out of every four deaths.^6^ CHD is the single leading cause of death and accounts for 43 percent of deaths attributable to CVD in the United States.^7,8^ In 2019, there were an estimated 558,000 deaths due to CHD and 109,000 deaths due to ischemic stroke.^9^ CHD caused 10 percent of deaths in persons aged 25 to 44 years, 21 percent of deaths in persons aged 45 to 64 years, and 25 percent of deaths in persons aged 65 years and older.^6^ Estimates based on Framingham Heart Study participants from 1971 to 1996 indicated that the lifetime risks (through age 80 years) of CHD for 40-year old men with a total cholesterol of 200, 200 to 239, and ≥240 mg/dL were 31, 43, and 57 percent, respectively, with 10-year cumulative risks of 3, 5, and 12 percent.^10^ In 2014, CVD and stroke accounted for over 350 billion dollars in health care costs.^8^

The prevalence of CHD increases with age and is higher in men than in women at the same age.^11^ In adults over age 20 years, prevalence of CHD varies by race/ethnicity, with prevalence from 2015 to 2018 estimated at 8.6 percent for American Indians/Alaska Natives,^12^ 6.7 percent for Black males and 7.2 percent for Black females, 6.8 percent for Hispanic males and 6.4 percent for Hispanic females, 5.0 percent for Asian males and 3.2 percent for Asian females, and 8.7 percent for White males and 6.0 percent for White females.^9^ Despite lower CHD prevalence among Asian American persons aggregated as a whole, mortality due to ischemic CHD is higher among South Asians compared with East Asian or White persons.^13^ CHD mortality is also higher in Black compared with White women and in Black compared with White men.^14^

### Etiology and Natural History

CVD has a multifactorial etiology, including well-established risk factors such as age, sex, family history of early CVD, smoking status, and presence and severity of obesity, dyslipidemia, hypertension, and diabetes.

Cholesterol is a lipid that is present in all animal cells, a primary contributor to plaque formation, and the main target of statin therapy.^15^ Cholesterol is transported in the body as particles of lipid and protein (lipoproteins).^16^ Classes of lipoproteins include low density and high density lipoprotein cholesterols (LDL-C, HDL-C), and very low density lipoprotein cholesterol (VLDL-C). LDL-C makes up 60 to 70 percent of total serum cholesterol, high density lipoprotein cholesterol (HDL-C) contributes 20 to 30 percent, and VLDL-C, 10 to 15 percent. LDL-C is the main atherogenic lipoprotein and is the primary target of cholesterol-lowering therapy. HDL-C is inversely related to risk for CHD. Some forms of VLDL-C are precursors to LDL-C and promote atherosclerosis. The risk of CVD increases as LDL-C levels increase. However, CVD can occur in patients with relatively low or normal lipid levels, depending on the presence and severity of other risk factors.

The natural history of CVD varies but often involves a long asymptomatic stage of gradual buildup of atherosclerotic plaque in affected arterial vessels. An important challenge in preventing the negative consequences of CVD is that its first clinical manifestation can be catastrophic, including sudden cardiac death, acute MI, or CVA.^17^ Among those who die suddenly of CHD, over half had no antecedent symptoms.^18^ In addition, MI may be silent,^19,20^ causing no recognized symptoms, but negatively impacting prognosis.^19,20^

### Risk Factors

Modifiable risk factors for CHD include dyslipidemia (high LDL-C, low HDL-C, or high triglyceride [TG] levels), hypertension, smoking, thrombogenic/hemostatic state, diabetes, obesity, physical inactivity, and an atherogenic diet.^16^ Non-modifiable risk factors include age (male ≥45 years, female ≥55 years), male sex, and family history of early-onset CHD. Socioeconomic factors are strong determinants of CVD risk, but are not incorporated in existing cardiovascular risk assessment instruments.^21^

Risk factors for dyslipidemia include physical inactivity, obesity, abdominal obesity, metabolic syndrome, hypertension, atherogenic diet (high in saturated fatty acids, cholesterol, and sodium), consumption of dietary added sugars, genetic factors, age, and male sex.^16,22–24^ Elevated TG is associated with overweight and obesity, physical inactivity, smoking, excess alcohol intake, high carbohydrate diet, other diseases such as diabetes and nephrotic syndrome, medications such as corticosteroids or estrogens, and genetic factors.^16^ Dyslipidemia is also associated with conditions such as HIV infection, solid organ transplantation, and use of certain medications, such as antipsychotic medications and anti-HIV protease inhibitors.^25–27^

Non-HDL-C (i.e., TC minus HDL-C) is a measure that includes all potentially atherogenic lipoprotein particles, including LDL-C, VLDL, intermediate-density lipoprotein, and lipoprotein(a), and may be a more accurate predictor of CHD risk than LDL-C.^28–30^ Apolipoprotein B directly measures the total number of atherogenic particles, though it is unclear whether it is superior to non-HDL-C as a marker of CHD risk and is more difficult and costly to measure.^28,31,32^ The USPSTF previously (last updated in 2008) recommended lipid screening with a fasting or nonfasting HDL-C, with either the total cholesterol or LDL-C.^33^

Other potential risk factors for CVD include alternative measures of lipids such as apolipoproteins, TC-to-HDL-C ratio, and other lipoprotein levels and non-lipid factors such as inflammatory markers (e.g., C-reactive protein,^34^ or homocysteine), thrombogenic factors (e.g., fibrinogen, antithrombin III, factor V Leiden),^16^ and markers of atherosclerosis (e.g., ankle brachial index, coronary artery calcium).^35^ In 2018, the USPSTF found insufficient evidence to assess the balance of benefits and harms of adding the ankle brachial index, C-reactive protein, or coronary artery calcium score to traditional risk assessment for CVD in asymptomatic adults to prevent CVD events, though there was some evidence indicating improvements in discrimination and risk reclassification.^36^

In 2016, the USPSTF recommended use of the ACC/AHA Pooled Cohort Equations (PCE) to predict cardiovascular risk.^1^ The purpose of the PCE is to estimate 10-year risk of CVD events (death from coronary heart disease, nonfatal myocardial infarction, and fatal or nonfatal stroke) in persons 40 to 79 years of age without prior cardiovascular events.^37^ The PCE has been best validated among non-Hispanic White and Black persons; other racial/ethnic populations are underrepresented in the development cohorts. The PCE is not intended for use in patients with very severe dyslipidemia (e.g., total cholesterol >320 mg/dL or LDL-C >300 mg/dL, or in patients with familial hyperlipidemia), because it was not validated in this population and potentially underestimates risk.^38^ The PCE consists of separate equations for males and females and for Black and non-Black (White or other race) persons. Risk factors utilized by the PCE to estimate risk are age, cholesterol levels, systolic blood pressure level, use of antihypertensive treatment, presence of diabetes, and smoking status. As noted in an in-progress USPSTF review on aspirin for primary prevention, concerns have been noted regarding potential inaccuracies with the PCE.^39^ In particular, a number of validation studies have found that the PCE tends to overestimate CVD risk generally as well as in specific populations defined by race and ethnicity, though underestimation has also been reported.^40–47^ Inaccuracy of the PCE could be due in part to use of older cohorts to develop the models. Some analyses indicate that the PCE underpredicts CVD risk in socioeconomically disadvantaged populations, though this finding is not consistent in all studies.^42,44,48^ Modifications to the PCE (e.g., recalibration, addition of nontraditional risk factors, and other model revisions) have been proposed to improve accuracy,^21,49–52^ but such modifications have not undergone extensive validation. To refine risk assessments based on the PCE, particularly for persons in borderline or intermediate risk categories in whom there is uncertainty regarding initiation of preventive therapies, the 2019 ACC/AHA primary prevention guideline^21^ suggests consideration of additional “risk-enhancing factors” to refine assessments based on the PCE. These include family history of early CHD, presence of chronic kidney disease, metabolic syndrome, pre-eclampsia, premature menopause, inflammatory diseases, HIV, and South Asian ancestry. The 2019 ACC/AHA also suggests consideration of biomarkers and tests, such as coronary artery calcium score, triglyceride level, apolipoprotein B, C-reactive protein, ankle brachial index; the USPSTF reviewed coronary artery calcium score, C-reactive protein, and ankle brachial index in 2018 and found evidence to be insufficient.^53^

### Rationale for Preventive Treatment

CVD is often associated with a prolonged asymptomatic phase, is highly prevalent, and is an important cause of mortality and morbidity in adults age 40 years or older. If effective, use of statin therapy in persons at higher risk for CVD could prevent future events (including MI and stroke), potentially reducing morbidity and mortality and improving quality of life. Potential harms that could offset benefits of statins include hepatotoxicity (ranging from mild transaminitis to hepatic failure),^54^ muscle injury (ranging from myalgia to overt rhabdomyolysis),^55^ renal dysfunction,^56^ and diabetes. Adverse effects on behavior, cognition,^57^ and increased risk of cancer,^58^ hemorrhagic stroke, and cataracts have also been linked with statins but not clearly established, with some studies showing no association.^59^ Regarding cognition, some studies suggest that statins may reduce risk of dementia.

### Mechanism of Action

Statins are a class of drugs that work by inhibiting the enzyme 3-hydroxy-3-methylglutaryl coenzyme A reductase, the rate-limiting step in cholesterol biosynthesis. Statins reduce LDL-C, TC, and TG levels and slightly increase HDL-C levels, resulting in plaque regression,^60^ and are also thought to have anti-inflammatory and other plaque stabilization effects.^61^ Seven statins are available in the United States: atorvastatin, fluvastatin, lovastatin, pitavastatin, pravastatin, rosuvastatin, and simvastatin. The statins, dose ranges, and relative potency (based on average lipid-lowering effects, classified as low, moderate, or high) are shown in Table 1.

Table 1 Statin Dosing and ACC/AHA Classification of Intensity

Statin | Low-Intensity Dosage (LDL-C Reduction <30%) | Moderate-Intensity Dosage (LDL-C Reduction 30% to <50%) | High-Intensity Dosage (LDL-C Reduction ≥50%)
Atorvastatin | NA | 10 to 20 mg | 40 to 80 mg
Fluvastatin | 20 to 40 mg | 40 mg 2x/day; XL 80 mg | NA
Lovastatin | 20 mg | 40 to 80 mg | NA
Pitavastatin | NA | 1 to 4 mg | NA
Pravastatin | 10 to 20 mg | 40 to 80 mg | NA
Rosuvastatin | NA | 5 to 10 mg | 20 to 40 mg
Simvastatin | 10 mg | 20 to 40 mg | NA

From ACC/AHA, 2018.^199^ Dosages shown are total daily dosages; exceptions are noted.

Abbreviations: ACC=American College of Cardiology; AHA=American Heart Association; LDL-C=low-density lipoprotein cholesterol; NA=not applicable.

### Current Clinical Practice/Recommendations of Other Groups

Approximately 39 million Americans are treated with statins.^62^ Current recommendations on statin therapy from other groups are presented in Table 2. The 2013 ACC/AHA guideline recommended statin therapy for primary prevention in persons with 1) LDL-C ≥190 mg/dL, 2) persons 40 to 75 years of age with diabetes and LDL-C 70-189 mg/dL, and 3) other persons with an estimated 10-year risk of CVD of 7.5% or higher.^61^ In 2019, ACC/AHA issued revised guidelines on primary prevention of cardiovascular disease.^21^ It recommends initiation of statin therapy in persons with 10-year risk ≥7.5% (“intermediate” or “high”) and a risk discussion in persons at 5% to <7.5% (“borderline”) risk. As described above, it recommends consideration of “risk enhancers” to refine risk assessments based on the PCE and inform decision-making in persons at “intermediate” (10-year risk of cardiovascular events ≥7.5% to <20%) and “borderline” risk.

Table 2 Recommendations of Other Groups

Organization | Year Published | Recommendation/Clinical Guidance
American College of Cardiology/American Heart Association^21^ | 2019 | Measure traditional risk factors every 4 to 6 years to identify major factors related to atherosclerotic cardiovascular disease (ASCVD), and estimate lifetime or 30-year risk for ASCVD for people who are 20 to 39 years or 40 to 59 years who do not have an elevated 10-year risk of ≥7.5%.; For statin treatment:; - Patients 20 to 75 years with LDL-C at least 190 mg/dL use a high-intensity statin without risk assessment; - Patients with type 2 diabetes and 40 to 75 years use a moderate-intensity statin and risk estimate to consider high-intensity statins; - Patients 40 to 75 years without diabetes with LDL-C between 70 and 189 mg/dl to use a risk estimator to determine the intensity. For these patients, the following guidelines are recommended:; A. For 5% to <7.5% risk, discuss using a moderate-intensity statin if any risk-enhancing factors are present; B. For ≥7.5% to 20% risk, discuss using moderate-intensity statins and increase to high-intensity statins if risk enhancers are present; C. For ≥20% risk discuss initiating high-intensity statins to reduce LDL-C by ≥50%; ASCVD risk enhancers include: family history of premature ASCVD, persistently elevated LDL-C ≥160 mg/dL, chronic kidney disease, metabolic syndrome, conditions specific to women (e.g., preeclampsia, premature menopause), inflammatory diseases (especially rheumatoid arthritis, psoriasis, HIV), ethnicity (e.g., South Asian ancestry), persistently elevated triglycerides ≥175 mg/dL.; Additional risk enhancers in selected individuals if measured include: hs-CRP ≥2.0 mg/L, Lp(a) levels >50mg/dL, and ankle-brachial index <0.9.
Veterans Affairs/Department of Defense^63^ | 2014 – update currently underway | - In patients with an estimated 10-year CVD risk of ≥12%, initiate a moderate-dose statin; - In patients with a 10-year CVD risk of 6% to 12%, consider a moderate-dose statin following a discussion of benefits and harms and exploring patient values and preferences
Canadian Cardiovascular Society^200^ | 2016 | Assess CVD risk using the Framingham Risk Score or the Cardiovascular Life Expectancy Model.; - In patients with an estimated 10-year CVD risk <10%, do not use statins to decrease risk of CVD events; - In patients with a 10-year CVD risk 10% to 19% with LDL-C 3.5 mmol/L, use statin therapy; statin therapy should also be considered in patients with LDL-C <3.5 mmol/L when specific risk factors are present; - In patients with an estimated 10-year CVD risk ≥20%, use statin therapy
United Kingdom National Institute for Health and Care Excellence^201^ | 2014 | Assess 10-year risk of CVD events using the QRISK2 tool and offer atorvastatin 20 mg to patients with ≥10% risk
European Society of Cardiology/European Atherosclerosis Society^202^ | 2019 | Assess 10-year risk of fatal CVD using SCORE and prescribe a high-intensity statin up to the highest tolerated dose to reach goals set for the specific level of risk

Abbreviations: ASCVD = atherosclerotic cardiovascular disease; CVD = cardiovascular disease; hs-CRP = high-sensitivity C-reactive protein; HIV=human immunodeficiency virus; LDL-C = low-density lipoprotein cholesterol; SCORE = Systemic Coronary Risk Estimation.

In 2014, the Veterans Affairs/Department of Defense issued recommendations on use of statins for primary prevention.^63^ It recommended initiation of a moderate-dose statin in persons with an estimated 10-year cardiovascular risk of ≥12 percent, and shared decisionmaking in persons at 6 percent to 12 percent risk.

Drugs in the proprotein convertase subtilisin/kexin type 9 (PCSK9) class were introduced around the time of the 2016 USPSTF recommendation. Medications in this class have potent LDL lowering effects. However, these medications are not recommended as first-line therapy for primary prevention and are typically used as add-on therapy to statins or other lipid-lowering agents for secondary prevention.^64^