# Appendix E Results of Sensitivity Analyses Excluding ALLHAT-LLT for Pooled Estimates of Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Outcome | Pooled Estimate
All-cause mortality | 17 RCTs; RR 0.89, 95% CI, 0.83 to 0.96; I^2^=0%; ARD −0.36%, 95% CI, −0.58 to −0.14; NNT 278
Cardiovascular mortality | 11 RCTs; RR 0.85, 95% CI, 0.73 to 0.98; I^2^=0%; ARD −0.13%, 95% CI, −0.25 to −0.02; NNT 769
Fatal or nonfatal stroke | 14 RCTs; RR 0.75, 95% CI, 0.65 to 0.87; I^2^=14%; ARD −0.40%, 95% CI, −0.55 to −0.25; NNT 250
Fatal or nonfatal MI | 11 RCTs; RR 0.65, 95% CI, 0.58 to 0.72; I^2^=0%; ARD −0.85%, 95% CI, −1.24 to −0.45; NNT 117
Revascularization | 9 RCTs; RR 0.65, 95% CI, 0.57 to 0.74; I^2^=0%; ARD −0.59%, 95% CI, −0.77 to −0.40; NNT 169

Abbreviations: ARD=absolute risk difference; CI=confidence interval; NNT=number needed to treat; RCT=randomized controlled trial; RR=relative risk