# Appendix C Meta-Analyses

## Appendix C1 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on All-Cause Mortality

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C1 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on All-Cause Mortality. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 18 studies, with a pooled risk ratio of 0.92 (95% confidence interval, 0.87 to 0.98) and an overall I-squared value of 0%.

## Appendix C2 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Cardiovascular Mortality

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C2 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Cardiovascular Mortality. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 12 studies, with a pooled risk ratio of 0.91 (95% confidence interval, 0.81 to 1.02) and an overall I-squared value of 0%.

## Appendix C3 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Fatal or Nonfatal Stroke

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C3 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Fatal or Nonfatal Stroke. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 15 studies, with a pooled risk ratio of 0.78 (95% confidence interval, 0.68 to 0.90) and an overall I-squared value of 22%.

## Appendix C4 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Fatal Stroke

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C4 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Fatal Stroke. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.73 (95% confidence interval, 0.35 to 1.50) and an overall I-squared value of 29%.

## Appendix C5 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Nonfatal Stroke

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C5 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Nonfatal Stroke. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.57 (95% confidence interval, 0.41 to 0.81) and an overall I-squared value of 0%.

## Appendix C6 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Fatal or Nonfatal MI

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C6 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin Fatal or Nonfatal MI. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 12 studies, with a pooled risk ratio of 0.67 (95% confidence interval, 0.60 to 0.75) and an overall I-squared value of 14%.

## Appendix C7 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Fatal MI

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C7 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Fatal MI. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 6 studies, with a pooled risk ratio of 0.83 (95% confidence interval, 0.51 to 1.37) and an overall I-squared value of 23%.

## Appendix C8 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Nonfatal MI

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C8 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Nonfatal MI. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 8 studies, with a pooled risk ratio of 0.60 (95% confidence interval, 0.47 to 0.75) and an overall I-squared value of 19%.

## Appendix C9 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Revascularization

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C9 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Revascularization. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 0.71 (95% confidence interval, 0.63 to 0.80) and an overall I-squared value of 15%.

## Appendix C10 Meta-Analysis: Effect of Statins vs. Placebo or No Statin on Composite Cardiovascular Outcomes

Abbreviations: CHD= coronary heart disease; CI=confidence interval; CV=cardiovascular; CVA=cerebrovascular accident; df=degrees of freedom; MH=Mantel–Haenszel; MI=myocardial infarction; TIA=transient ischemic attack

Note: See Appendix D for trial name abbreviations

*Primary prevention population only.

Appendix C10 is a forest plot titled Meta-Analysis: Effect of Statins Versus Placebo or No Statin on Composite Cardiovascular Outcomes. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 15 studies, with a pooled risk ratio of 0.72 (95% confidence interval, 0.64 to 0.81) and an overall I-squared value of 51%.

## Appendix C11 Funnel Plot: Randomized, Controlled Trials of the Effect of Statins vs. Placebo or No Statin on All-Cause Mortality

p for Egger’s test=0.133

Abbreviations: RR=relative risk; SE=standard error

Appendix C11 is titled Funnel Plot: RCTs of the Effect of Statins Versus Placebo or No Statin on All-Cause Mortality. There are circular symbols representing individual studies, plotted on an x-axis of risk ratios (from 0.01 to 100) and a y-axis of the standard error of the logarithm of the risk ratios (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall. The p-value from Egger’s test is 0.133.

## Appendix C12 Funnel Plot: Randomized, Controlled Trials of the Effect of Statins vs. Placebo or No Statin on Cardiovascular Mortality

p for Egger’s test=0.026

Abbreviations: RR=relative risk; SE=standard error

Appendix C12 is titled Funnel Plot: RCTs of the Effect of Statins Versus Placebo or No Statin on Cardiovascular Mortality. There are circular symbols representing individual studies, plotted on an x-axis of risk ratios (from 0.01 to 100) and a y-axis of the standard error of the risk ratio (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall. The p-value from Egger’s test is 0.026.

## Appendix C13 Funnel Plot: Randomized, Controlled Trials of the Effect of Statins vs. Placebo or No Statin on Fatal or Nonfatal Stroke

p for Egger’s test=0.076

Abbreviations: RR=relative risk; SE=standard error

Appendix C13 is titled Funnel Plot: RCTs of the Effect of Statins Versus Placebo or No Statin on Fatal or Nonfatal Stroke. There are circular symbols representing individual studies, plotted on an x-axis of risk ratio (from 0.01 to 100) and a y-axis of the standard error of the risk ratio (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall. The p-value from Egger’s test is 0.076.

## Appendix C14 Funnel Plot: Randomized, Controlled Trials of the Effect of Statins vs. Placebo or No Statin on Fatal or Nonfatal MI

p for Egger’s test=0.090.

Abbreviations: RR=relative risk; SE=standard error.

Appendix C14 is titled Funnel Plot: RCTs of the Effect of Statins Versus Placebo or No Statin on Fatal or Nonfatal MI. There are circular symbols representing individual studies, plotted on an x-axis of risk ratio (from 0.01 to 100) and a y-axis of the standard error of the risk ratio (from 2 to 0). A dotted center line represents the pooled estimate, around which most studies fall. The p-value from Egger’s test is 0.090.

## Appendix C15 Funnel Plot: Randomized, Controlled Trials of the Effect of Statins vs. Placebo or No Statin on Revascularization

p for Egger’s test=0.653

Abbreviations: RR=relative risk; SE=standard error

Appendix C15 is titled Funnel Plot: RCTs of the Effect of Statins Versus Placebo or No Statin on Revascularization. There are circular symbols representing individual studies, plotted on an x-axis of risk ratio (from 0.01 to 100) and a y-axis of the standard error of the risk ratio (from 1 to 0). A dotted center line represents the pooled estimate, around which most studies fall. The p-value from Egger’s test is 0.653.

## Appendix C16 Funnel Plot: Randomized, Controlled Trials of the Effect of Statins vs. Placebo or No Statin on Composite Cardiovascular Outcomes

p for Egger’s test=0.142

Abbreviations: RR=relative risk; SE=standard error

Appendix C16 is titled Funnel Plot: RCTs of the Effect of Statins Versus Placebo or No Statin on Composite CV Outcomes. There are circular symbols representing individual studies, plotted on an x-axis of risk ratio (from 0.01 to 100) and a y-axis of the standard error of the risk ratio (from 1 to 0). A dotted center line represents the pooled estimate, around which most studies fall. The p-value from Egger’s test is 0.142.

## Appendix C17 Meta-Analysis: Outcomes of Randomized, Controlled Trials of Statins vs. Placebo or No Statin in the Primary Prevention Population Older Than Age 70 Years

Abbreviations: CI=confidence interval; CV=cardiovascular; df=degrees of freedom; MH=Mantel–Haenszel; MI=myocardial infarction.

Note: See Appendix D for trial name abbreviations.

*Primary prevention population only.

Appendix C17 is a forest plot titled Meta-Analysis: Outcomes of RCTs of Statins Versus Placebo or No Statin in the Primary Prevention Population Over Age 70 Years. There is a table divided into four subgroups, each listing the analyzed studies, events and totals in statin and control groups, weight, risk ratio, and 95% confidence interval for each subgroup. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. For All-cause mortality subgroup, risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.96 (95% confidence interval, 0.62 to 1.48) and an overall I-squared value of 89%. For Fatal and nonfatal stroke, risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.87 (95% confidence interval, 0.58 to 1.30) and an overall I-squared value of 55%. For Fatal and nonfatal MI, risk ratios were reported or calculated for 2 studies, with a pooled risk ratio of 0.67 (95% confidence interval, 0.47 to 0.96) and an overall I-squared value of 0%. For Composite CV outcomes, risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 0.77 (95% confidence interval, 0.57 to 1.04) and an overall I-squared value of 68%.

## Appendix C18 Meta-Analysis: Withdrawals Due to Adverse Events in Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C18 is a forest plot titled Meta-Analysis: Withdrawals Due to Adverse Events in Randomized Controlled Trials of Statins Versus Placebo or No Statin. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 0.97 (95% confidence interval, 0.78 to 1.19) and an overall I-squared value of 84%.

## Appendix C19 Meta-Analysis: Serious Adverse Events in Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C19 is a forest plot titled Meta-Analysis: Serious Adverse Events in Randomized Controlled Trials of Statins Versus Placebo or No Statin. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 0.97 (95% confidence interval, 0.93 to 1.01) and an overall I-squared value of 0%.

## Appendix C20 Meta-Analysis: Cancer in Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C20 is a forest plot titled Meta-Analysis: Cancer in Randomized Controlled Trials of Statins Versus Placebo or No Statin. There is a table divided into two subgroups, each listing the analyzed studies, events and totals in statin and control groups, weight, risk ratio, and 95% confidence interval. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. For Any cancer subgroup, risk ratios were reported or calculated for 13 studies, with a pooled risk ratio of 0.98 (95% confidence interval, 0.91 to 1.04) and an overall I-squared value of 0%. For Fatal cancer, risk ratios were reported or calculated for 6 studies, with a pooled risk ratio of 0.89 (95% confidence interval, 0.66 to 1.19) and an overall I-squared value of 56%.

## Appendix C21 Meta-Analysis: Incident Diabetes in Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C21 is a forest plot titled Meta-Analysis: Incident Diabetes in Randomized Controlled Trials of Statins Versus Placebo or No Statin. There is a table listing the analyzed studies, events and totals in statin and control groups, weight, and risk ratio and 95% confidence interval for each study, as well as a row of totals and a pooled estimate on the left side, and a graph of the individual and pooled risk ratios on the right. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. Risk ratios were reported or calculated for 6 studies, with a pooled risk ratio of 1.04 (95% confidence interval, 0.92 to 1.19) and an overall I-squared value of 52%.

## Appendix C22 Meta-Analysis: Muscle Abnormalities in Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C22 is a forest plot titled Meta-Analysis: Muscle Abnormalities in Randomized Controlled Trials of Statins Versus Placebo or No Statin. There is a table divided into three subgroups, each listing the analyzed studies, events and totals in statin and control groups, weight, risk ratio, and 95% confidence interval. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. For Myalgia subgroup, risk ratios were reported or calculated for 9 studies, with a pooled risk ratio of 0.98 (95% confidence interval, 0.86 to 1.11) and an overall I-squared value of 30%. For Myopathy, risk ratios were reported or calculated for 3 studies, with a pooled risk ratio of 1.09 (95% confidence interval, 0.48 to 2.47) and an overall I-squared value of 0%. For Rhabdomyolysis, risk ratios were reported or calculated for 8 studies, with a pooled risk ratio of 1.54 (95% confidence interval, 0.36 to 6.64) and an overall I-squared value of 0%.

## Appendix C23 Meta-Analysis: Liver Abnormalities in Randomized, Controlled Trials of Statins vs. Placebo or No Statin

Abbreviations: ALT=alanine aminotransferase; AST= aspartate aminotransferase; CI=confidence interval; df=degrees of freedom; MH=Mantel–Haenszel

Note: See Appendix D for trial name abbreviations

Appendix C23 is a forest plot titled Meta-Analysis: Liver Abnormalities in Randomized Controlled Trials of Statins Versus Placebo or No Statin. There is a table divided into three subgroups, each listing the analyzed studies, events and totals in statin and control groups, weight, risk ratio, and 95% confidence. Risk ratios in the graph are represented by squares for individual studies and a diamond for the pooled estimate. For ALT elevation subgroup, risk ratios were reported or calculated for 10 studies, with a pooled risk ratio of 0.94 (95% confidence interval, 0.78 to 1.13) and an overall I-squared value of 0%. For AST elevation, risk ratios were reported or calculated for 4 studies, with a pooled risk ratio of 1.30 (95% confidence interval, 0.78 to 2.17) and an overall I-squared value of 35%. For ALT or AST elevation, risk ratios were reported or calculated for 2 studies, with a pooled risk ratio of 1.61 (95% confidence interval, 0.78 to 3.33) and an overall I-squared value of 0%.