# Appendix B Evidence Tables and Quality Tables

## Appendix B1 Evidence Table for Randomized, Controlled Trials: Key Questions 1 and 2

## Appendix B2 Evidence Table for Randomized, Controlled Trials: Key Question 3

## Appendix B3 Quality Assessment for Randomized, Controlled Trials

## Appendix B4 Quality Assessment for Observational Studies