# Appendix A Detailed Methods

## Appendix A1 Search Strategies

Database: Ovid MEDLINE(R) ALL 1946 to November 12, 2021

1. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
2. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin or statin*).ti,ab,kf.
3. (altoprev or crestor or ezallor or flolipid or lescol or lipex or lipitor or livalo or pravachol or zocor).ti,ab,kf.
4. or/1-3
5. exp Cardiovascular Diseases/
6. (cardiovascular or CVD or coronary of CHD or CD or heart or myocardial or infarc* or vascular* or angina or revascular* or “transient ischemic attack” or stroke or cerebrovascular or TIA).ti,ab,kf.
7. 5 or 6
8. Primary Prevention/
9. (prevent* or avoid* or asymptomatic).ti,ab,kf.
10. 8 or 9
11. 4 and 7 and 10
12. (201605$ or 201606$ or 201607$ or 201608$ or 201609$ or 20161$ or 2017$ or 2018$ or 2019$ or 2020$).dp,dt,ed,ep.
13. (“2016 05 $” or “2016 06 $” or “2016 07 $” or “2016 08 $” or “2016 09 $” or “2016 1$”).dp,dt,ed,ep.
14. (“2016 may $” or “2016 jun $” or “2016 jul $” or “2016 aug $” or “2016 sep $” or “2016 oct $” or “2016 nov $” or “2016 dec $”).dp,dt,ed,ep.
15. or/12-14
16. 11 and 15
17. randomized controlled trial.pt.
18. (random* or placebo* or control* or trial or blind*).ti,ab.
19. (animals not humans).sh. (4665913)
20. (comment or editorial or meta-analysis or practice-guideline or review or letter).pt.
21. (17 or 18) not (19 or 20)
22. exp cohort studies/
23. cohort$.tw.
24. controlled clinical trial.pt.
25. exp case-control studies/
26. (case$ and control$).tw.
27. (retrospective* or prospective*).tw.
28. or/22-27
29. 16 and 21
30. limit 16 to randomized controlled trial
31. 29 or 30
32. 16 and 28
33. (systematic or “meta analysis” or metaanalysis or Medline).ti,ab,kf.
34. 16 and 33
35. 31 or 32 or 34
36. limit 35 to english language

Database: EBM Reviews - Cochrane Central Register of Controlled Trials November 12, 2021

1. exp Hydroxymethylglutaryl-CoA Reductase Inhibitors/
2. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin or statin*).ti,ab.
3. (altoprev or crestor or ezallor or flolipid or lescol or lipex or lipitor or livalo or pravachol or zocor).ti,ab.
4. or/1-3
5. exp Cardiovascular Diseases/
6. (cardiovascular or CVD or coronary of CHD or CD or heart or myocardial or infarc* or vascular* or angina or revascular* or “transient ischemic attack” or stroke or cerebrovascular or TIA).ti,ab.
7. 5 or 6
8. Primary Prevention/
9. (prevent* or avoid* or asymptomatic).ti,ab.
10. 8 or 9
11. 4 and 7 and 10
12. conference abstract.pt.
13. “journal: conference abstract”.pt.
14. “journal: conference review”.pt.
15. “http://.www.who.int/trialsearch*”.so.
16. “https://clinicaltrials.gov*”.so.
17. 12 or 13 or 14 or 15 or 16
18. 11 not 17
19. (201605$ or 201606$ or 201607$ or 201608$ or 2016 09$ or 20161$ or 2017$ or 2018$ or 2019$ or 2020$).yr,up.
20. 18 and 19
21. limit 20 to yr=“2016 -Current”
22. limit 21 to english language

Database: EBM Reviews - Cochrane Database of Systematic Reviews 2005 to November 12, 2021

1. (atorvastatin or fluvastatin or lovastatin or pitavastatin or pravastatin or rosuvastatin or simvastatin or statin*).ti,ab.
2. (cardiovascular or CVD or coronary of CHD or CD or heart or myocardial or infarc* or vascular* or angina or revascular* or “transient ischemic attack” or stroke or cerebrovascular or TIA).ti,ab.
3. (prevent* or avoid* or asymptomatic).ti,ab.
4. 1 and 2 and 3
5. limit 4 to full systematic reviews
6. (“2016” or “2017” or “2018” or “2019” or “2020”).so.
7. 5 and 6

## Appendix A2 Inclusion and Exclusion Criteria

PICOTS Element | Include | Exclude
Populations | Asymptomatic adults without prior CVD events (e.g., myocardial infarction, angina, revascularization, CVA, or transient ischemic attack), including persons at increased risk for CVD events based on 10-year or lifetime individualized CVD risk level or presence of specific CVD risk factors; Specific populations of interest: Age, sex, race/ethnicity, CVD risk factors, estimated CVD risk, comorbidities, socioeconomic status | Populations younger than age 18 years or with a prior CVD-related event or familial dyslipidemia
Interventions | Statin therapy | Other drugs or non-drug interventions (e.g., diet, exercise)
Comparators | KQs 1a, 1c, 2: Placebo, no treatment or usual care without a statin (or other lipid-lowering medication); KQ 1b: Dosing statin to target low-density lipoprotein cholesterol level vs. fixed dose therapy; KQ 3: Higher- vs. lower-intensity statin therapy | Other comparisons
Outcomes | KQs 1, 3: CHD- and/or CVA-related morbidity or mortality; all-cause mortality; quality of life; KQ 2: Myopathy, rhabdomyolysis, myalgia, cognitive loss, diabetes, cataracts, elevations in liver function tests or creatinine phosphokinase levels | Intermediate outcomes (e.g., lipid levels, measures of atherosclerosis such as intima media thickness or coronary artery calcium score)
Settings | Primary care or primary care–generalizable settings | Settings not generalizable to primary care
Study Designs | KQs 1–3: RCTs, without publication date limitations; KQ 2: Large cohort studies (n>10,000) and case-control studies (>500 cases) on harms of statins vs. no statin for primary prevention | Case series, case reports; poor-quality studies

Abbreviations: CHD=coronary heart disease; CVA=cerebrovascular accident (stroke); CVD=cardiovascular disease; KQ=key question; PICOTS = Population, Intervention, Comparators, Outcomes, Timing, Settings; RCT=randomized, controlled trial.

## Appendix A3 Literature Flow Diagram

*Other sources include prior reports, reference lists of relevant articles, systematic reviews, etc.

^†^Some studies were included for multiple KQs.

^‡^KQ1b and KQ2b were not included in the prior review, though prior included studies provided evidence for the KQs.

^§^KQ1c was KQ1b in the prior review.

Abbreviation: KQ = key question; RCT=randomized, controlled trial.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 2095 abstracts of potentially relevant articles were identified through MEDLINE and Cochrane databases, as well as other sources. 303 articles were reviewed at the full-text level after excluding 1792 non-relevant abstracts and background articles. From the 303 articles reviewed for inclusion, 240 were excluded. Articles were excluded due to wrong population (45), wrong intervention (8), wrong outcomes (48), wrong comparison (4), wrong study design for key question (43), inadequate duration (3), wrong publication type (19), in systematic review but not directly used (27), sample size too small (3), background only (18), included for contextual questions (16), or excluded prior report include (6). After excluding these studies, 23 studies in 60 publications were included that provide evidence for the key questions, as follows: 23 trials for Key Question 1a, 10 trials for Key Question 1b, 3 trials for Key Question 1c, 19 trials and 3 observational studies for Key Question 2a, 4 trials for Key Question 2b, and 4 trials (direct evidence) for Key Question 3.

## Appendix A4 Included Studies List

1 Albert MA, Glynn RJ, Fonseca FA, . Race, ethnicity, and the efficacy of rosuvastatin in primary prevention: the Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) trial. Am Heart J. 2011 Jul;162(1):106–14.e2. doi: 10.1016/j.ahj.2011.03.032. PMID: 21742096.21742096
2 Anderssen SA, Hjelstuen AK, Hjermann I, . Fluvastatin and lifestyle modification for reduction of carotid intima-media thickness and left ventricular mass progression in drug-treated hypertensives. Atherosclerosis. 2005 Feb;178(2):387–97. doi: 10.1016/j.atherosclerosis.2004.08.033. PMID: 15694949.15694949
3 Asselbergs FW, Diercks GF, Hillege HL, . Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation. 2004 Nov 2;110(18):2809–16. doi: 10.1161/01.Cir.0000146378.65439.7a. PMID: 15492322.15492322
4 Beishuizen ED, van de Ree MA, Jukema JW, . Two-year statin therapy does not alter the progression of intima-media thickness in patients with type 2 diabetes without manifest cardiovascular disease. Diabetes Care. 2004 Dec;27(12):2887–92. doi: 10.2337/diacare.27.12.2887. PMID: 15562202.15562202
5 Bone HG, Kiel DP, Lindsay RS, . Effects of atorvastatin on bone in postmenopausal women with dyslipidemia: a double-blind, placebo-controlled, dose-ranging trial. J Clin Endocrinol Metab. 2007 Aug 28;92(12):4671–7. doi: 10.1210/jc.2006-1909. PMID: 17726081.17726081
6 Bosch J, Lonn EM, Dagenais GR, . Antihypertensives and Statin Therapy for Primary Stroke Prevention: a Secondary Analysis of the HOPE-3 Trial. Stroke. 2021 PMID: 33985364.33985364
7 Chan KL, Teo K, Dumesnil JG, . Effect of Lipid lowering with rosuvastatin on progression of aortic stenosis: results of the aortic stenosis progression observation: measuring effects of rosuvastatin (ASTRONOMER) trial. Circulation. 2010 Jan 19;121(2):306–14. doi: 10.1161/circulationaha.109.900027. PMID: 20048204.20048204
8 Colhoun HM, Betteridge DJ, Durrington PN, . Effects of atorvastatin on kidney outcomes and cardiovascular disease in patients with diabetes: an analysis from the Collaborative Atorvastatin Diabetes Study (CARDS). Am J Kidney Dis. 2009 Nov;54(5):810–9. doi: 10.1053/j.ajkd.2009.03.022. PMID: 19540640.19540640
9 Colhoun HM, Betteridge DJ, Durrington PN, . Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet. 2004 Aug 21–27;364(9435):685–96. doi: 10.1016/s0140-6736(04)16895-5. PMID: 15325833.15325833
10 Colhoun HM, Thomason MJ, Mackness MI, . Design of the Collaborative AtoRvastatin Diabetes Study (CARDS) in patients with type 2 diabetes. Diabet Med. 2002 Mar;19(3):201–11. doi: 10.1046/j.1464-5491.2002.00643.x. PMID: 11918622.11918622
11 Collier DJ, Poulter NR, Dahlöf B, . Impact of atorvastatin among older and younger patients in the Anglo-Scandinavian Cardiac Outcomes Trial lipid-lowering arm. J Hypertens. 2011 Mar;29(3):592–9. doi: 10.1097/HJH.0b013e328342c8f7. PMID: 21297502.21297502
12 Crouse JR, 3rd, Raichlen JS, Riley WA, . Effect of rosuvastatin on progression of carotid intima-media thickness in low-risk individuals with subclinical atherosclerosis: the METEOR Trial. JAMA. 2007 Mar 28;297(12):1344–53. doi: 10.1001/jama.297.12.1344. PMID: 17384434.17384434
13 Culver AL, Ockene IS, Balasubramanian R, . Statin use and risk of diabetes mellitus in postmenopausal women in the Women’s Health Initiative. Arch Intern Med. 2012 Jan 23;172(2):144–52. doi: 10.1001/archinternmed.2011.625. PMID: 22231607.22231607
14 Downs JR, Clearfield M, Tyroler HA, . Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TEXCAPS): additional perspectives on tolerability of long-term treatment with lovastatin. Am J Cardiol. 2001 May 1;87(9):1074–9. doi: 10.1016/s0002-9149(01)01464-3. PMID: 11348605.11348605
15 Downs JR, Clearfield M, Weis S, . Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS. Air Force/Texas Coronary Atherosclerosis Prevention Study. JAMA. 1998 May 27;279(20):1615–22. doi: 10.1001/jama.279.20.1615. PMID: 9613910.9613910
16 Ford I, Blauw GJ, Murphy MB, . A Prospective Study of Pravastatin in the Elderly at Risk (PROSPER): screening experience and baseline characteristics. Curr Control Trials Cardiovasc Med. 2002 May 20;3(1):8. doi: 10.1186/1468-6708-3-8. PMID: 12097148.12097148
17 Freeman DJ, Norrie J, Sattar N, . Pravastatin and the development of diabetes mellitus: evidence for a protective treatment effect in the West of Scotland Coronary Prevention Study. Circulation. 2001 Jan 23;103(3):357–62. doi: 10.1161/01.cir.103.3.357. PMID: 11157685.11157685
18 Furberg C, and TAO, ALLHAT Cft, . Major outcomes in moderately hypercholesterolemic, hypertensive patients randomized to pravastatin vs usual care: the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT-LLT). JAMA. 2002 Dec 18;288(23):2998–3007. doi: 10.1001/jama.288.23.2998. PMID: 12479764.12479764
19 Furberg CD, Adams HP, Jr., Applegate WB, . Effect of lovastatin on early carotid atherosclerosis and cardiovascular events. Asymptomatic Carotid Artery Progression Study (ACAPS) Research Group. Circulation. 1994 Oct;90(4):1679–87. doi: 10.1161/01.cir.90.4.1679. PMID: 7734010.7734010
20 Glynn RJ, Koenig W, Nordestgaard BG, . Rosuvastatin for primary prevention in older persons with elevated C-reactive protein and low to average low-density lipoprotein cholesterol levels: exploratory analysis of a randomized trial. Ann Intern Med. 2010 Apr 20;152(8):488–96, w174. doi: 10.7326/0003-4819-152-8-201004200-00005. PMID: 20404379.20404379
21 Gotto AM, Jr. Establishing the benefit of statins in low-to-moderate--risk primary prevention: the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Atherosclerosis. Supplements. 2007 Aug;8(2):3–8. doi: 10.1016/j.atherosclerosissup.2007.02.002. PMID: 17588826.17588826
22 Gotto AM, Jr., Whitney E, Stein EA, . Application of the National Cholesterol Education Program and joint European treatment criteria and clinical benefit in the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Eur Heart J. 2000 Oct;21(19):1627–33. doi: 10.1053/euhj.2000.2288. PMID: 10988016.10988016
23 Gotto AM, Jr., Whitney E, Stein EA, . Relation between baseline and on-treatment lipid parameters and first acute major coronary events in the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Circulation. 2000 Feb 8;101(5):477–84. doi: 10.1161/01.cir.101.5.477. PMID: 10662743.10662743
24 Han BH, Sutin D, Williamson JD, . Effect of statin treatment vs usual care on primary cardiovascular prevention among older adults: the ALLHAT-LLT randomized clinical trial. JAMA Intern Med. 2017 Jul 01;177(7):955–65. doi: 10.1001/jamainternmed.2017.1442. PMID: 28531241.28531241
25 Heljić B, Velija-Asimi Z, Kulić M. The statins in prevention of coronary heart diseases in type 2 diabetics. Bosn J Basic Med Sci. 2009 Feb;9(1):71–6. doi: 10.17305/bjbms.2009.2860. PMID: 19284399.19284399
26 Itoh H, Komuro I, Takeuchi M, . Intensive treat-to-target statin therapy in high-risk Japanese patients with hypercholesterolemia and diabetic retinopathy: report of a randomized study. Diabetes Care. 2018 Jun;41(6):1275–84. doi: 10.2337/dc17-2224. PMID: 29626074.29626074
27 Jick SS, Bradbury BD. Statins and newly diagnosed diabetes. Br J Clin Pharmacol. 2004 Sep;58(3):303–9. doi: 10.1111/j.1365-2125.2004.02142.x. PMID: 15327590.15327590
28 Kitas GD, Nightingale P, Armitage J, . A multicenter, randomized, placebo-controlled trial of atorvastatin for the primary prevention of cardiovascular events in patients with rheumatoid arthritis. Arthritis rheumatol. 2019 Sep;71(9):1437–49. doi: 10.1002/art.40892. PMID: 30983166.30983166
29 Knopp RH, d’Emden M, Smilde JG, . Efficacy and safety of atorvastatin in the prevention of cardiovascular end points in subjects with type 2 diabetes: the Atorvastatin Study for Prevention of Coronary Heart Disease Endpoints in non-insulin-dependent diabetes mellitus (ASPEN). Diabetes Care. 2006 Jul;29(7):1478–85. doi: 10.2337/dc05-2415. PMID: 16801565.16801565
30 Koenig W, Ridker PM. Rosuvastatin for primary prevention in patients with European systematic coronary risk evaluation risk ≥ 5% or Framingham risk >20%: post hoc analyses of the JUPITER trial requested by European health authorities. Eur Heart J. 2011 Jan;32(1):75–83. doi: 10.1093/eurheartj/ehq370. PMID: 20971747.20971747
31 Kushiro T, Mizuno K, Nakaya N, . Pravastatin for cardiovascular event primary prevention in patients with mild-to-moderate hypertension in the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) study. Hypertension (Dallas, Tex. : 1979). 2009 Feb;53(2):135–41. doi: 10.1161/hypertensionaha.108.120584. PMID: 19104004.19104004
32 Lonn E, Bosch J, Pogue J, . Novel approaches in primary cardiovascular disease prevention: the HOPE-3 trial rationale, design, and participants’ baseline characteristics. Can J Cardiol. 2016 Mar;32(3):311–8. doi: 10.1016/j.cjca.2015.07.001. PMID: 26481083.26481083
33 Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study Group. Design and baseline characteristics of a study of primary prevention of coronary events with pravastatin among Japanese with mildly elevated cholesterol levels. Circ J. 2004 Sep;68(9):860–7. doi: 10.1253/circj.68.860. PMID: 15329509.15329509
34 Mercuri M, Bond MG, Sirtori CR, . Pravastatin reduces carotid intima-media thickness progression in an asymptomatic hypercholesterolemic mediterranean population: the Carotid Atherosclerosis Italian Ultrasound Study. Am J Med. 1996 Dec;101(6):627–34. doi: 10.1016/s0002-9343(96)00333-6. PMID: 9003110.9003110
35 Mizuno K, Nakaya N, Ohashi Y, . Usefulness of pravastatin in primary prevention of cardiovascular events in women: analysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA study). Circulation. 2008 Jan 29;117(4):494–502. doi: 10.1161/circulationaha.106.671826. PMID: 18172039.18172039
36 Mora S, Glynn RJ, Hsia J, . Statins for the primary prevention of cardiovascular events in women with elevated high-sensitivity C-reactive protein or dyslipidemia: results from the Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin (JUPITER) and meta-analysis of women from primary prevention trials. Circulation. 2010 Mar 9;121(9):1069–77. doi: 10.1161/circulationaha.109.906479. PMID: 20176986.20176986
37 Muldoon MF, Ryan CM, Sereika SM, . Randomized trial of the effects of simvastatin on cognitive functioning in hypercholesterolemic adults. Am J Med. 2004 Dec 1;117(11):823–9. doi: 10.1016/j.amjmed.2004.07.041. PMID: 15589485.15589485
38 Nakamura H, Arakawa K, Itakura H, . Primary prevention of cardiovascular disease with pravastatin in Japan (MEGA Study): a prospective randomised controlled trial. Lancet. 2006 Sep 30;368(9542):1155–63. doi: 10.1016/s0140-6736(06)69472-5. PMID: 17011942.17011942
39 Nakamura H, Mizuno K, Ohashi Y, . Pravastatin and cardiovascular risk in moderate chronic kidney disease. Atherosclerosis. 2009 Oct;206(2):512–7. doi: 10.1016/j.atherosclerosis.2009.03.031. PMID: 19423108.19423108
40 Nakaya N, Mizuno K, Ohashi Y, . Low-dose pravastatin and age-related differences in risk factors for cardiovascular disease in hypercholesterolaemic Japanese: analysis of the management of elevated cholesterol in the primary prevention group of adult Japanese (MEGA study). Drugs Aging. 2011 Sep 1;28(9):681–92. doi: 10.2165/11595620-000000000-00000. PMID: 21815708.21815708
41 Neil HA, DeMicco DA, Luo D, . Analysis of efficacy and safety in patients aged 65-75 years at randomization: Collaborative Atorvastatin Diabetes Study (CARDS). Diabetes Care. 2006 Nov;29(11):2378–84. doi: 10.2337/dc06-0872. PMID: 17065671.17065671
42 Newman CB, Szarek M, Colhoun HM, . The safety and tolerability of atorvastatin 10 mg in the Collaborative Atorvastatin Diabetes Study (CARDS). Diab Vasc Dis Res. 2008 Sep;5(3):177–83. doi: 10.3132/dvdr.2008.029. PMID: 18777490.18777490
43 Nishiwaki M, Ikewaki K, Ayaori M, . Risk reductions for cardiovascular disease with pravastatin treatment by dyslipidemia phenotype: a post hoc analysis of the MEGA Study. J Cardiol. 2013 Mar;61(3):196–200. doi: 10.1016/j.jjcc.2012.10.005. PMID: 23265677.23265677
44 Porath A, Arbelle JE, Fund N, . Statin therapy: diabetes mellitus risk and cardiovascular benefit in primary prevention. Isr Med Assoc J. 2018 Aug;20(8):480–5. PMID: 30084572.30084572
45 Ridker PM. Rosuvastatin in the primary prevention of cardiovascular disease among patients with low levels of low-density lipoprotein cholesterol and elevated high-sensitivity C-reactive protein: rationale and design of the JUPITER trial. Circulation. 2003 Nov 11;108(19):2292–7. doi: 10.1161/01.Cir.0000100688.17280.E6. PMID: 14609996.14609996
46 Ridker PM, Danielson E, Fonseca FA, . Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med. 2008 Nov 20;359(21):2195–207. doi: 10.1056/NEJMoa0807646. PMID: 18997196.18997196
47 Ridker PM, Fonseca FA, Genest J, . Baseline characteristics of participants in the JUPITER trial, a randomized placebo-controlled primary prevention trial of statin therapy among individuals with low low-density lipoprotein cholesterol and elevated high-sensitivity C-reactive protein. Am J Cardiol. 2007 Dec 1;100(11):1659–64. doi: 10.1016/j.amjcard.2007.09.072. PMID: 18036365.18036365
48 Ridker PM, MacFadyen J, Cressman M, . Efficacy of rosuvastatin among men and women with moderate chronic kidney disease and elevated high-sensitivity C-reactive protein: a secondary analysis from the JUPITER (Justification for the Use of Statins in Prevention-an Intervention Trial Evaluating Rosuvastatin) trial. J Am Coll Cardiol. 2010 Mar 23;55(12):1266–73. doi: 10.1016/j.jacc.2010.01.020. PMID: 20206456.20206456
49 Ridker PM, Macfadyen JG, Nordestgaard BG, . Rosuvastatin for primary prevention among individuals with elevated high-sensitivity c-reactive protein and 5% to 10% and 10% to 20% 10-year risk. Implications of the Justification for Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) trial for “intermediate risk”. Circ Cardiovasc Qual Outcomes. 2010 Sep;3(5):447–52. doi: 10.1161/circoutcomes.110.938118. PMID: 20736443.20736443
50 Ridker PM, Pradhan A, MacFadyen JG, . Cardiovascular benefits and diabetes risks of statin therapy in primary prevention: an analysis from the JUPITER trial. Lancet. 2012 Aug 11;380(9841):565–71. doi: 10.1016/s0140-6736(12)61190-8. PMID: 22883507.22883507
51 Ridker PM, Rifai N, Clearfield M, . Measurement of C-reactive protein for the targeting of statin therapy in the primary prevention of acute coronary events. N Engl J Med. 2001 Jun 28;344(26):1959–65. doi: 10.1056/nejm200106283442601. PMID: 11430324.11430324
52 Salonen R, Nyyssönen K, Porkkala E, . Kuopio Atherosclerosis Prevention Study (KAPS). A population-based primary preventive trial of the effect of LDL lowering on atherosclerotic progression in carotid and femoral arteries. Circulation. 1995 Oct 1;92(7):1758–64. doi: 10.1161/01.cir.92.7.1758. PMID: 7671358.7671358
53 Sever PS, Dahlöf B, Poulter NR, . Prevention of coronary and stroke events with atorvastatin in hypertensive patients who have average or lower-than-average cholesterol concentrations, in the Anglo-Scandinavian Cardiac Outcomes Trial--Lipid Lowering Arm (ASCOT-LLA): a multicentre randomised controlled trial. Lancet. 2003 Apr 5;361(9364):1149–58. doi: 10.1016/s0140-6736(03)12948-0. PMID: 12686036.12686036
54 Sever PS, Dahlöf B, Poulter NR, . Rationale, design, methods and baseline demography of participants of the Anglo-Scandinavian Cardiac Outcomes Trial. ASCOT investigators. J Hypertens. 2001 Jun;19(6):1139–47. doi: 10.1097/00004872-200106000-00020. PMID: 11403364.11403364
55 Sever PS, Poulter NR, Dahlöf B, . Reduction in cardiovascular events with atorvastatin in 2,532 patients with type 2 diabetes: Anglo-Scandinavian Cardiac Outcomes Trial--Lipid-Lowering Arm (ASCOT-LLA). Diabetes Care. 2005 May;28(5):1151–7. doi: 10.2337/diacare.28.5.1151. PMID: 15855581.15855581
56 Shepherd J, Blauw GJ, Murphy MB, . Pravastatin in elderly individuals at risk of vascular disease (PROSPER): a randomised controlled trial. Lancet. 2002 Nov 23;360(9346):1623–30. doi: 10.1016/s0140-6736(02)11600-x. PMID: 12457784.12457784
57 Shepherd J, Blauw GJ, Murphy MB, . The design of a prospective study of Pravastatin in the Elderly at Risk (PROSPER). PROSPER Study Group. PROspective Study of Pravastatin in the Elderly at Risk. Am J Cardiol. 1999 Nov 15;84(10):1192–7. doi: 10.1016/s0002-9149(99)00533-0. PMID: 10569329.10569329
58 Shepherd J, Cobbe SM, Ford I, . Prevention of coronary heart disease with pravastatin in men with hypercholesterolemia. West of Scotland Coronary Prevention Study Group. N Engl J Med. 1995 Nov 16;333(20):1301–7. doi: 10.1056/nejm199511163332001. PMID: 7566020.7566020
59 Sirtori CR, Bianchi G, Bond MG, . Pravastatin intervention trial on carotid artery atherosclerosis in patients with mild hypercholesterolemia: the CAIUS study. Int J Cardiovasc Imaging. 1995;11(2):119–24.
60 Tajima N, Kurata H, Nakaya N, . Pravastatin reduces the risk for cardiovascular disease in Japanese hypercholesterolemic patients with impaired fasting glucose or diabetes: diabetes subanalysis of the Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese (MEGA) Study. Atherosclerosis. 2008 Aug;199(2):455–62. doi: 10.1016/j.atherosclerosis.2008.05.027. PMID: 18635188.18635188
61 Uchiyama S, Nakaya N, Mizuno K, . Risk factors for stroke and lipid-lowering effect of pravastatin on the risk of stroke in Japanese patients with hypercholesterolemia: analysis of data from the MEGA Study, a large randomized controlled trial. J Neurol Sci. 2009 Sep 15;284(1–2):72–6. doi: 10.1016/j.jns.2009.04.002. PMID: 19423132.19423132
62 Vallejo-Vaz AJ, Robertson M, Catapano AL, . Low-density lipoprotein cholesterol lowering for the primary prevention of cardiovascular disease among men with primary elevations of low-density lipoprotein cholesterol levels of 190 mg/dL or above: analyses from the WOSCOPS (West of Scotland Coronary Prevention Study) 5-year randomized trial and 20-year observational follow-up. Circulation. 2017 Nov 14;136(20):1878–91. doi: 10.1161/CIRCULATIONAHA.117.027966. PMID: 28877913.28877913
63 Yusuf S, Bosch J, Dagenais G, . Cholesterol lowering in intermediate-risk persons without cardiovascular disease. N Engl J Med. 2016 May 26;374(21):2021–31. doi: 10.1056/NEJMoa1600176. PMID: 27040132.27040132

## Appendix A5 Excluded Studies With Reasons for Exclusion

1 Adedinsewo D, Taka N, Agasthi P, . Prevalence and factors associated with statin use among a nationally representative sample of US adults: National Health and Nutrition Examination Survey, 2011-2012. Clin Cardiol. 2016 Sep;39(9):491–6. doi: 10.1002/clc.22577. PMID: 27505443. Exclusion reason: Ineligible study design27505443
2 Agarwala A, Kulkarni S, Maddox T. The Association of Statin Therapy with Incident Diabetes: Evidence, Mechanisms, and Recommendations. Curr Cardiol Rep. 2018 May 19;20(7):50. doi: 10.1007/s11886-018-0995-6. PMID: 29779165. Exclusion reason: Ineligible publication type29779165
3 Ahmadizar F, Ochoa-Rosales C, Glisic M, . Associations of statin use with glycaemic traits and incident type 2 diabetes. Br J Clin Pharmacol. 2019 May;85(5):993–1002. doi: 10.1111/bcp.13898. PMID: 30838685. Exclusion reason: Sample size too small30838685
4 Ajala ON, Demler OV, Liu Y, . Anti-inflammatory HDL function, incident cardiovascular events, and mortality: a secondary analysis of the JUPITER randomized clinical trial. J Am Heart Assoc. 2020 Sep;9(17):e016507. doi: 10.1161/jaha.119.016507. PMID: 32799709. Exclusion reason: Ineligible intervention32799709
5 Akintoye E, Briasoulis A, Afonso L. Biochemical risk markers and 10-year incidence of atherosclerotic cardiovascular disease: independent predictors, improvement in pooled cohort equation, and risk reclassification. Am Heart J. 2017 Nov;193:95–103. doi: 10.1016/j.ahj.2017.08.002. PMID: 29129262. Exclusion reason: Ineligible outcome29129262
6 Akinwunmi B, Vitonis AF, Titus L, . Statin therapy and association with ovarian cancer risk in the New England Case Control (NEC) study. Int J Cancer. 2019 Mar 01;144(5):991–1000. doi: 10.1002/ijc.31758. PMID: 30006925. Exclusion reason: Ineligible outcome30006925
7 Al-Gobari M, Al-Aqeel S, Gueyffier F, . Effectiveness of drug interventions to prevent sudden cardiac death in patients with heart failure and reduced ejection fraction: an overview of systematic reviews. BMJ Open. 2018 Jul 28;8(7):e021108. doi: 10.1136/bmjopen-2017-021108. PMID: 30056380. Exclusion reason: Ineligible population30056380
8 Al-Gobari M, Le HH, Fall M, . No benefits of statins for sudden cardiac death prevention in patients with heart failure and reduced ejection fraction: a meta-analysis of randomized controlled trials. PLoS ONE. 2017;12(2):e0171168. doi: 10.1371/journal.pone.0171168. PMID: 28166237. Exclusion reason: Ineligible population28166237
9 Arad Y, Goodman KJ, Roth M, . Coronary calcification, coronary disease risk factors, C-reactive protein, and atherosclerotic cardiovascular disease events: the St. Francis Heart Study. J Am Coll Cardiol. 2005 Jul 5;46(1):158–65. doi: 10.1016/j.jacc.2005.02.088. PMID: 15992651. Exclusion reason: Included for contextual question only15992651
10 Asberg S, Eriksson M. Statin therapy and the risk of intracerebral haemorrhage: a nationwide observational study. Int J Stroke. 2015 Oct;10 Suppl A100:46–9. doi: 10.1111/ijs.12539. PMID: 26043664. Exclusion reason: Ineligible study design26043664
11 Atique M, Naveedshehzad, Khan DM, . Comparative Effectiveness of Atorvastatin (Low Vs High Dose) in Lowering Low-Density Lipoprotein Cholesterol in Intermediate Risk Cardiovascular Patients. Pakistan journal of medical and health sciences. 2020;14(2):312–5. PMID: CN-02203380 NEW. Exclusion reason: Ineligible outcome
12 Aznaouridis K, Masoura C, Vlachopoulos C, . Statins in stroke. Curr Med Chem. 2019;26(33):6174–85. doi: 10.2174/0929867326666190620104539. PMID: 31218948. Exclusion reason: Ineligible publication type31218948
13 Balder JW, de Vries JK, Mulder DJ, . Time to improve statin prescription guidelines in low-risk patients? Eur J Prev Cardiolog. 2017 Jul;24(10):1064–70. doi: 10.1177/2047487317698585. PMID: 28429651. Exclusion reason: Ineligible outcome28429651
14 Basu S, Sussman JB, Rigdon J, . Benefit and harm of intensive blood pressure treatment: derivation and validation of risk models using data from the SPRINT and ACCORD trials. PLoS Med. 2017 Oct;14(10):e1002410. doi: 10.1371/journal.pmed.1002410. PMID: 29040268. Exclusion reason: Ineligible study design29040268
15 Bergen K, Brismar K, Tehrani S. High-dose atorvastatin is associated with lower IGF-1 levels in patients with type 1 diabetes. Growth Horm IGF Res. 2016 Aug;29:78–82. doi: 10.1016/j.ghir.2016.06.001. PMID: 27400272. Exclusion reason: Ineligible outcome27400272
16 Berwanger O, de Barros ESPG, Barbosa RR, . Atorvastatin for high-risk statin-naive patients undergoing noncardiac surgery: the Lowering the Risk of Operative Complications Using Atorvastatin Loading Dose (LOAD) randomized trial. Am Heart J. 2017 Feb;184:88–96. doi: 10.1016/j.ahj.2016.11.001. PMID: 27892891. Exclusion reason: Ineligible population27892891
17 Bezin J, Moore N, Mansiaux Y, . Real-life benefits of statins for cardiovascular prevention in elderly subjects: a population-based cohort study. Am J Med. 2019 Jun;132(6):740–8.e7. doi: 10.1016/j.amjmed.2018.12.032. PMID: 30660573. Exclusion reason: Ineligible study design30660573
18 Bissacco D, Carmo M, Barbetta I, . Medical therapy before carotid endarterectomy: changes over a 13-year period and comparison between asymptomatic and symptomatic patients. Angiology. 2018 Feb;69(2):113–9. doi: 10.1177/0003319717706626. PMID: 28446026. Exclusion reason: Ineligible population28446026
19 Blackburn R, Osborn D, Walters K, . Statin prescribing for people with severe mental illnesses: a staggered cohort study of ‘real-world’ impacts. BMJ Open. 2017 Mar 07;7(3):e013154. doi: 10.1136/bmjopen-2016-013154. PMID: 28270387. Exclusion reason: Ineligible study design28270387
20 Blackburn R, Osborn D, Walters K, . Statin prescribing for prevention of cardiovascular disease amongst people with severe mental illness: cohort study in UK primary care. Schizophr Res. 2018 Feb;192:219–25. doi: 10.1016/j.schres.2017.05.028. PMID: 28599749. Exclusion reason: Ineligible outcome28599749
21 Ble A, Hughes PM, Delgado J, . Safety and effectiveness of statins for prevention of recurrent myocardial infarction in 12 156 typical older patients: a quasi-experimental study. J Gerontol A Biol Sci Med Sci. 2017 Feb;72(2):243–50. doi: 10.1093/gerona/glw082. PMID: 27146371. Exclusion reason: Ineligible population27146371
22 Bonnet F, Benard A, Poulizac P, . Discontinuing statins or not in the elderly? Study protocol for a randomized controlled trial. Trials 2020 Apr 19;21(1):342. doi: 10.1186/s13063-020-04259-5. PMID: 32307005. Exclusion reason: Background32307005
23 Booth JN, 3rd, Colantonio LD, Chen L, . Statin discontinuation, reinitiation, and persistence patterns among Medicare beneficiaries after myocardial infarction: a cohort study. Circ Cardiovasc Qual Outcomes. 2017 Oct;10(10):e003626. doi: 10.1161/CIRCOUTCOMES.117.003626. PMID: 29021332. Exclusion reason: Ineligible population29021332
24 Borghi C, Tubach F, De Backer G, . Lack of control of hypertension in primary cardiovascular disease prevention in Europe: results from the EURIKA study. Int J Cardiol. 2016 Sep 01;218:83–8. doi: 10.1016/j.ijcard.2016.05.044. PMID: 27232917. Exclusion reason: Ineligible study design27232917
25 Bosch J, O’Donnell M, Swaminathan B, . Effects of blood pressure and lipid lowering on cognition: results from the HOPE-3 study. Neurology. 2019 Mar 26;92(13):e1435–e46. doi: 10.1212/WNL.0000000000007174. PMID: 30814321. Exclusion reason: Ineligible outcome30814321
26 Bradford RH, Shear CL, Chremos AN, . Expanded Clinical Evaluation of Lovastatin (EXCEL) study results: I. Efficacy in modifying plasma lipoproteins and adverse event profile in 8245 patients with moderate hypercholesterolemia. Arch Intern Med. 1991 Jan;151(1):43–9. doi: 10.1001/archinte.1991.00400010067008. PMID: 1985608. Exclusion reason: Ineligible population1985608
27 Breuker C, Clement F, Mura T, . Non-achievement of LDL-cholesterol targets in patients with diabetes at very-high cardiovascular risk receiving statin treatment: Incidence and risk factors. Int J Cardiol. 2018 Oct 01;268:195–9. doi: 10.1016/j.ijcard.2018.04.068. PMID: 30041785. Exclusion reason: Ineligible population30041785
28 Brodney S, Valentine KD, Sepucha K, . Patient preference distribution for use of statin therapy. JAMA Netw Open. 2021 Mar 1;4(3):e210661. doi: 10.1001/jamanetworkopen.2021.0661. PMID: 33720368. Exclusion reason: Included for contextual question only33720368
29 Bruckert E, Lièvre M, Giral P, . Short-term efficacy and safety of extended-release fluvastatin in a large cohort of elderly patients. The American journal of geriatric cardiology. 2003 Jul–Aug;12(4):225–31. doi: 10.1111/j.1076-7460.2003.02000.x. PMID: 12888702. Exclusion reason: Inadequate duration12888702
30 Burton JK, Papworth R, Haig C, . Statin use is not associated with future long-term care admission: extended follow-up of two randomised controlled trials. Drugs Aging. 2018 Jul;35(7):657–63. doi: 10.1007/s40266-018-0560-4. PMID: 29916140. Exclusion reason: Ineligible outcome29916140
31 Byrne P, Cullinan J, Gillespie P, . Statins for primary prevention of cardiovascular disease: modelling guidelines and patient preferences based on an Irish cohort. Br J Gen Pract. 2019 Jun;69(683):e373–e80. doi: 10.3399/bjgp19X702701. PMID: 31015226. Exclusion reason: Ineligible outcome31015226
32 Byrne P, Cullinan J, Smith A, . Statins for the primary prevention of cardiovascular disease: an overview of systematic reviews. BMJ Open. 2019 Apr 23;9(4):e023085. doi: 10.1136/bmjopen-2018-023085. PMID: 31015265. Exclusion reason: Source document31015265
33 Cai T, Abel L, Langford O, . Associations between statins and adverse events in primary prevention of cardiovascular disease: systematic review with pairwise, network, and dose-response meta-analyses. Bmj. 2021 07 14;374:n1537. doi: 10.1136/bmj.n1537. PMID: 34261627. Exclusion reason: Source document34261627
34 Cangemi R, Romiti GF, Campolongo G, . Gender related differences in treatment and response to statins in primary and secondary cardiovascular prevention: the never-ending debate. Pharmacol Res. 2017 Mar;117:148–55. doi: 10.1016/j.phrs.2016.12.027. PMID: 28012963. Exclusion reason: Ineligible publication type28012963
35 Cao J, Remaley AT, Guan W, . Performance of novel low-density lipoprotein-cholesterol calculation methods in predicting clinical and subclinical atherosclerotic cardiovascular disease risk: the Multi-Ethnic Study of Atherosclerosis. Atherosclerosis. 2021;327:1–4. PMID: CN-02273051 NEW. Exclusion reason: Source document34004482
36 Castellano JM, Verdejo J, Ocampo S, . Clinical effectiveness of the cardiovascular polypill in a real-life setting in patients with cardiovascular risk: The SORS study. Arch Med Res. 2019 Jan;50(1):31–40. doi: 10.1016/j.arcmed.2019.04.001. PMID: 31101241. Exclusion reason: Ineligible intervention31101241
37 Castilla-Guerra L, Del Carmen Fernandez-Moreno M, Colmenero-Camacho MA. Statins in stroke prevention: present and future. Curr Pharm Des. 2016;22(30):4638–44. doi: 10.2174/1381612822666160510125229. PMID: 27160755. Exclusion reason: Background27160755
38 Cea-Soriano L, Fowkes FGR, Johansson S, . Time trends in peripheral artery disease incidence, prevalence and secondary preventive therapy: a cohort study in The Health Improvement Network in the UK. BMJ Open. 2018 Jan 21;8(1):e018184. doi: 10.1136/bmjopen-2017-018184. PMID: 29358428. Exclusion reason: Ineligible population29358428
39 Cesena FHY, Laurinavicius AG, Valente VA, . Low-density lipoprotein-cholesterol lowering in individuals at intermediate cardiovascular risk: percent reduction or target level? Clin Cardiol. 2018 Mar;41(3):333–8. doi: 10.1002/clc.22868. PMID: 29574925. Exclusion reason: Ineligible outcome29574925
40 Chaffey P, Thompson M, Pai AD, . Usefulness of statins for prevention of venous thromboembolism. Am J Cardiol. 2018 Jun 01;121(11):1436–40. doi: 10.1016/j.amjcard.2018.02.024. PMID: 29576234. Exclusion reason: Ineligible publication type29576234
41 Chan P, Tomlinson B, Lee CB, . Beneficial effects of pravastatin on fasting hyperinsulinemia in elderly hypertensive hypercholesterolemic subjects. Hypertension (Dallas, Tex. : 1979). 1996 Oct;28(4):647–51. doi: 10.1161/01.hyp.28.4.647. PMID: 8843892. Exclusion reason: Inadequate duration8843892
42 Chang AM, Litt HI, Snyder BS, . Impact of coronary computed tomography angiography findings on initiation of cardioprotective medications. Circulation. 2017 Nov 28;136(22):2195–7. doi: 10.1161/CIRCULATIONAHA.117.029994. PMID: 29180497. Exclusion reason: Ineligible intervention29180497
43 Chao TF, Liu CJ, Chen SJ, . Statins and the risk of dementia in patients with atrial fibrillation: a nationwide population-based cohort study. Int J Cardiol. 2015 Oct 01;196:91–7. doi: 10.1016/j.ijcard.2015.05.159. PMID: 26080283. Exclusion reason: Ineligible population26080283
44 Charach G, Argov O, Nochomovitz H, . A longitudinal 20 years of follow up showed a decrease in the survival of heart failure patients who maintained low LDL cholesterol levels. Qjm. 2018 May 01;111(5):319–25. doi: 10.1093/qjmed/hcy043. PMID: 29733423. Exclusion reason: Ineligible population29733423
45 Chen Q, Chen LZ, Guo XH, . Clinical efficacy of statins in the prevention and treatment of coronary heart disease. Biomed Res. 2018;29(2):309–12. Exclusion reason: Ineligible population
46 Chou R, Dana T, Blazina I, . Statins for prevention of cardiovascular disease in adults: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2016 Nov 15;316(19):2008–24. doi: 10.1001/jama.2015.15629. PMID: 27838722. Exclusion reason: Background27838722
47 Chrysant SG. New onset diabetes mellitus induced by statins: current evidence. Postgrad Med. 2017 May;129(4):430–5. doi: 10.1080/00325481.2017.1292107. PMID: 28276790. Exclusion reason: Ineligible study design28276790
48 Clearfield M, Downs JR, Weis S, . Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS): efficacy and tolerability of long-term treatment with lovastatin in women. Journal of women’s health & gender-based medicine. 2001 Dec;10(10):971–81. doi: 10.1089/152460901317193549. PMID: 11788107. Exclusion reason: Used original study11788107
49 Clearfield M, Whitney EJ, Weis S, . Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS): baseline characteristics and comparison with USA population. Journal of cardiovascular risk. 2000 Apr;7(2):125–33. doi: 10.1177/204748730000700207. PMID: 10879416. Exclusion reason: Used original study10879416
50 Colantonio LD, Richman JS, Carson AP, . Performance of the atherosclerotic cardiovascular disease pooled cohort risk equations by social deprivation status. J Am Heart Assoc. 2017 Mar 17;6(3):17. doi: 10.1161/JAHA.117.005676. PMID: 28314800. Exclusion reason: Ineligible outcome28314800
51 Colivicchi F, Gulizia MM, Franzini L, . Clinical implications of switching lipid lowering treatment from rosuvastatin to other agents in primary care. Adv Ther. 2016 Nov;33(11):2049–58. doi: 10.1007/s12325-016-0412-8. PMID: 27671328. Exclusion reason: Ineligible comparator27671328
52 Collins R, Reith C, Emberson J, . Interpretation of the evidence for the efficacy and safety of statin therapy. Lancet. 2016 Nov 19;388(10059):2532–61. doi: 10.1016/S0140-6736(16)31357-5. PMID: 27616593. Exclusion reason: Ineligible publication type27616593
53 Corrao G, Monzio Compagnoni M, Cantarutti A, . Balancing cardiovascular benefit and diabetogenic harm of therapy with statins: real-world evidence from Italy. Diabetes Res Clin Pract. 2020 May 07;164:108197. doi: 10.1016/j.diabres.2020.108197. PMID: 32389742. Exclusion reason: Ineligible population32389742
54 Coste J, Billionnet C, Rudnichi A, . Statins for primary prevention and rhabdomyolysis: a nationwide cohort study in France. Eur J Prev Cardiolog. 2019 Mar;26(5):512–21. doi: 10.1177/2047487318776831. PMID: 29799296. Exclusion reason: Ineligible outcome29799296
55 Coste J, Karras A, Rudnichi A, . Statins for primary prevention of cardiovascular disease and the risk of acute kidney injury. Pharmacoepidemiol Drug Saf. 2019 Dec;28(12):1583–90. doi: 10.1002/pds.4898. PMID: 31517431. Exclusion reason: Ineligible outcome31517431
56 Crandall JP, Mather K, Rajpathak SN, . Statin use and risk of developing diabetes: results from the Diabetes Prevention Program. BMJ Open Diabetes Res Care. 2017;5(1):e000438. doi: 10.1136/bmjdrc-2017-000438. PMID: 29081977. Exclusion reason: Sample size too small29081977
57 Craveiro NS, Silva Lopes B, Tomas L, . L-TRUST: long-term risk of cancer in patients under statins therapy. A systematic review and meta-analysis. Pharmacoepidemiol Drug Saf. 2019 Nov;28(11):1431–9. doi: 10.1002/pds.4895. PMID: 31509302. Exclusion reason: Source document31509302
58 Crouse JR, 3rd, Grobbee DE, O’Leary DH, . Measuring effects on intima media thickness: an evaluation of rosuvastatin in subclinical atherosclerosis--the rationale and methodology of the METEOR study. Cardiovasc Drugs Ther. 2004 May;18(3):231–8. doi: 10.1023/B:CARD.0000033645.55138.3d. PMID: 15229392. Exclusion reason: Used original study15229392
59 Cui JY, Zhou RR, Han S, . Statin therapy on glycemic control in type 2 diabetic patients: a network meta-analysis. J Clin Pharm Ther. 2018 Aug;43(4):556–70. doi: 10.1111/jcpt.12690. PMID: 29733433. Exclusion reason: Source document29733433
60 Dagenais GR, Jung H, Lonn E, . Effects of lipid-lowering and antihypertensive treatments in addition to healthy lifestyles in primary prevention: an analysis of the HOPE-3 trial. J Am Heart Assoc. 2018 Jul 22;7(15):22. doi: 10.1161/JAHA.118.008918. PMID: 30033433. Exclusion reason: Ineligible outcome30033433
61 Del Ben M, Baratta F, Polimeni L, . Under-prescription of statins in patients with non-alcoholic fatty liver disease. Nutr Metab Cardiovasc Dis. 2017 Feb;27(2):161–7. doi: 10.1016/j.numecd.2016.09.011. PMID: 27914698. Exclusion reason: Ineligible study design27914698
62 DeWitt CM, Ponce RB, Bry H, . Patient-Reported Reasons for Not Using Primary Prevention Statin Therapy. J. 2020 Oct 18;9(10):18. doi: 10.3390/jcm9103337. PMID: 33080939. Exclusion reason: Ineligible study design33080939
63 Dewland TA, Soliman EZ, Davis BR, . Effect of the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT) on conduction system disease. JAMA Intern Med. 2016 Aug 01;176(8):1085–92. doi: 10.1001/jamainternmed.2016.2502. PMID: 27367818. Exclusion reason: Ineligible population27367818
64 Diamond DM, de Lorgeril M, Kendrick M, . Formal comment on “systematic review of the predictors of statin adherence for the primary prevention of cardiovascular disease”. PLoS ONE. 2019 Jan 17;14(1):e0205138. doi: 10.1371/journal.pone.0205138. PMID: 30653537. Exclusion reason: Ineligible publication type30653537
65 Dobrzycka M, Spychalski P, Lachinski AJ, . Statins and colorectal cancer - a systematic review. Exp Clin Endocrinol Diabetes. 2020 Apr;128(4):255–62. doi: 10.1055/a-0668-5692. PMID: 30149418. Exclusion reason: Background30149418
66 Dong S, Guo J, Fang J, . Low-dose statin pretreatment reduces stroke severity and improves functional outcomes. J Neurol. 2019 Dec;266(12):2970–8. doi: 10.1007/s00415-019-09520-9. PMID: 31468121. Exclusion reason: Ineligible outcome31468121
67 Dorsch MP, Lester CA, Ding Y, . Effects of race on statin prescribing for primary prevention with high atherosclerotic cardiovascular disease risk in a large healthcare system. J Am Heart Assoc. 2019 Nov 19;8(22):e014709. doi: 10.1161/JAHA.119.014709. PMID: 31707943. Exclusion reason: Included for contextual question only31707943
68 Downs JR, Beere PA, Whitney E, . Design & rationale of the Air Force/Texas Coronary Atherosclerosis Prevention Study (AFCAPS/TexCAPS). Am J Cardiol. 1997 Aug 1;80(3):287–93. doi: 10.1016/s0002-9149(97)00347-0. PMID: 9264420. Exclusion reason: Used original study9264420
69 Drewes YM, Poortvliet RK, Blom JW, . Homocysteine levels and treatment effect in the PROspective Study of Pravastatin in the Elderly at Risk. J Am Geriatr Soc. 2014 Feb;62(2):213–21. doi: 10.1111/jgs.12660. PMID: 24447238. Exclusion reason: Ineligible population24447238
70 Eilat-Tsanani S, Mor E, Schonmann Y. Statin use over 65 years of age and all-cause mortality: a 10-year follow-up of 19 518 people. J Am Geriatr Soc. 2019 Oct;67(10):2038–44. doi: 10.1111/jgs.16060. PMID: 31287932. Exclusion reason: Background31287932
71 Eng D, Chute C, Khandwala N, . Automated coronary calcium scoring using deep learning with multicenter external validation. npj digit. 2021 Jun 01;4(1):88. doi: 10.1038/s41746-021-00460-1. PMID: 34075194. Exclusion reason: Ineligible outcome34075194
72 Fairman KA, Romanet D, Early NK, . Estimated cardiovascular risk and guideline-concordant primary prevention with statins: retrospective cross-sectional analyses of US ambulatory visits using competing algorithms. J Cardiovasc Pharmacol Ther. 2020 Jan;25(1):27–36. doi: 10.1177/1074248419866153. PMID: 31353942. Exclusion reason: Ineligible outcome31353942
73 Ferreira-Legere LE, Chu A, Rashid M, . Making informed CHOICES: the launch of a “big data” pragmatic trial to improve cholesterol management and prevent heart disease in Ontario. Healthc Q. 2020 Jan;22(4):6–9. doi: 10.12927/hcq.2020.26091. PMID: 32073384. Exclusion reason: Background32073384
74 Finnikin S, Willis BH, Ryan R, . Factors predicting statin prescribing for primary prevention: a historical cohort study. Br J Gen Pract. 2021;71(704):e219–e25. doi: 10.3399/bjgp20X714065. PMID: 33558331. Exclusion reason: Ineligible study design33558331
75 Flach C, Elstad M, Muruet W, . The impact of pre- and post-stroke statin use on stroke severity and long-term outcomes: a population-based cohort study. Cerebrovasc Dis. 2019;47(5–6):260–7. doi: 10.1159/000501543. PMID: 31311007. Exclusion reason: Ineligible study design31311007
76 Flint AC, Conell C, Ren X, . Statin adherence is associated with reduced recurrent stroke risk in patients with or without atrial fibrillation. Stroke. 2017 Jul;48(7):1788–94. doi: 10.1161/STROKEAHA.117.017343. PMID: 28596457. Exclusion reason: Ineligible population28596457
77 Flueckiger P, Qureshi W, Michos ED, . Guideline-based statin/lipid-lowering therapy eligibility for primary prevention and accuracy of coronary artery calcium and clinical cardiovascular events: the Multi-Ethnic Study of Atherosclerosis (MESA). Clin Cardiol. 2017 Mar;40(3):163–9. doi: 10.1002/clc.22642. PMID: 27859433. Exclusion reason: Ineligible outcome27859433
78 Ford I, Murray H, McCowan C, . Long-term safety and efficacy of lowering low-density lipoprotein cholesterol with statin therapy: 20-year follow-up of West of Scotland Coronary Prevention Study. Circulation. 2016 Mar 15;133(11):1073–80. doi: 10.1161/CIRCULATIONAHA.115.019014. PMID: 26864092. Exclusion reason: Ineligible outcome26864092
79 Freeman DJ, Robertson M, Brown EA, . Incident venous thromboembolic events in the Prospective Study of Pravastatin in the Elderly at Risk (PROSPER). BMC Geriatr. 2011 Feb 22;11:8. doi: 10.1186/1471-2318-11-8. PMID: 21342490. Exclusion reason: Ineligible population21342490
80 Gamboa CM, Colantonio LD, Brown TM, . Race-sex differences in statin use and low-density lipoprotein cholesterol control among people with diabetes mellitus in the reasons for geographic and racial differences in stroke study. J Am Heart Assoc. 2017 May 10;6(5):e004264. doi: 10.1161/jaha.116.004264. PMID: 28490523. Exclusion reason: Included for contextual question only28490523
81 Garcia-Gil M, Comas-Cufi M, Blanch J, . Effectiveness of statins as primary prevention in people with different cardiovascular risk: a population-based cohort study. Clin Pharmacol Ther. 2018 Oct;104(4):719–32. doi: 10.1002/cpt.954. PMID: 29194590. Exclusion reason: Ineligible outcome29194590
82 Gili S, Grosso Marra W, D’Ascenzo F, . Comparative safety and efficacy of statins for primary prevention in human immunodeficiency virus-positive patients: a systematic review and meta-analysis. Eur Heart J. 2016 Dec 21;37(48):3600–9. doi: 10.1093/eurheartj/ehv734. PMID: 26851703. Exclusion reason: Ineligible study design26851703
83 Ginter E, Kajaba I. Risk of statin therapy in elderly. Bratisl Lek Listy. 2016;117(10):555–6. doi: 10.4149/bll_2016_108. PMID: 27826969. Exclusion reason: Background27826969
84 Giral P, Neumann A, Weill A, . Cardiovascular effect of discontinuing statins for primary prevention at the age of 75 years: a nationwide population-based cohort study in France. Eur Heart J. 2019 Nov 14;40(43):3516–25. doi: 10.1093/eurheartj/ehz458. PMID: 31362307. Exclusion reason: Background31362307
85 Gitsels LA, Bakbergenuly I, Steel N, . Do statins reduce mortality in older people? Findings from a longitudinal study using primary care records. Fam. 2021 May;9(2)doi: 10.1136/fmch-2020-000780. PMID: 34031184. Exclusion reason: Ineligible study design34031184
86 Gitsels LA, Kulinskaya E, Steel N. Survival benefits of statins for primary prevention: a cohort study. PLoS ONE 2016 Nov 18;11(11):e0166847. doi: 10.1371/journal.pone.0166847. PMID: 27861639. Exclusion reason: Ineligible outcome27861639
87 Greve AM, Bang CN, Boman K, . Relation of lipid-lowering therapy to need for aortic valve replacement in patients with asymptomatic mild to moderate aortic stenosis. Am J Cardiol. 2019 Dec 01;124(11):1736–40. doi: 10.1016/j.amjcard.2019.08.037. PMID: 31586530. Exclusion reason: Ineligible intervention31586530
88 Group A. Rationale and design for the asymptomatic carotid artery plaque study (ACAPS). Control Clin Trials. 1992;13(4):293–314. Exclusion reason: Used original study1330434
89 Grundy SM, Stone NJ, Guideline Writing Committee for the Cholesterol G. 2018 cholesterol clinical practice guidelines: synopsis of the 2018 American Heart Association/American College of Cardiology/Multisociety Cholesterol Guideline. Ann Intern Med. 2019 Jun 04;170(11):779–83. doi: 10.7326/M19-0365. PMID: 31132793. Exclusion reason: Ineligible publication type31132793
90 Gu A, Kamat S, Argulian E. Trends and disparities in statin use and low-density lipoprotein cholesterol levels among US patients with diabetes, 1999-2014. Diabetes Res Clin Pract. 2018 May;139:1–10. doi: 10.1016/j.diabres.2018.02.019. PMID: 29476887. Exclusion reason: Included for contextual question only29476887
91 Guber K, Pemmasani G, Malik A, . Statins and Higher Diabetes Mellitus Risk: Incidence, Proposed Mechanisms, and Clinical Implications. Cardiol Rev. 2021 Nov–Dec 01;29(6):314–22. doi: 10.1097/CRD.0000000000000348. PMID: 32947479. Exclusion reason: Ineligible publication type32947479
92 Guercio V, Turati F, Bosetti C, . Bladder cancer risk in users of selected drugs for cardiovascular disease prevention. Eur J Cancer Prev. 2019 Mar;28(2):76–80. doi: 10.1097/CEJ.0000000000000419. PMID: 29280915. Exclusion reason: Ineligible study design29280915
93 Hale M, Zaman H, Mehdizadeh D, . Association between statins prescribed for primary and secondary prevention and major adverse cardiac events among older adults with frailty: a systematic review. Drugs Aging. 2020 Nov;37(11):787–99. doi: 10.1007/s40266-020-00798-3. PMID: 32929609. Exclusion reason: Ineligible study design32929609
94 Herrera-Gomez F, Chimeno MM, Martin-Garcia D, . Cholesterol-lowering treatment in chronic kidney disease: multistage pairwise and network meta-analyses. Sci Rep. 2019 Jun 20;9(1):8951. doi: 10.1038/s41598-019-45431-5. PMID: 31222137. Exclusion reason: Source document31222137
95 Herrett E, Williamson E, Brack K, . The effect of statins on muscle symptoms in primary care: the StatinWISE series of 200 N-of-1 RCTs. Health Technol Assess. 2021 Mar;25(16):1–62. doi: 10.3310/hta25160. PMID: 33709907. Exclusion reason: Ineligible population33709907
96 Hobbs FD, Banach M, Mikhailidis DP, . Is statin-modified reduction in lipids the most important preventive therapy for cardiovascular disease? A pro/con debate. BMC Med. 2016 Jan 14;14:4. doi: 10.1186/s12916-016-0550-5. PMID: 26769594. Exclusion reason: Ineligible publication type26769594
97 Houx PJ, Shepherd J, Blauw GJ, . Testing cognitive function in elderly populations: the PROSPER study. PROspective Study of Pravastatin in the Elderly at Risk. J Neurol Neurosurg Psychiatry. 2002 Oct;73(4):385–9. doi: 10.1136/jnnp.73.4.385. PMID: 12235304. Exclusion reason: Ineligible population12235304
98 Howard TM, Bavishi AA, Stone NJ. A new HOPE? Lessons from heart outcomes prevention evaluation-3. Am J Med. 2018 Feb;131(2):134–40. doi: 10.1016/j.amjmed.2017.10.012. PMID: 29074093. Exclusion reason: Ineligible publication type29074093
99 Huang CY, Lin TT, Yang YH, . Effect of statin therapy on the prevention of new-onset acute coronary syndrome in patients with rheumatoid arthritis. Int J Cardiol. 2018 Feb 15;253:1–6. doi: 10.1016/j.ijcard.2017.11.009. PMID: 29174015. Exclusion reason: Ineligible study design29174015
100 Huang H, Zeng C, Ma Y, . Effects of long-term statin therapy in coronary artery disease patients with or without chronic kidney disease. Dis Markers. 2015 Oct 8;2015:252564. doi: 10.1155/2015/252564. PMID: 26557729. Exclusion reason: Ineligible population26557729
101 Huesch MD. Association of baseline statin use among older adults without clinical cardiovascular disease in the SPRINT trial. JAMA Intern Med. 2018 Apr 01;178(4):560–1. doi: 10.1001/jamainternmed.2017.7844. PMID: 29356825. Exclusion reason: Ineligible publication type29356825
102 Iribarren C, Lu M, Jorgenson E, . Clinical utility of multimarker genetic risk scores for prediction of incident coronary heart disease: a cohort study among over 51 000 individuals of European ancestry. Circ Cardiovasc Genet. 2016 Dec;9(6):531–40. doi: 10.1161/CIRCGENETICS.116.001522. PMID: 27780846. Exclusion reason: Ineligible study design27780846
103 Iwere RB, Hewitt J. Myopathy in older people receiving statin therapy: a systematic review and meta-analysis. Br J Clin Pharmacol. 2015 Sep;80(3):363–71. doi: 10.1111/bcp.12687. PMID: 26032930. Exclusion reason: Source document26032930
104 Izquierdo-Palomares JM, Fernandez-Tabera JM, Plana MN, . Chronotherapy versus conventional statins therapy for the treatment of hyperlipidaemia. Cochrane Database Syst Rev. 2016 Nov 26;11:CD009462. doi: 10.1002/14651858.CD009462.pub2. PMID: 27888640. Exclusion reason: Ineligible population27888640
105 Jia X, Al Rifai M, Gluckman TJ, . Highlights from selected cardiovascular disease prevention studies presented at the 2019 European Society of Cardiology Congress. Curr Atheroscler Rep. 2019 Nov 19;21(12):46. doi: 10.1007/s11883-019-0813-7. PMID: 31741082. Exclusion reason: Ineligible publication type31741082
106 Joseph P, Glynn R, Lonn E, . Rosuvastatin for the prevention of venous thromboembolism: a pooled analysis of the HOPE-3 and JUPITER randomized controlled trials. Cardiovasc Res. 2021 Mar 10;10:10. doi: 10.1093/cvr/cvab078. PMID: 33705531. Exclusion reason: Background33705531
107 Joseph P, Lonn E, Bosch J, . Long-term effects of statins, blood pressure-lowering, and both on erectile function in persons at intermediate risk for cardiovascular disease: a substudy of the Heart Outcomes Prevention Evaluation-3 (HOPE-3) randomized controlled trial. Can J Cardiol. 2018 Jan;34(1):38–44. doi: 10.1016/j.cjca.2017.09.026. PMID: 29275880. Exclusion reason: Ineligible outcome29275880
108 Jun JE, Cho IJ, Han K, . Statins for primary prevention in adults aged 75 years and older: a nationwide population-based case-control study. Atherosclerosis. 2019 Apr;283:28–34. doi: 10.1016/j.atherosclerosis.2019.01.030. PMID: 30772771. Exclusion reason: Ineligible study design30772771
109 Jung M, Lee S. Effects of statin therapy on the risk of intracerebral hemorrhage in Korean patients with hyperlipidemia. Pharmacotherapy. 2019 Feb;39(2):129–39. doi: 10.1002/phar.2211. PMID: 30585646. Exclusion reason: Ineligible outcome30585646
110 Kaasenbrood L, Poulter NR, Sever PS, . Development and validation of a model to predict absolute vascular risk reduction by moderate-intensity statin therapy in individual patients with type 2 diabetes mellitus: the Anglo Scandinavian Cardiac Outcomes Trial, Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial, and Collaborative Atorvastatin Diabetes Study. Circ Cardiovasc Qual Outcomes. 2016 May;9(3):213–21. doi: 10.1161/CIRCOUTCOMES.115.001980. PMID: 27174798. Exclusion reason: Ineligible study design27174798
111 Kamran H, Kupferstein E, Sharma N, . Statins and new-onset diabetes in cardiovascular and kidney disease cohorts: a meta-analysis. Cardiorenal med. 2018 Apr 8;8(2):105–12. doi: 10.1159/000485196. PMID: 29617000. Exclusion reason: Source document29617000
112 Kang EY, Chen TH, Garg SJ, . Association of statin therapy with prevention of vision-threatening diabetic retinopathy. JAMA Ophthalmol. 2019 Apr 01;137(4):363–71. doi: 10.1001/jamaophthalmol.2018.6399. PMID: 30629109. Exclusion reason: Ineligible outcome30629109
113 Karmali KN, Lee JY, Brown T, . Predictors of cholesterol treatment discussions and statin prescribing for primary cardiovascular disease prevention in community health centers. Prev Med. 2016 Jul;88:176–81. doi: 10.1016/j.ypmed.2016.04.011. PMID: 27090436. Exclusion reason: Included for contextual question only27090436
114 Karmali KN, Lloyd-Jones DM, Berendsen MA, . Drugs for primary prevention of atherosclerotic cardiovascular disease: an overview of systematic reviews. JAMA Cardiol. 2016 Jun 01;1(3):341–9. doi: 10.1001/jamacardio.2016.0218. PMID: 27438118. Exclusion reason: Ineligible study design27438118
115 Kawashiri MA, Sakata K, Hayashi K, . Impact of combined lipid lowering and blood pressure control on coronary plaque: myocardial ischemia treated by percutaneous coronary intervention and plaque regression by lipid lowering and blood pressure controlling assessed by intravascular ultrasonography (MILLION) study. Heart Vessels. 2017 May;32(5):539–48. doi: 10.1007/s00380-016-0910-2. PMID: 27798731. Exclusion reason: Ineligible publication type27798731
116 Kendrick J, Shlipak MG, Targher G, . Effect of lovastatin on primary prevention of cardiovascular events in mild CKD and kidney function loss: a post hoc analysis of the Air Force/Texas Coronary Atherosclerosis Prevention Study. Am J Kidney Dis. 2010 Jan;55(1):42–9. doi: 10.1053/j.ajkd.2009.09.020. PMID: 19932541. Exclusion reason: Used original study19932541
117 Khunti K, Jung H, Dans AL, . Statin use in primary prevention: a simple trial-based approach compared with guideline-recommended risk algorithms for selection of eligible patients. Can J Cardiol. 2019 May;35(5):644–52. doi: 10.1016/j.cjca.2019.03.002. PMID: 31030865. Exclusion reason: Ineligible outcome31030865
118 Kim K, Kwak A, Choi CU, . Differences in preventing new-onset cardiovascular events with statin therapy in seniors aged 75 years and over: a cohort study in the South Korean National Health Insurance Database. Basic Clin Pharmacol Toxicol. 2019 Aug;125(2):108–16. doi: 10.1111/bcpt.13229. PMID: 30924261. Exclusion reason: Ineligible study design30924261
119 Kim K, Lee CJ, Shim CY, . Statin and clinical outcomes of primary prevention in individuals aged >75years: the SCOPE-75 study. Atherosclerosis. 2019 May;284:31–6. doi: 10.1016/j.atherosclerosis.2019.02.026. PMID: 30870705. Exclusion reason: Ineligible study design30870705
120 Kim MY, Jung M, Noh Y, . Impact of statin use on dementia incidence in elderly men and women with ischemic heart disease. Biomedicines. 2020 Feb 09;8(2):09. doi: 10.3390/biomedicines8020030. PMID: 32050497. Exclusion reason: Background32050497
121 Kim S, Choi H, Won CW. Effects of Statin Use for Primary Prevention among Adults Aged 75 Years and Older in the National Health Insurance Service Senior Cohort (2002-2015). Ann. 2020 Jun;24(2):91–8. doi: 10.4235/agmr.20.0028. PMID: 32743329. Exclusion reason: Ineligible study design32743329
122 King W, Lacey A, White J, . Socioeconomic inequality in medication persistence in primary and secondary prevention of coronary heart disease - a population-wide electronic cohort study. PLoS ONE. 2018;13(3):e0194081. doi: 10.1371/journal.pone.0194081. PMID: 29522561. Exclusion reason: Ineligible outcome29522561
123 Kohli-Lynch CN, Bellows BK, Thanassoulis G, . Cost-effectiveness of low-density lipoprotein cholesterol level-guided statin treatment in patients with borderline cardiovascular risk. JAMA Cardiol. 2019 Aug 28;28:28. doi: 10.1001/jamacardio.2019.2851. PMID: 31461121. Exclusion reason: Included for contextual question only31461121
124 Korhonen MJ, Ruokoniemi P, Ilomaki J, . Adherence to statin therapy and the incidence of ischemic stroke in patients with diabetes. Pharmacoepidemiol Drug Saf. 2016 Feb;25(2):161–9. doi: 10.1002/pds.3936. PMID: 26687512. Exclusion reason: Ineligible study design26687512
125 Kostis JB, Giakoumis M, Zinonos S, . Meta-Analysis of Usefulness of Treatment of Hypercholesterolemia With Statins for Primary Prevention in Patients Older Than 75 Years. Am J Cardiol. 2020 04 15;125(8):1154–7. doi: 10.1016/j.amjcard.2020.01.020. PMID: 32088001. Exclusion reason: Ineligible population32088001
126 Kristensen ML, Christensen PM, Hallas J. The effect of statins on average survival in randomised trials, an analysis of end point postponement. BMJ Open. 2015 Sep 24;5(9):e007118. doi: 10.1136/bmjopen-2014-007118. PMID: 26408281. Exclusion reason: Source document26408281
127 Kuiper JG, Sanchez RJ, Houben E, . Use of lipid-modifying therapy and LDL-C goal attainment in a high-cardiovascular-risk population in the Netherlands. Clin Ther. 2017 Apr;39(4):819–27.e1. doi: 10.1016/j.clinthera.2017.03.001. PMID: 28347514. Exclusion reason: Ineligible population28347514
128 Kulenovic I, Mortensen MB, Bertelsen J, . Statin use prior to first myocardial infarction in contemporary patients: inefficient and not gender equitable. Prev Med. 2016 Feb;83:63–9. doi: 10.1016/j.ypmed.2015.12.001. PMID: 26687101. Exclusion reason: Ineligible outcome26687101
129 Kullo IJ, Jouni H, Austin EE, . Incorporating a genetic risk score into coronary heart disease risk estimates: effect on low-density lipoprotein cholesterol levels (the MI-GENES clinical trial). Circulation. 2016 Mar 22;133(12):1181–8. doi: 10.1161/CIRCULATIONAHA.115.020109. PMID: 26915630. Exclusion reason: Ineligible outcome26915630
130 Kunutsor SK, Seidu S, Khunti K. Statins and primary prevention of venous thromboembolism: a systematic review and meta-analysis. Lancet Haematol. 2017 Feb;4(2):e83–e93. doi: 10.1016/S2352-3026(16)30184-3. PMID: 28089655. Exclusion reason: Source document28089655
131 Ladapo JA, Pfeifer JM, Pitcavage JM, . Quantifying sex differences in cardiovascular care among patients evaluated for suspected ischemic heart disease. J Womens Health (Larchmt). 2019 May;28(5):698–704. doi: 10.1089/jwh.2018.7018. PMID: 30543478. Exclusion reason: Ineligible outcome30543478
132 Lafeber M, Webster R, Visseren F, . Estimated cardiovascular relative risk reduction from fixed-dose combination pill (polypill) treatment in a wide range of patients with a moderate risk of cardiovascular disease. Eur J Prev Cardiolog. 2016 Aug;23(12):1289–97. doi: 10.1177/2047487315624523. PMID: 26743587. Exclusion reason: Ineligible intervention26743587
133 Lamy A, Lonn E, Tong W, . The cost implication of primary prevention in the HOPE 3 trial. Eur Heart J Qual Care Clin Outcomes. 2019 Jul 01;5(3):266–71. doi: 10.1093/ehjqcco/qcz001. PMID: 30657891. Exclusion reason: Ineligible outcome30657891
134 Lavie G, Hoshen M, Leibowitz M, . Statin Therapy for Primary Prevention in the Elderly and Its Association with New-Onset Diabetes, Cardiovascular Events, and All-Cause Mortality. Am J Med. 2021 May;134(5):643–52. doi: 10.1016/j.amjmed.2020.09.058. PMID: 33217370. Exclusion reason: Ineligible comparator33217370
135 Lavikainen P, Helin-Salmivaara A, Eerola M, . Statin adherence and risk of acute cardiovascular events among women: a cohort study accounting for time-dependent confounding affected by previous adherence. BMJ Open. 2016 Jun 03;6(6):e011306. doi: 10.1136/bmjopen-2016-011306. PMID: 27259530. Exclusion reason: Ineligible outcome27259530
136 Lawler PR, Akinkuolie AO, Harada P, . Residual risk of atherosclerotic cardiovascular events in relation to reductions in very-low-density lipoproteins. J Am Heart Assoc. 2017 Dec 09;6(12):09. doi: 10.1161/JAHA.117.007402. PMID: 29223956. Exclusion reason: Ineligible population29223956
137 Lee DH, Youn HJ, Jung HO, . Coronary artery calcium score plays an important role for cardiovascular risk stratification in the statin benefit groups of asymptomatic individuals. Lipids health dis. 2017 Sep 12;16(1):172. doi: 10.1186/s12944-017-0560-0. PMID: 28899385. Exclusion reason: Ineligible outcome28899385
138 Li H, Wang C, Zhang S, . Safety profile of atorvastatin 80 mg: a meta-analysis of 17 randomized controlled trials in 21,910 participants. Drug Saf. 2016 May;39(5):409–19. doi: 10.1007/s40264-016-0394-0. PMID: 26860922. Exclusion reason: Ineligible study design26860922
139 Li M, Wang X, Li X, . Statins for the primary prevention of coronary heart disease. Biomed Res Int. 2019 Jan 29;2019:4870350. doi: 10.1155/2019/4870350. PMID: 30834266. Exclusion reason: Source document30834266
140 Li YR, Tsai SS, Lin YS, . Moderate- to high-intensity statins for secondary prevention in patients with type 2 diabetes mellitus on dialysis after acute myocardial infarction. Diabetol Metab Syndr. 2017;9:71. doi: 10.1186/s13098-017-0272-7. PMID: 28932290. Exclusion reason: Ineligible population28932290
141 Lin JS, Evans CV, Johnson E, . Nontraditional risk factors in cardiovascular disease risk assessment: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Jul 17;320(3):281–97. doi: 10.1001/jama.2018.4242. PMID: 29998301. Exclusion reason: Included for contextual question only29998301
142 Lindbohm JV, Sipila PN, Mars NJ, . 5-year versus risk-category-specific screening intervals for cardiovascular disease prevention: a cohort study. Lancet Public Health. 2019 Apr;4(4):e189–e99. doi: 10.1016/S2468-2667(19)30023-4. PMID: 30954144. Exclusion reason: Background30954144
143 Liu CH, Chen TH, Lin MS, . Ezetimibe-simvastatin therapy reduce recurrent ischemic stroke risks in type 2 diabetic patients. J Clin Endocrinol Metab. 2016 Aug;101(8):2994–3001. doi: 10.1210/jc.2016-1831. PMID: 27270238. Exclusion reason: Ineligible population27270238
144 Lloyd SM, Stott DJ, de Craen AJ, . Long-term effects of statin treatment in elderly people: extended follow-up of the PROspective Study of Pravastatin in the Elderly at Risk (PROSPER). PLoS ONE. 2013 Sep 2;8(9):e72642. doi: 10.1371/journal.pone.0072642. PMID: 24023757. Exclusion reason: Ineligible population24023757
145 Lloyd-Jones DM, Braun LT, Ndumele CE, . Use of risk assessment tools to guide decision-making in the primary prevention of atherosclerotic cardiovascular disease: a special report from the American Heart Association and American College of Cardiology. J Am Coll Cardiol. 2019 Jun 25;73(24):3153–67. doi: 10.1016/j.jacc.2018.11.005. PMID: 30423392. Exclusion reason: Ineligible publication type30423392
146 Lowe RN, Vande Griend JP, Saseen JJ. Statins for the primary prevention of cardiovascular disease in the elderly. Consult Pharm. 2015 Jan;30(1):20–30. doi: 10.4140/TCP.n.2015.20. PMID: 25591028. Exclusion reason: Source document25591028
147 Mach F, Ray KK, Wiklund O, . Adverse effects of statin therapy: perception vs. the evidence - focus on glucose homeostasis, cognitive, renal and hepatic function, haemorrhagic stroke and cataract. Eur Heart J. 2018 Jul 14;39(27):2526–39. doi: 10.1093/eurheartj/ehy182. PMID: 29718253. Exclusion reason: Source document29718253
148 Maggioni AP, Calabria S, Rossi E, . Use of lipid lowering drugs in patients at very high risk of cardiovascular events: an analysis on nearly 3,000,000 Italian subjects of the ARNO Observatory. Int J Cardiol. 2017 Nov 01;246:62–7. doi: 10.1016/j.ijcard.2017.02.108. PMID: 28298250. Exclusion reason: Ineligible population28298250
149 Magnoni M, Berteotti M, Norata GD, . Applicability of the 2013 ACC/AHA Risk Assessment and Cholesterol Treatment Guidelines in the real world: results from a multiethnic case-control study. Ann Med. 2016;48(4):282–92. doi: 10.3109/07853890.2016.1168934. PMID: 27052543. Exclusion reason: Ineligible intervention27052543
150 Mahabadi AA, Mohlenkamp S, Lehmann N, . CAC score improves coronary and CV risk assessment above statin indication by ESC and AHA/ACC primary prevention guidelines. JACC Cardiovasc Imaging. 2017 Feb;10(2):143–53. doi: 10.1016/j.jcmg.2016.03.022. PMID: 27665163. Exclusion reason: Ineligible outcome27665163
151 Mansi I, Frei CR, Wang CP, . Statins and new-onset diabetes mellitus and diabetic complications: a retrospective cohort study of US healthy adults. J Gen Intern Med. 2015 Nov;30(11):1599–610. doi: 10.1007/s11606-015-3335-1. PMID: 25917657. Exclusion reason: Sample size too small25917657
152 Mansi IA, English J, Zhang S, . Long-term outcomes of short-term statin use in healthy adults: a retrospective cohort study. Drug Saf. 2016 Jun;39(6):543–59. doi: 10.1007/s40264-016-0412-2. PMID: 26979831. Exclusion reason: Ineligible study design26979831
153 Martin-Ruiz E, Olry-de-Labry-Lima A, Ocana-Riola R, . Systematic review of the effect of adherence to statin treatment on critical cardiovascular events and mortality in primary prevention. J Cardiovasc Pharmacol Ther. 2018 May;23(3):200–15. doi: 10.1177/1074248417745357. PMID: 29343082. Exclusion reason: Ineligible outcome29343082
154 McGuinness B, Craig D, Bullock R, . Statins for the prevention of dementia. Cochrane Database Syst Rev. 2016 Jan 04(1):CD003160. doi: 10.1002/14651858.CD003160.pub3. PMID: 26727124. Exclusion reason: Ineligible outcome26727124
155 Miedema MD, Dardari ZA, Kianoush S, . Statin eligibility, coronary artery calcium, and subsequent cardiovascular events according to the 2016 United States Preventive Services Task Force (USPSTF) Statin Guidelines: MESA (Multi-Ethnic Study of Atherosclerosis). J Am Heart Assoc. 2018 Jun 13;7(12):13. doi: 10.1161/JAHA.118.008920. PMID: 29899017. Exclusion reason: Included for contextual question only29899017
156 Miksza JK, Zaccardi F, Kunutsor SK, . Statins and risk of thromboembolism: a meta-regression to disentangle the efficacy-to-effectiveness gap using observational and trial evidence. Nutr Metab Cardiovasc Dis. 2019 Oct;29(10):1023–9. doi: 10.1016/j.numecd.2019.06.022. PMID: 31383500. Exclusion reason: Source document31383500
157 Milionis H, Ntaios G, Korompoki E, . Statin-based therapy for primary and secondary prevention of ischemic stroke: a meta-analysis and critical overview. Int J Stroke. 2019 Sep 07;15(4):377–84. doi: 10.1177/1747493019873594. PMID: 31496436. Exclusion reason: Source document31496436
158 Mitchell JD, Fergestrom N, Gage BF, . Impact of statins on cardiovascular outcomes following coronary artery calcium scoring. J Am Coll Cardiol. 2018 Dec 25;72(25):3233–42. doi: 10.1016/j.jacc.2018.09.051. PMID: 30409567. Exclusion reason: Included for contextual question only30409567
159 Mohammad S, Nguyen H, Nguyen M, . Pleiotropic effects of statins: untapped potential for statin pharmacotherapy. Curr Vasc Pharmacol. 2019;17(3):239–61. doi: 10.2174/1570161116666180723120608. PMID: 30033872. Exclusion reason: Source document30033872
160 Mortensen MB, Fuster V, Muntendam P, . A simple disease-guided approach to personalize ACC/AHA-recommended statin allocation in elderly people: the BioImage Study. J Am Coll Cardiol. 2016 Aug 30;68(9):881–91. doi: 10.1016/j.jacc.2016.05.084. PMID: 27561760. Exclusion reason: Ineligible outcome27561760
161 Mortensen MB, Nordestgaard BG. Statin use in primary prevention of atherosclerotic cardiovascular disease according to 5 major guidelines for sensitivity, specificity, and number needed to treat. JAMA Cardiol. 2019 Oct 02;02:02. doi: 10.1001/jamacardio.2019.3665. PMID: 31577339. Exclusion reason: Included for contextual question only31577339
162 Mortensen MB, Nordestgaard BG, Afzal S, . ACC/AHA guidelines superior to ESC/EAS guidelines for primary prevention with statins in non-diabetic Europeans: the Copenhagen General Population Study. Eur Heart J. 2017 Feb 21;38(8):586–94. doi: 10.1093/eurheartj/ehw426. PMID: 28363217. Exclusion reason: Ineligible outcome28363217
163 Morville T, Dohlmann TL, Kuhlman AB, . Aerobic exercise performance and muscle strength in statin users-the LIFESTAT Study. Med Sci Sports Exerc. 2019 Jul;51(7):1429–37. doi: 10.1249/MSS.0000000000001920. PMID: 31210648. Exclusion reason: Ineligible study design31210648
164 Nayak A, Hayen A, Zhu L, . Legacy effects of statins on cardiovascular and all-cause mortality: a meta-analysis. BMJ Open. 2018 Oct 04;8(9):e020584. doi: 10.1136/bmjopen-2017-020584. PMID: 30287603. Exclusion reason: Source document30287603
165 Ngo-Metzger Q, Zuvekas S, Shafer P, . Statin use in the U.S. for secondary prevention of cardiovascular disease remains suboptimal. Journal of the American Board of Family Medicine : JABFM. 2019 Nov–Dec;32(6):807–17. doi: 10.3122/jabfm.2019.06.180313. PMID: 31704749. Exclusion reason: Ineligible population31704749
166 Nunes JP. Statins in primary prevention: impact on mortality. A meta-analysis study. Minerva Cardioangiol. 2017 Oct;65(5):531–8. doi: 10.23736/S0026-4725.17.04323-7. PMID: 28249380. Exclusion reason: Source document28249380
167 O’Neill D, Stone NJ, Forman DE. Primary prevention statins in older adults: personalized care for a heterogeneous population. J Am Geriatr Soc. 2020 Mar;68(3):467–73. doi: 10.1111/jgs.16330. PMID: 31967323. Exclusion reason: Background31967323
168 Offer A, Arnold M, Clarke R, . Assessment of vascular event prevention and cognitive function among older adults with preexisting vascular disease or diabetes: a secondary analysis of 3 randomized clinical trials. JAMA Netw Open. 2019 Mar 01;2(3):e190223. doi: 10.1001/jamanetworkopen.2019.0223. PMID: 30821829. Exclusion reason: Ineligible outcome30821829
169 Olotu BS, Shepherd MD, Novak S, . Use of statins and the risk of incident diabetes: a retrospective cohort study. Am J Cardiovasc Drugs. 2016 Oct;16(5):377–90. doi: 10.1007/s40256-016-0176-1. PMID: 27272032. Exclusion reason: Ineligible population27272032
170 Orkaby AR, Driver JA, Ho YL, . Association of Statin Use With All-Cause and Cardiovascular Mortality in US Veterans 75 Years and Older. JAMA. 2020 07 07;324(1):68–78. doi: 10.1001/jama.2020.7848. PMID: 32633800. Exclusion reason: Ineligible study design32633800
171 Orkaby AR, Gaziano JM, Djousse L, . Statins for primary prevention of cardiovascular events and mortality in older men. J Am Geriatr Soc. 2017 Nov;65(11):2362–8. doi: 10.1111/jgs.14993. PMID: 28892121. Exclusion reason: Ineligible study design28892121
172 Pandit AK, Kumar P, Kumar A, . High-dose statin therapy and risk of intracerebral hemorrhage: a meta-analysis. Acta Neurol Scand. 2016 Jul;134(1):22–8. doi: 10.1111/ane.12540. PMID: 26647879. Exclusion reason: Source document26647879
173 Perera R, McFadden E, McLellan J, . Optimal strategies for monitoring lipid levels in patients at risk or with cardiovascular disease: a systematic review with statistical and cost-effectiveness modelling. Health Technol Assess. 2015 Dec;19(100):1–401, vii–viii. doi: 10.3310/hta191000. PMID: 26680162. Exclusion reason: Ineligible outcome26680162
174 Perez de Isla L, Arroyo-Olivares R, Muniz-Grijalvo O, . Long-term effect of 2 intensive statin regimens on treatment and incidence of cardiovascular events in familial hypercholesterolemia: the SAFEHEART study. J. 2019 Nov – Dec;13(6):989–96. doi: 10.1016/j.jacl.2019.10.005. PMID: 31706904. Exclusion reason: Background31706904
175 Pletcher MJ, Pignone M, Jarmul JA, . Population impact & efficiency of benefit-targeted versus risk-targeted statin prescribing for primary prevention of cardiovascular disease. J Am Heart Assoc. 2017 Feb 10;6(2):10. doi: 10.1161/JAHA.116.004316. PMID: 28188251. Exclusion reason: Included for contextual question only28188251
176 Ponce OJ, Larrea-Mantilla L, Hemmingsen B, . Lipid-lowering agents in older individuals: a systematic review and meta-analysis of randomized clinical trials. J Clin Endocrinol Metab. 2019 May 01;104(5):1585–94. doi: 10.1210/jc.2019-00195. PMID: 30903687. Exclusion reason: Source document30903687
177 Poortvliet RK, Ford I, Lloyd SM, . Blood pressure variability and cardiovascular risk in the PROspective Study of Pravastatin in the Elderly at Risk (PROSPER). PLoS ONE. 2012 Dec 20;7(12):e52438. doi: 10.1371/journal.pone.0052438. PMID: 23285043. Exclusion reason: Ineligible population23285043
178 Qato DM, Lee TA, Durazo-Arvizu R, . Statin and aspirin use among hispanic and Latino adults at high cardiovascular risk: findings from the Hispanic community health study/study of Latinos. J Am Heart Assoc. 2016 Mar 30;5(4):e002905. doi: 10.1161/JAHA.115.002905. PMID: 27030340. Exclusion reason: Background27030340
179 Qato DM, Lindau ST, Conti RM, . Racial and ethnic disparities in cardiovascular medication use among older adults in the United States. Pharmacoepidemiol Drug Saf. 2010 Aug;19(8):834–42. doi: 10.1002/pds.1974. PMID: 20681002. Exclusion reason: Ineligible population20681002
180 Qureshi WT, Michos ED, Flueckiger P, . Impact of replacing the pooled cohort equation with other cardiovascular disease risk scores on atherosclerotic cardiovascular disease risk assessment (from the Multi-Ethnic Study of Atherosclerosis [MESA]). Am J Cardiol. 2016 Sep 01;118(5):691–6. doi: 10.1016/j.amjcard.2016.06.015. PMID: 27445216. Exclusion reason: Ineligible comparator27445216
181 Ramos R, Comas-Cufi M, Marti-Lluch R, . Statins for primary prevention of cardiovascular events and mortality in old and very old adults with and without type 2 diabetes: retrospective cohort study. Bmj. 2018 Sep 05;362:k3359. doi: 10.1136/bmj.k3359. PMID: 30185425. Exclusion reason: Ineligible study design30185425
182 Ramos R, Garcia-Gil M, Comas-Cufi M, . Statins for prevention of cardiovascular events in a low-risk population with low ankle brachial index. J Am Coll Cardiol. 2016 Feb 16;67(6):630–40. doi: 10.1016/j.jacc.2015.11.052. PMID: 26868687. Exclusion reason: Ineligible outcome26868687
183 Rana JS, Tabada GH, Solomon MD, . Accuracy of the atherosclerotic cardiovascular risk equation in a large contemporary, multiethnic population. J Am Coll Cardiol. 2016 May 10;67(18):2118–30. doi: 10.1016/j.jacc.2016.02.055. PMID: 27151343. Exclusion reason: Ineligible outcome27151343
184 Riaz H, Khan AR, Khan MS, . Meta-analysis of placebo-controlled randomized controlled trials on the prevalence of statin intolerance. Am J Cardiol. 2017 Sep 01;120(5):774–81. doi: 10.1016/j.amjcard.2017.05.046. PMID: 28779871. Exclusion reason: Source document28779871
185 Ridker PM, Mora S, Rose L, . Percent reduction in LDL cholesterol following high-intensity statin therapy: potential implications for guidelines and for the prescription of emerging lipid-lowering agents. Eur Heart J. 2016 May 01;37(17):1373–9. doi: 10.1093/eurheartj/ehw046. PMID: 26916794. Exclusion reason: Ineligible population26916794
186 Roe MT, Li QH, Bhatt DL, . Risk categorization using New American College of Cardiology/American Heart Association guidelines for cholesterol management and its relation to alirocumab treatment following acute coronary syndromes. Circulation. 2019 Nov 05;140(19):1578–89. doi: 10.1161/CIRCULATIONAHA.119.042551. PMID: 31475572. Exclusion reason: Ineligible population31475572
187 Rosenblit PD. Lowering targeted atherogenic lipoprotein cholesterol goals for patients at “extreme” ASCVD risk. Curr Diab Rep. 2019 Nov 21;19(12):146. doi: 10.1007/s11892-019-1246-y. PMID: 31754844. Exclusion reason: Background31754844
188 Roshandel G, Khoshnia M, Poustchi H, . Effectiveness of polypill for primary and secondary prevention of cardiovascular diseases (PolyIran): a pragmatic, cluster-randomised trial. Lancet. 2019 Aug 24;394(10199):672–83. doi: 10.1016/S0140-6736(19)31791-X. PMID: 31448738. Exclusion reason: Ineligible intervention31448738
189 Safford M, Eaton L, Hawley G, . Disparities in use of lipid-lowering medications among people with type 2 diabetes mellitus. Arch Intern Med. 2003 Apr 28;163(8):922–8. doi: 10.1001/archinte.163.8.922. PMID: 12719201. Exclusion reason: Ineligible study design12719201
190 Sandwith L, Forget P. Statins in Healthy Adults: A Meta-Analysis. Medicina (Kaunas). 2021 Jun 07;57(6):07. doi: 10.3390/medicina57060585. PMID: 34200448. Exclusion reason: Source document34200448
191 Sarasua SM, Li J, Hernandez GT, . Opportunities for improving cardiovascular health outcomes in adults younger than 65 years with guideline-recommended statin therapy. J Clin Hypertens (Greenwich). 2017 Sep;19(9):850–60. doi: 10.1111/jch.13004. PMID: 28480530. Exclusion reason: Ineligible outcome28480530
192 Sarkar S, Orimoloye OA, Nass CM, . Cardiovascular risk heterogeneity in adults with diabetes: selective use of coronary artery calcium in statin use decision-making. J Gen Intern Med. 2019 Nov;34(11):2643–7. doi: 10.1007/s11606-019-05266-2. PMID: 31414361. Exclusion reason: Ineligible study design31414361
193 Sasso FC, Lascar N, Ascione A, . Moderate-intensity statin therapy seems ineffective in primary cardiovascular prevention in patients with type 2 diabetes complicated by nephropathy. A multicenter prospective 8 years follow up study. Cardiovasc. 2016 Oct 13;15(1):147. doi: 10.1186/s12933-016-0463-9. PMID: 27733159. Exclusion reason: Ineligible study design27733159
194 Schroff P, Gamboa CM, Durant RW, . Vulnerabilities to health disparities and statin use in the REGARDS (Reasons for Geographic and Racial Differences in Stroke) study. J Am Heart Assoc. 2017 Aug 28;6(9):e005449. doi: 10.1161/jaha.116.005449. PMID: 28847913. Exclusion reason: Included for contextual question only28847913
195 Schwartz GG, Fayyad R, Szarek M, . Early, intensive statin treatment reduces ‘hard’ cardiovascular outcomes after acute coronary syndrome. Eur J Prev Cardiol. 2017 Aug;24(12):1294–6. doi: 10.1177/2047487317708677. PMID: 28504565. Exclusion reason: Ineligible population28504565
196 Sebastian GB, Anoop TM, Thomas JK, . Comparison of efficacy and adverse effect profile of high dose versus standard dose atorvastatin in acute ST elevation myocardial infarction patients. Heart Asia. 2011 Jan 1;3(1):82–6. doi: 10.1136/ha.2010.003632. PMID: 27326000. Exclusion reason: Ineligible population27326000
197 Segars LW, Lea AR. Assessing prescriptions for statins in ambulatory diabetic patients in the United States: a national, cross-sectional study. Clin Ther. 2008 Nov;30(11):2159–66. doi: 10.1016/j.clinthera.2008.11.004. PMID: 19108804. Exclusion reason: Ineligible study design19108804
198 Shah RV, Spahillari A, Mwasongwe S, . Subclinical atherosclerosis, statin eligibility, and outcomes in African American individuals: the Jackson Heart study. JAMA Cardiol. 2017 Jun 01;2(6):644–52. doi: 10.1001/jamacardio.2017.0944. PMID: 28315622. Exclusion reason: Included for contextual question only28315622
199 Sharma S, Verma H, Jain M. Study of adverse drug reaction of low dose atorvastatin in patients with metabolic syndrome and comparison with the usual care group. Biomed Pharmacol J. 2017;10(1):165–72. doi: 10.13005/bpj/1094. Exclusion reason: Ineligible study design
200 Shum K, Solivan A, Parto P, . Cardiovascular risk and level of statin use among women with breast cancer in a cardio-oncology clinic. Ochsner J. 2016 Fall;16(3):217–24. PMID: 27660568. Exclusion reason: Ineligible population27660568
201 Silverman MG, Ference BA, Im K, . Association between lowering LDL-C and cardiovascular risk reduction among different therapeutic interventions: a systematic review and meta-analysis. JAMA. 2016 Sep 27;316(12):1289–97. doi: 10.1001/jama.2016.13985. PMID: 27673306. Exclusion reason: Background27673306
202 Singh S, Zieman S, Go AS, . Statins for primary prevention in older adults-moving toward evidence-based decision-making. J Am Geriatr Soc. 2018 Nov;66(11):2188–96. doi: 10.1111/jgs.15449. PMID: 30277567. Exclusion reason: Ineligible publication type30277567
203 Sirois C, Moisan J, Poirier P, . Comparative effectiveness of cardioprotective drugs in elderly individuals with type 2 diabetes. Int J Clin Pract. 2015 Mar;69(3):305–12. doi: 10.1111/ijcp.12503. PMID: 25359240. Exclusion reason: Ineligible comparator25359240
204 Sjolander M, Eriksson M, Glader EL. Inequalities in medication adherence to statin treatment after stroke: a nationwide observational study. Eur Stroke J. 2016 Jun;1(2):101–7. doi: 10.1177/2396987316646026. PMID: 31008271. Exclusion reason: Ineligible population31008271
205 Skajaa N, Szepligeti SK, Horvath-Puho E, . Initiation of statins and risk of venous thromboembolism: population-based matched cohort study. Thromb Res. 2019 Dec;184:99–104. doi: 10.1016/j.thromres.2019.11.003. PMID: 31715545. Exclusion reason: Ineligible study design31715545
206 Smolina K, Ball L, Humphries KH, . Sex disparities in post-acute myocardial infarction pharmacologic treatment initiation and adherence: problem for young women. Circ Cardiovasc Qual Outcomes. 2015 Nov;8(6):586–92. doi: 10.1161/CIRCOUTCOMES.115.001987. PMID: 26462876. Exclusion reason: Ineligible population26462876
207 Solanki JD, Makwana AH, Mehta HB, . Is the peripheral arterial disease in low risk type 2 diabetic patients influenced by body mass index, lipidemic control, and statins? J Pharmacol Pharmacother. 2016 Apr–Jun;7(2):87–92. doi: 10.4103/0976-500X.184772. PMID: 27440953. Exclusion reason: Ineligible population27440953
208 Sparrow RT, Khan AM, Ferreira-Legere LE, . Effectiveness of interventions aimed at increasing statin-prescribing rates in primary cardiovascular disease prevention: a systematic review of randomized clinical trials. JAMA Cardiol. 2019 Aug 28;28:28. doi: 10.1001/jamacardio.2019.3066. PMID: 31461127. Exclusion reason: Background31461127
209 Stam-Slob MC, Visseren FL, Wouter Jukema J, . Personalized absolute benefit of statin treatment for primary or secondary prevention of vascular disease in individual elderly patients. Clin. 2017 Jan;106(1):58–68. doi: 10.1007/s00392-016-1023-8. PMID: 27554244. Exclusion reason: Ineligible study design27554244
210 Strandberg TE. Role of statin therapy in primary prevention of cardiovascular disease in elderly patients. Curr Atheroscler Rep. 2019;21(8):28. doi: 10.1007/s11883-019-0793-7. PMID: 31111235. Exclusion reason: Background31111235
211 Suero-Abreu GA, Karatasakis A, Rashid S, . Factors associated with disparities in appropriate statin therapy in an outpatient inner city population. Healthcare (Basel, Switzerland). 2020 Sep 24;8(4):361. doi: 10.3390/healthcare8040361. PMID: 32987753. Exclusion reason: Included for contextual question only32987753
212 Sundstrom J, Gulliksson G, Wiren M. Synergistic effects of blood pressure-lowering drugs and statins: systematic review and meta-analysis. BMJ Evid Based Med. 2018 Apr;23(2):64–9. doi: 10.1136/bmjebm-2017-110888. PMID: 29595132. Exclusion reason: Source document29595132
213 Swiger KJ, Martin SS, Tang F, . Cognitive and physical function by statin exposure in elderly individuals following acute myocardial infarction. Clin Cardiol. 2015 Aug;38(8):455–61. doi: 10.1002/clc.22423. PMID: 26212493. Exclusion reason: Ineligible population26212493
214 Taron J, Lyass A, Mahoney TF, . Coronary artery calcium score-directed primary prevention with statins on the basis of the 2018 American College of Cardiology/American Heart Association/Multisociety Cholesterol Guidelines. J Am Heart Assoc. 2021 Jan 5;10(1):e018342. doi: 10.1161/jaha.120.018342. PMID: 33348999. Exclusion reason: Ineligible outcome33348999
215 Tascilar K, Dell’Aniello S, Hudson M, . Statins and risk of rheumatoid arthritis: a nested case-control study. Arthritis rheumatol. 2016 Nov;68(11):2603–11. doi: 10.1002/art.39774. PMID: 27273914. Exclusion reason: Ineligible population27273914
216 Taylor F, Huffman MD, Macedo FA, . Statins for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2017(5) PMID: 21249663. Exclusion reason: Ineligible study design21249663
217 Thanassoulis G, Williams K, Altobelli KK, . Individualized statin benefit for determining statin eligibility in the primary prevention of cardiovascular disease. Circulation. 2016 Apr 19;133(16):1574–81. doi: 10.1161/CIRCULATIONAHA.115.018383. PMID: 26945047. Exclusion reason: Included for contextual question only26945047
218 Thomopoulos C, Skalis G, Michalopoulou H, . Effect of low-density lipoprotein cholesterol lowering by ezetimibe/simvastatin on outcome incidence: overview, meta-analyses, and meta-regression analyses of randomized trials. Clin Cardiol. 2015 Dec;38(12):763–9. doi: 10.1002/clc.22441. PMID: 26282344. Exclusion reason: Ineligible intervention26282344
219 Thongtang N, Piyapromdee J, Tangkittikasem N, . Efficacy and safety of switching from low-dose statin to high-intensity statin for primary prevention in type 2 diabetes: a randomized controlled trial. Diabetes Metab Syndr Obes. 2020;13:423–31. doi: 10.2147/DMSO.S219496. PMID: 32110075. Exclusion reason: Inadequate duration32110075
220 Ueshima K, Itoh H, Kanazawa N, . Rationale and design of the standard versus intensive statin therapy for hypercholesterolemic patients with diabetic retinopathy (EMPATHY) study: a randomized controlled trial. J Atheroscler Thromb. 2016 Aug 01;23(8):976–90. doi: 10.5551/jat.33563. PMID: 26961114. Exclusion reason: Ineligible outcome26961114
221 Upmeier E, Vire J, Korhonen MJ, . Cardiovascular risk profile and use of statins at the age of 70 years: a comparison of two Finnish birth cohorts born 20 years apart. Age Ageing. 2016 Jan;45(1):84–90. doi: 10.1093/ageing/afv187. PMID: 26764397. Exclusion reason: Ineligible study design26764397
222 van der Ploeg MA, Poortvliet RK, van Blijswijk SC, . Statin use and self-reported hindering muscle complaints in older persons: a population based study. PLoS ONE 2016 Dec 2;11(12):e0166857. doi: 10.1371/journal.pone.0166857. PMID: 27911918. Exclusion reason: Ineligible population27911918
223 Vivanco-Hidalgo RM, Elosua R, Gomez Gonzalez A, . People with epilepsy receive more statins than the general population but have no higher cardiovascular risk: results from a cross-sectional study. Eur J Neurol. 2017 Feb;24(2):419–26. doi: 10.1111/ene.13222. PMID: 28000339. Exclusion reason: Ineligible study design28000339
224 Waheed S, Pollack S, Roth M, . Collective impact of conventional cardiovascular risk factors and coronary calcium score on clinical outcomes with or without statin therapy: The St Francis Heart Study. Atherosclerosis. 2016 Dec;255:193–9. doi: 10.1016/j.atherosclerosis.2016.09.060. PMID: 27693004. Exclusion reason: Ineligible outcome27693004
225 Wang N, Fulcher J, Abeysuriya N, . Intensive LDL cholesterol-lowering treatment beyond current recommendations for the prevention of major vascular events: a systematic review and meta-analysis of randomised trials including 327 037 participants. Lancet Diabetes Endocrinol. 2020 Jan;8(1):36–49. doi: 10.1016/S2213-8587(19)30388-2. PMID: 31862150. Exclusion reason: Source document31862150
226 Warren JB, Dimmitt SB, Stampfer HG. Cholesterol trials and mortality. Br J Clin Pharmacol. 2016 Jul;82(1):168–77. doi: 10.1111/bcp.12945. PMID: 27043432. Exclusion reason: Ineligible publication type27043432
227 Watson KE, Fonarow GC. Closing the remaining evidence gap: randomized controlled trial data to support statin therapy for low-density lipoprotein >=190 mg/dL. Circulation. 2017 Nov 14;136(20):1892–4. doi: 10.1161/CIRCULATIONAHA.117.030989. PMID: 29133529. Exclusion reason: Ineligible publication type29133529
228 Welsh P, Preiss D, Lloyd SM, . Contrasting associations of insulin resistance with diabetes, cardiovascular disease and all-cause mortality in the elderly: PROSPER long-term follow-up. Diabetologia. 2014 Dec;57(12):2513–20. doi: 10.1007/s00125-014-3383-9. PMID: 25264116. Exclusion reason: Ineligible population25264116
229 Wilkins JT, Lloyd-Jones DM. Prevention: HOPE-3 trial - targeting BP and LDL-C in at-risk patients. Nat Rev Cardiol. 2016 May 16;13(6):315–6. doi: 10.1038/nrcardio.2016.74. PMID: 27181913. Exclusion reason: Ineligible publication type27181913
230 Wood FA, Howard JP, Finegold JA, . N-of-1 trial of a statin, placebo, or no treatment to assess side effects. N Engl J Med. 2020 Nov 26;383(22):2182–4. doi: 10.1056/NEJMc2031173. PMID: 33196154. Exclusion reason: Ineligible population33196154
231 Yadlowsky S, Hayward RA, Sussman JB, . Clinical implications of revised pooled cohort equations for estimating atherosclerotic cardiovascular disease risk. Ann Intern Med. 2018 Jul 03;169(1):20–9. doi: 10.7326/M17-3011. PMID: 29868850. Exclusion reason: Ineligible outcome29868850
232 Yang Q, Zhong Y, Gillespie C, . Assessing potential population impact of statin treatment for primary prevention of atherosclerotic cardiovascular diseases in the USA: population-based modelling study. BMJ Open. 2017 Jan 24;7(1):e011684. doi: 10.1136/bmjopen-2016-011684. PMID: 28119384. Exclusion reason: Ineligible outcome28119384
233 Yebyo HG, Aschmann HE, Kaufmann M, . Comparative effectiveness and safety of statins as a class and of specific statins for primary prevention of cardiovascular disease: a systematic review, meta-analysis, and network meta-analysis of randomized trials with 94,283 participants. Am Heart J. 2019 Apr;210:18–28. doi: 10.1016/j.ahj.2018.12.007. PMID: 30716508. Exclusion reason: Source document30716508
234 Yebyo HG, Aschmann HE, Puhan MA. Finding the balance between benefits and harms when using statins for primary prevention of cardiovascular disease: a modeling study. Ann Intern Med. 2019 Jan 01;170(1):1–10. doi: 10.7326/M18-1279. PMID: 30508425. Exclusion reason: Ineligible outcome30508425
235 Yeh YT, Yin WH, Tseng WK, . Lipid lowering therapy in patients with atherosclerotic cardiovascular diseases: which matters in the real world? Statin intensity or low-density lipoprotein cholesterol level? - Data from a multicenter registry cohort study in Taiwan. PLoS ONE 2017 Oct 26;12(10):e0186861. doi: 10.1371/journal.pone.0186861. PMID: 29073192. Exclusion reason: Ineligible study design29073192
236 Yourman LC, Cenzer IS, Boscardin WJ, . Evaluation of time to benefit of statins for the primary prevention of cardiovascular events in adults aged 50 to 75 years: a meta-analysis. JAMA Intern Med. 2021 Feb 1;181(2):179–85. doi: 10.1001/jamainternmed.2020.6084. PMID: 33196766. Exclusion reason: Source document33196766
237 Yousef Yengej FA, Limper M, Leavis HL. Statins for prevention of cardiovascular disease in systemic lupus erythematosus. Neth J Med. 2017 Apr;75(3):99–105. PMID: 28469051. Exclusion reason: Ineligible study design28469051
238 Zhou Z, Albarqouni L, Breslin M, . Statin-associated muscle symptoms (SAMS) in primary prevention for cardiovascular disease in older adults: a protocol for a systematic review and meta-analysis of randomised controlled trials. BMJ Open. 2017 Sep 27;7(9):e017587. doi: 10.1136/bmjopen-2017-017587. PMID: 28963307. Exclusion reason: Ineligible publication type28963307
239 Zhou Z, Albarqouni L, Curtis AJ, . The safety and tolerability of statin therapy in primary prevention in older adults: a systematic review and meta-analysis. Drugs Aging. 2020 Mar;37(3):175–85. doi: 10.1007/s40266-019-00736-y. PMID: 31919804. Exclusion reason: Source document31919804
240 Zigmont VA, Shoben AB, Lu B, . Statin users have an elevated risk of dysglycemia and new-onset-diabetes. Diabetes Metab Res Rev. 2019 Nov;35(8):e3189. doi: 10.1002/dmrr.3189. PMID: 31125480. Exclusion reason: Ineligible study design31125480

## Appendix A6 USPSTF Quality Rating Criteria

### Criteria for Assessing Internal Validity of Individual Studies

The Methods Work Group for the US Preventive Services Task Force (USPSTF) developed a set of criteria by which the internal validity of individual studies could be evaluated. The USPSTF accepted the criteria, and the associated definitions of quality categories, that relate to internal validity at its September 1999 meeting.

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for primary care practice may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a “good” study is one that meets all criteria well. A “fair” study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups:
  ○ For RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  ○ For cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to followup or overall high loss to followup.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of interventions.
- All important outcomes considered.
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

#### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.
Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.
Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

Source:U.S. Preventive Services Task Force Procedure Manual. Available at: https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual

## Appendix A7 Expert Reviewers of the Draft Report

❖ Jacquelyn Kulinski, MD, FASPC, Froedtert & Medical College of Wisconsin
❖ Bruce Warden, PharmD, Oregon Heath & Science University - Knight Cardiovascular Institute, Heart Failure and Transplant Program
❖ Eugene Yang, MD, MS, University of Washington School of Medicine
❖ Centers for Disease Control and Prevention representatives

Note: Reviewers provided comments on a prior version of the draft report and may or may not agree with the report findings.

## Appendix A8 Statin Adherence in Trials

Study Name | Details on Statin Adherence
ACAPS^81^ | 77% took ≥80% of study med (pill count) over mean 34.1 months
AFCAPS/TexCAPS^79^ | Maintained study drug regimen until trial termination (mean 5.2 years); Statin: 71%; Placebo: 63%
ALLHAT-LLT^80^ | Statin (receiving statin): 87% at 2 years, 80% at 4 years; Placebo (no lipid-lowering drug): 90% at 2 years, 81% at 4 years
ASCOT-LLA^90^ | Statin (taking statin): 87% at 3 years; Placebo (not taking statin): 91% at 3 years
ASPEN^85^ | Taking study medication; Statin: 68% at median 4 years; Placebo: 58% at median 4 years
ASTRONOMER^67^ | NR
Beishuizen, 2004^75^ | Adherence (pill count): 97% overall over 2 years
Bone, 2007^76^ | Did not discontinue treatment: 72% overall at 1 year
CAIUS^86^ | NR
CARDS^77^ | Statin (taking statin or another lipid-lowering drug): 90% at 1 year, 86% at 3 years, 78% at 4 years; Placebo (not taking statin or another lipid-lowering drug): 98% at 1 year, 88% at 3 years, 85% at 4 years
Heljić, 2009^82^ | NR
HOPE-3^93^ | Taking assigned regimen; Statin: 88% at 1 year, 84% at 3 years, 76% at 5 years; Placebo: 88% at 1 year, 83% at 3 years, 73% at 5 years
HYRIM^73^ | NR
JUPITER^66^ | Taking study pill: 75% overall at end of trial
KAPS^89^ | Adherence (pill count); Statin: 92% over 3 years; Placebo: 93% over 3 years
MEGA^88^ | Statin (received statin): 95% at 1 year, 90% at 5 years, 89% at 9 years; Placebo (did not receive statin): 91% at 1 year, 75% at 5 years, 59% at 9 years
METEOR^78^ | NR
Muldoon, 2004^87^ | Adherence (pill count): 95% overall over 6 months
PREVEND-IT^74^ | Compliance >75%; Statin: 74% at 4 years; Placebo: 66% at 4 years
PROSPER^91^ | Adherence (pill count): 94% overall (mean 3.2 years)
TRACE-RA^84^ | Taking “most” study tablets; Statin: 71% at 1 year, 53% at 3 years; Placebo: 72% at 1 year, 52% at 3 years
WOSCOPS^125^ | Did not discontinue treatment; Statin: 84% at 1 year, 77% at 3 years, 70% at 5 years; Placebo: 85% at 1 year, 78% at 3 years, 69% at 5 years

Abbreviations: ACAPS=Asymptomatic Carotid Artery Progression Study; AFCAPS/TexCAPS=Air Force/Texas Coronary Atherosclerosis Prevention Study; ALLHAT-LLT=Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial–Lipid-Lowering Trial; ASCOT-LLA=Anglo-Scandinavian Cardiac Outcomes Trial–Lipid Lowering Arm; ASTRONOMER=Aortic Stenosis Progression Observation: Measuring Effects of Rosuvastatin; CAIUS=Carotid Atherosclerosis Italian Ultrasound Study; CARDS=Collaborative Atorvastatin Diabetes Study; HOPE-3=Heart Outcomes Prevention Evaluation; JUPITER=Justification for the Use of Statins in Prevention and Intervention Trial Evaluating Rosuvastatin; KAPS=Kuopio Atherosclerosis Prevention Study; MEGA=Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese; METEOR=Measuring Effects on Intima-Media Thickness: an Evaluation of Rosuvastatin; NR=not reported; PREVEND-IT=Prevention of Renal and Vascular Endstage Disease Intervention Trial; PROSPER= Prospective Study of Pravastatin in the Elderly at Risk; TRACE-RA=Trial of Atorvastatin for the Primary Prevention of Cardiovascular Events in Patients with Rheumatoid Arthritis; WOSCOPS=West of Scotland Prevention Study Group.