# Abbreviations and Acronyms

ACC: American College of Cardiology
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
ALLHAT-LLT: Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial–Lipid-Lowering Trial
ALT: Alanine aminotransferase
ARD: Absolute risk difference
ASCOT-LLA: Anglo-Scandinavian Cardiac Outcomes Trial-Lipid Lowering Arm
AST: Aspartate transaminase
ASTRONOMER: Aortic Stenosis Progression Observation: Measuring Effects of Rosuvastatin
ATP: Adult Treatment Panel
BMI: Body mass index
CAC: Coronary artery calcium
CARDS: Collaborative Atorvastatin Diabetes Study
CCS: Canadian Cardiovascular Society
CI: Confidence interval
CHD: Coronary heart disease
CRP: C-reactive protein
CT: Computerized tomography
CTT: Cholesterol Treatment Trialists
CVA: Cerebrovascular accident
CVD: Cardiovascular disease
DBP: Diastolic blood pressure
EAS: European Atherosclerosis Society
EMPATHY: Standard Versus Intensive Statin Therapy for Hypercholesterolemic Patients with Diabetic Retinopathy
EPC: Evidence-based Practice Center
ESC: European Society of Cardiology
HDL-C: High density lipoprotein cholesterol
HIV: Human immunodeficiency virus
HOPE-3: Heart Outcomes Prevention Evaluation
HR: Hazard ratio
HYRIM: Hypertension High Risk Management
JUPITER: Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin
KQ: Key Question
LDL-C: Low density lipoprotein cholesterol
MEGA: Management of Elevated Cholesterol in the Primary Prevention Group of Adult Japanese
MESA: Multi-Ethnic Study of Atherosclerosis
MI: Myocardial infarction
NHANES: National Health and Nutrition Examination Survey
NICE: National Institute for Health and Care Excellence
NNT: Number needed to treat
NNH: Number needed to harm
OR: Odds ratio
PCE: Pooled cohort equation
PCSK9: Proprotein convertase subtilisin/kexin type 9
PROSPER: PROspective Study of Pravastatin in the Elderly at Risk
PVD: Peripheral vascular disease
QALY: Quality-adjusted life-year
RCT: Randomized controlled trial
REGARDS: Reasons for Geographic Racial Differences in Stroke
ROBINSCA: Risk or Benefit in Screening for Cardiovascular Disease
RR: Relative risk
SBP: Systolic blood pressure
SCORE: Systematic Coronary Risk Evaluation
TC: Total cholesterol
TexCAPS: Texas Coronary Atherosclerosis Prevention Study
TG: Triglyceride
TRACE-RA: Trial of Atorvastatin for the Primary Prevention of Cardiovascular Events in Patients with Rheumatoid Arthritis
USPSTF: US Preventive Services Task Force
VLDL-C: Very low density lipoprotein cholesterol
WOSCOPS: West of Scotland Coronary Prevention Study