# References

1 U.S. Preventive Services Task Force, Grossman DC, Bibbins-Domingo K, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Cardiovascular Risk Factors: US Preventive Services Task Force Recommendation Statement. Jama. 2017;318(2):167–74. PMID: 28697260. 10.1001/jama.2017.7171 28697260
2 Patnode CD, Evans CV, Senger CA, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. Jama. 2017;318(2):175–93. PMID: 28697259. 10.1001/jama.2017.3303 28697259
3 Patnode CD, Evans CV, Senger CA, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Known Cardiovascular Disease Risk Factors: Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2017 Jul. Report No.: 15-05222-EF-1: U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews; 2017.
4 O’Connor EA, Evans CV, Rushkin MC, . Behavioral Counseling to Promote a Healthy Diet and Physical Activity for Cardiovascular Disease Prevention in Adults With Cardiovascular Risk Factors: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. Jama. 2020;324(20):2076–94. PMID: 33231669. 10.1001/jama.2020.17108 33231669
5 O’Connor EA, Evans CV, Rushkin MC, . Behavioral Counseling Interventions to Promote a Healthy Diet and Physical Activity for Cardiovascular Disease Prevention in Adults With Cardiovascular Risk Factors: Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville, MD: Agency for Healthcare Research and Quality; 2020.
6 US Preventive Services Task Force. Behavioral Counseling Interventions to Promote a Healthy Diet and Physical Activity for Cardiovascular Disease Prevention in Adults With Cardiovascular Risk Factors: US Preventive Services Task Force Recommendation Statement. Jama. 2020;324(20):2069–75. 10.1001/jama.2020.21749 33231670
7 Krist AH, Davidson KW, Mangione CM, . Interventions for Tobacco Smoking Cessation in Adults, Including Pregnant Persons: US Preventive Services Task Force Recommendation Statement. Jama. 2021;325(3):265–79. PMID: 33464343. 10.1001/jama.2020.25019 33464343
8 U.S. Preventive Services Task Force, Curry SJ, Krist AH, . Behavioral Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: US Preventive Services Task Force Recommendation Statement. Jama. 2018;320(11):1163–71. PMID: 30326502. 10.1001/jama.2018.13022 30326502
9 Bibbins-Domingo K, U.S. Preventive Services Task Force. Aspirin Use for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2016;164(12):836–45. PMID: 27064677. 10.7326/M16-0577 27064677
10 U.S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. Jama. 2016;316(19):1997–2007. PMID: 27838723. 10.1001/jama.2016.15450 27838723
11 Siu A, U.S. Preventive Services Task Force. Screening for High Blood Pressure in Adults: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2015;163(10):778–86. PMID: 26458190.26458123
12 Siu A, U.S. Preventive Services Task Force. Screening for Abnormal Blood Glucose and Type 2 Diabetes Mellitus: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2015;163(11):861–8. PMID: 26501513.26501513
13 U.S. Department of Health and Human Services, U.S. Department of Agriculture. 2015–2020 Dietary Guidelines for Americans. 8th Edition. December 2015. https://health.gov/dietaryguidelines/2015/guidelines/. Accessed: November 5, 2019.
14 U.S. Department of Health and Human Services. Physical Activity Guidelines for Americans. 2nd edition. 2018. https://health.gov/paguidelines/second-edition/pdf/Physical_Activity_Guidelines_2nd_edition.pdf. Accessed: November 5, 2019.
15 2018 Physical Activity Guidelines Advisory Committee. 2018 Physical Activity Guidelines Advisory Committee Scientific Report. Washington, DC: U.S. Department of Health and Human Services, 2018. https://health.gov/paguidelines/second-edition/report/pdf/PAG_Advisory_Committee_Report.pdf. Accessed: November 5, 2019.
16 Virani SS, Alonso A, Benjamin EJ, . Heart Disease and Stroke Statistics-2020 Update: A Report From the American Heart Association. Circulation. 2020;141(9):e139–e596. PMID: 31992061. 10.1161/cir.0000000000000757 31992061
17 Centers for Disease Control and Prevention. Leading Causes of Death. https://www.cdc.gov/nchs/fastats/leading-causes-of-death.htm. Accessed: 2021.
18 Benjamin EJ, Muntner P, Alonso A, . Heart Disease and Stroke Statistics-2019 Update: A Report From the American Heart Association. Circulation. 2019;139(10):e56–e528. PMID: 30700139. 10.1161/CIR.0000000000000659 30700139
19 Mathers CD, Loncar D. Projections of global mortality and burden of disease from 2002 to 2030. PLoS Med. 2006;3(11):e442. PMID: 17132052. 10.1371/journal.pmed.0030442 17132052
20 Centers for Disease Control and Prevention. About Chronic Diseases. https://www.cdc.gov/chronicdisease/about/index.htm. Accessed: May 2021.
21 Fryar CD, Chen TC, Li X. Prevalence of uncontrolled risk factors for cardiovascular disease: United States, 1999-2010. NCHS Data Brief. 2012(103):1–8. PMID: 23101933. https://www.cdc.gov/nchs/data/databriefs/db103.pdf 23101933
22 Armstrong S, Wong CA, Perrin E, . Association of Physical Activity With Income, Race/Ethnicity, and Sex Among Adolescents and Young Adults in the United States: Findings From the National Health and Nutrition Examination Survey, 2007-2016. JAMA Pediatr. 2018;172(8):732–40. PMID: 29889945. 10.1001/jamapediatrics.2018.1273 29889945
23 Scholes S, Bann D. Education-related disparities in reported physical activity during leisure-time, active transportation, and work among US adults: repeated cross-sectional analysis from the National Health and Nutrition Examination Surveys, 2007 to 2016. BMC Public Health. 2018;18(1):926. PMID: 30055611. 10.1186/s12889-018-5857-z 30055611
24 Storey M, Anderson P. Income and race/ethnicity influence dietary fiber intake and vegetable consumption. Nutr Res. 2014;34(10):844–50. PMID: 25262170. 10.1016/j.nutres.2014.08.016 25262170
25 Lee-Kwan SH, Moore LV, Blanck HM, . Disparities in State-Specific Adult Fruit and Vegetable Consumption - United States, 2015. MMWR Morb Mortal Wkly Rep. 2017;66(45):1241–7. PMID: 29145355. 10.15585/mmwr.mm6645a1 29145355
26 Chai W, Fan JX, Wen M. Association of Individual and Neighborhood Factors with Home Food Availability: Evidence from the National Health and Nutrition Examination Survey. J Acad Nutr Diet. 2018;118(5):815–23. PMID: 29396154. 10.1016/j.jand.2017.11.009 29396154
27 American Academy of Family Physicians. Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Cardiovascular Risk Factors: Recommendation Statement. AFP. 2017;96(10). PMID: 29431383.29431383
28 National Institute for Health and Care Excellence. Physical activity: brief advice for adults in primary care. Public health guideline [PH44]. https://www.nice.org.uk/guidance/ph44. Accessed: December 2, 2019.
29 United States Department of Veterans Affairs, United States Department of Defense, United States Dyslipidemia Working Group. VA/DoD clinical practice guideline for the management of dyslipidemia for cardiovascular risk reduction. Washington, D.C.: Department of Veterans Affairs Department of Defense; 2014.
30 American College of Sports Medicine. Exercise is Medicine. https://www.exerciseismedicine.org/. Accessed: December 2, 2019.
31 Wolford ML, Stangnitti MN. Number of Adult Visits by Characteristics of Practices Identified as Usual Source of Care Providers during 2016–Results from the MEPS Medical Organizations Survey. Statistical Brief #523. July 2019. https://meps.ahrq.gov/data_files/publications/st523/stat523.shtml. Accessed: December 2, 2019.
32 Grabovac I, Smith L, Stefanac S, . Health Care Providers’ Advice on Lifestyle Modification in the US Population: Results from the NHANES 2011-2016. Am J Med. 2019;132(4):489–97 e1. PMID: 30521796. 10.1016/j.amjmed.2018.11.021 30521796
33 Shah MK, Moore MA, Narayan KMV, . Trends in Lifestyle Counseling for Adults With and Without Diabetes in the U.S., 2005-2015. Am J Prev Med. 2019;57(5):e153–e61. PMID: 31630765. 10.1016/j.amepre.2019.07.005 31630765
34 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force: 2015.
35 LeBlanc EL, Patnode CD, Webber EM, . Behavioral and Pharmacotherapy Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: An Updated Systematic Review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2018 Sep. Report No.: 18-05239-EF-1: U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews; 2018.
36 Whelton PK, Carey RM, Aronow WS, . 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA Guideline for the Prevention, Detection, Evaluation, and Management of High Blood Pressure in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Hypertension. 2017;71(6). PMID: 29133356. 10.1161/HYP.0000000000000065 29133356
37 Programme UND. 2018 Statistical Update: Human Development Indices and Indicators. New York: 2018.
38 Michie S, Richardson M, Johnston M, . The behavior change technique taxonomy (v1) of 93 hierarchically clustered techniques: building an international consensus for the reporting of behavior change interventions. Ann Behav Med. 2013;46(1):81–95. PMID: 23512568. 10.1007/s12160-013-9486-6 23512568
39 Raudenbush SW. Analyzing effect sizes: Random-effects models. In: Cooper H, Hedges LV, Valentine JC, editors. The Handbook of Research Synthesis and Meta-Analysis. 2nd ed. New York, New York: Russell Sage Foundation; 2009. p. 296–314.
40 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–710. PMID: 12939780. 10.1002/sim.1482 12939780
41 Veroniki AA, Jackson D, Bender R, . Methods to calculate uncertainty in the estimated overall effect size from a random-effects meta-analysis. Res Synth Methods. 2019;10(1):23–43. PMID: 30129707. 10.1002/jrsm.1319 30129707
42 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. Bmj. 1997;315(7109):629–34. PMID: 9310563. 10.1136/bmj.315.7109.629 9310563
43 Peters JL, Sutton AJ, Jones DR, . Comparison of two methods to detect publication bias in meta-analysis. Jama. 2006;295(6):676–80. PMID: 16467236. 10.1001/jama.295.6.676 16467236
44 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID.
45 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
46 Koniak-Griffin D, Brecht ML, Takayanagi S, . A community health worker-led lifestyle behavior intervention for Latina (Hispanic) women: feasibility and outcomes of a randomized controlled trial. International journal of nursing studies. 2015;52(1):75–87. PMID: 25307195. 10.1016/j.ijnurstu.2014.09.005 25307195
47 Oddone EZ, Gierisch JM, Sanders LL, . A Coaching by Telephone Intervention on Engaging Patients to Address Modifiable Cardiovascular Risk Factors: a Randomized Controlled Trial. Journal of General Internal Medicine. 2018;33(9):1487–94. PMID: 29736750. 10.1007/s11606-018-4398-6 29736750
48 Horton LA, Ayala GX, Slymen DJ, . A Mediation Analysis of Mothers’ Dietary Intake: The Entre Familia: Reflejos de Salud Randomized Controlled Trial. Health Education & Behavior. 2018;45(4):501–10. PMID: 29212358. 10.1177/1090198117742439 29212358
49 Allman-Farinelli M, Partridge SR, McGeechan K, . A Mobile Health Lifestyle Program for Prevention of Weight Gain in Young Adults (TXT2BFiT): Nine-Month Outcomes of a Randomized Controlled Trial. JMIR Mhealth Uhealth. 2016;4(2):e78. PMID: 27335237. 10.2196/mhealth.5768 27335237
50 Harris T, Kerry S, Victor C, . A pedometer-based walking intervention in 45- to 75-year-olds, with and without practice nurse support: the PACE-UP three-arm cluster RCT. Health Technol Assess. 2018;22(37):1–274. PMID: 29961442. 10.3310/hta22370 29961442
51 Patel MS, Benjamin EJ, Volpp KG, . Effect of a Game-Based Intervention Designed to Enhance Social Incentives to Increase Physical Activity Among Families: The BE FIT Randomized Clinical Trial. JAMA Intern Med. 2017;177(11):1586–93. PMID: 28973115. 10.1001/jamainternmed.2017.3458 28973115
52 Jenkins DJA, Boucher BA, Ashbury FD, . Effect of Current Dietary Recommendations on Weight Loss and Cardiovascular Risk Factors. J Am Coll Cardiol. 2017;69(9):1103–12. PMID: 28254171. 10.1016/j.jacc.2016.10.089 28254171
53 Maselli M, Gobbi E, Carraro A. Effectiveness of individual counselling and activity monitors to promote physical activity among university students. J Sports Med Phys Fitness. 2019;59(1):132–40. PMID: 29199784. 10.23736/S0022-4707.17.07981-6 29199784
54 Herghelegiu AM, Moser A, Prada GI, . Effects of health risk assessment and counselling on physical activity in older people: A pragmatic randomised trial. PLoS ONE. 2017;12(7):e0181371. PMID: 28727796. 10.1371/journal.pone.0181371 28727796
55 Wieland ML, Hanza MMM, Weis JA, . Healthy Immigrant Families: Randomized Controlled Trial of a Family-Based Nutrition and Physical Activity Intervention. American Journal of Health Promotion. 2018;32(2):473–84. PMID: 29186984. 10.1177/0890117117733342 29186984
56 Sun A, Cheng J, Bui Q, . Home-Based and Technology-Centered Childhood Obesity Prevention for Chinese Mothers With Preschool-Aged Children. J Transcult Nurs. 2017;28(6):616–24. PMID: 28826348. 10.1177/1043659617719139 28826348
57 Kegler MC, Haardorfer R, Alcantara IC, . Impact of Improving Home Environments on Energy Intake and Physical Activity: A Randomized Controlled Trial. Am J Public Health. 2016;106(1):143–52. PMID: 26696290. 10.2105/AJPH.2015.302942 26696290
58 Caplette ME, Provencher V, Bissonnette-Maheux V, . Increasing Fruit and Vegetable Consumption Through a Healthy Eating Blog: A Feasibility Study. JMIR Res Protoc. 2017;6(4):e59. PMID: 28420600. 10.2196/resprot.6622 28420600
59 Gomez Quinonez S, Walthouwer MJ, Schulz DN, . mHealth or eHealth? Efficacy, Use, and Appreciation of a Web-Based Computer-Tailored Physical Activity Intervention for Dutch Adults: A Randomized Controlled Trial. J Med Internet Res. 2016;18(11):e278. PMID: 27829576. 10.2196/jmir.6171 27829576
60 Spring B, Pellegrini C, McFadden HG, . Multicomponent mHealth Intervention for Large, Sustained Change in Multiple Diet and Activity Risk Behaviors: The Make Better Choices 2 Randomized Controlled Trial. J Med Internet Res. 2018;20(6):e10528. PMID: 29921561. 10.2196/10528 29921561
61 Marcus BH, Hartman SJ, Larsen BA, . Pasos Hacia La Salud: a randomized controlled trial of an internet-delivered physical activity intervention for Latinas. Int. 2016;13:62. PMID: 27234302. 10.1186/s12966-016-0385-7 27234302
62 Lombard C, Harrison C, Kozica S, . Preventing Weight Gain in Women in Rural Communities: A Cluster Randomised Controlled Trial. PLoS Med. 2016;13(1):e1001941. PMID: 26785406. 10.1371/journal.pmed.1001941 26785406
63 James EL, Ewald BD, Johnson NA, . Referral for Expert Physical Activity Counseling: A Pragmatic RCT. Am J Prev Med. 2017;53(4):490–9. PMID: 28818417. 10.1016/j.amepre.2017.06.016 28818417
64 Ball K, McNaughton SA, Le HN, . ShopSmart 4 Health: results of a randomized controlled trial of a behavioral intervention promoting fruit and vegetable consumption among socioeconomically disadvantaged women. Am J Clin Nutr. 2016;104(2):436–45. PMID: 27413129. 10.3945/ajcn.116.133173 27413129
65 Metzgar C, Nickols-Richardson S. Effects of nutrition education on weight gain prevention: a randomized controlled trial. Nutrition journal. 2016;15: Available from: http://cochranelibrary-wiley.com/o/cochrane/clcentral/articles/636/CN-01214636/frame.html.
66 Anand S, Samaan Z, Middleton C, . A digital health intervention to lower cardiovascular risk: a randomized clinical trial. JAMA Cardiology. 2016;1(5):601–6. PMID: 27438754. 10.1001/jamacardio.2016.1035 27438754
67 Samdal GB, Meland E, Eide GE, . The Norwegian Healthy Life Centre Study: A pragmatic RCT of physical activity in primary care. Scand J Public Health. 2019;47(1):18–27. PMID: 30074437. 10.1177/1403494818785260 30074437
68 Halperin DT, Laux J, LeFranc-Garcia C, . Findings From a Randomized Trial of Weight Gain Prevention Among Overweight Puerto Rican Young Adults. J Nutr Educ Behav. 2019;51(2):205–16. PMID: 30291016. 10.1016/j.jneb.2018.07.014 30291016
69 Fukuoka Y, Haskell W, Lin F, . Short- and Long-term Effects of a Mobile Phone App in Conjunction With Brief In-Person Counseling on Physical Activity Among Physically Inactive Women: The mPED Randomized Clinical Trial. JAMA netw. 2019;2(5):e194281. PMID: 31125101. 10.1001/jamanetworkopen.2019.4281 31125101
70 Fischer X, Kreppke JN, Zahner L, . Telephone-Based Coaching and Prompting for Physical Activity: Short- and Long-Term Findings of a Randomized Controlled Trial (Movingcall). Int J Environ Res Public Health. 2019;16(14):23. PMID: 31340528. 10.3390/ijerph16142626 31340528
71 Aadahl M, Linneberg A, Moller TC, . Motivational counseling to reduce sitting time: a community-based randomized controlled trial in adults. Am J Prev Med. 2014;47(5):576–86. PMID: 25113139. 10.1016/j.amepre.2014.06.020 25113139
72 Aittasalo M, Miilunpalo S, Kukkonen-Harjula K, . A randomized intervention of physical activity promotion and patient self-monitoring in primary health care. Prev Med. 2006;42(1):40–6. PMID: 16297442. 10.1016/j.ypmed.2005.10.003 16297442
73 Albright CL, Steffen AD, Wilkens LR, . Effectiveness of a 12-month randomized clinical trial to increase physical activity in multiethnic postpartum women: Results from Hawaii’s N Mikimiki Project. Prev Med. 2014;69:214–23. PMID: 25285751. 10.1016/j.ypmed.2014.09.019 25285751
74 Aldana SG, Greenlaw RL, Diehl HA, . The behavioral and clinical effects of therapeutic lifestyle change on middle-aged adults. Prev Chronic Dis. 2006;3(1):A05. PMID: 16356358. http://www.cdc.gov/pcd/issues/2006/jan/05_0088.htm 16356358
75 Alexander GL, McClure JB, Calvi JH, . A randomized clinical trial evaluating online interventions to improve fruit and vegetable consumption. Am J Public Health. 2010;100(2):319–26. PMID: 20019315. 10.2105/AJPH.2008.154468 20019315
76 Baron JA, Gleason R, Crowe B, . Preliminary trial of the effect of general practice based nutritional advice. Br J Gen Pract. 1990;40(333):137–41. PMID: 2115348. https://bjgp.org/content/40/333/137.long 2115348
77 Bennett GG, Foley P, Levine E, . Behavioral treatment for weight gain prevention among black women in primary care practice: A randomized clinical trial. JAMA Intern Med. 2013;173(19):1770–7. PMID: 23979005. 10.1001/jamainternmed.2013.9263 23979005
78 Beresford SA, Curry SJ, Kristal AR, . A dietary intervention in primary care practice: the Eating Patterns Study. Am J Public Health. 1997;87(4):610–6. PMID: 9146440. 10.2105/ajph.87.4.610 9146440
79 Bernstein A, Nelson ME, Tucker KL, . A home-based nutrition intervention to increase consumption of fruits, vegetables, and calcium-rich foods in community dwelling elders. J Am Diet Assoc. 2002;102(10):1421–7. PMID: 12396159. 10.1016/s0002-8223(02)90315-9 12396159
80 Bickmore TW, Silliman RA, Nelson K, . A Randomized Controlled Trial of an Automated Exercise Coach for Older Adults. J Am Geriatr Soc. 2013;61(10):1676–83. PMID: 24001030. 10.1111/jgs.12449 24001030
81 Brekke HK, Jansson PA, Lenner RA. Long-term (1- and 2-year) effects of lifestyle intervention in type 2 diabetes relatives. Diabetes Res Clin Pract. 2005;70(3):225–34. PMID: 15885845. 10.1016/j.diabres.2005.03.027 15885845
82 Bryan AD, Magnan RE, Hooper AE, . Colorado stride (COSTRIDE): testing genetic and physiological moderators of response to an intervention to increase physical activity. Int. 2013;10:139. PMID: 24359456. 10.1186/1479-5868-10-139 24359456
83 Burke L, Lee AH, Jancey J, . Physical activity and nutrition behavioural outcomes of a home-based intervention program for seniors: a randomized controlled trial. Int. 2013;10:14. PMID: 23363616. 10.1186/1479-5868-10-14 23363616
84 Carpenter RA, Finley C, Barlow CE. Pilot test of a behavioral skill building intervention to improve overall diet quality. J Nutr Educ Behav. 2004;36(1):20–4. PMID: 14756978. 10.1016/s1499-4046(06)60124-3 14756978
85 Carroll JK, Lewis BA, Marcus BH, . Computerized tailored physical activity reports. A randomized controlled trial. Am J Prev Med. 2010;39(2):148–56. PMID: 20621262. 10.1016/j.amepre.2010.04.005 20621262
86 Coates RJ, Bowen DJ, Kristal AR, . The Women’s Health Trial Feasibility Study in Minority Populations: changes in dietary intakes. Am J Epidemiol. 1999;149(12):1104–12. PMID: 10369504. 10.1093/oxfordjournals.aje.a009764 10369504
87 De Vet E, Oenema A, Sheeran P, . Should implementation intentions interventions be implemented in obesity prevention: the impact of if-then plans on daily physical activity in Dutch adults. Int. 2009;6:11. PMID: 19267889. 10.1186/1479-5868-6-11 19267889
88 Delichatsios HK, Friedman RH, Glanz K, . Randomized trial of a “talking computer” to improve adults’ eating habits. Am J Health Promot. 2001;15(4):215–24. PMID: 11349340. 10.4278/0890-1171-15.4.215 11349340
89 Elley CR, Kerse N, Arroll B, . Effectiveness of counselling patients on physical activity in general practice: cluster randomised controlled trial. Bmj. 2003;326(7393):793. PMID: 12689976. 10.1136/bmj.326.7393.793 12689976
90 Estabrooks PA, Smith-Ray RL, Almeida FA, . Move More: Translating an efficacious group dynamics physical activity intervention into effective clinical practice. Int J Sport Exerc Psychology. 2011;9(1):4–18. 10.1080/1612197X.2011.563123
91 Fjeldsoe BS, Miller YD, Graves N, . Randomized Controlled Trial of an Improved Version of MobileMums, an Intervention for Increasing Physical Activity in Women with Young Children. Ann Behav Med. 2015;49(4):487–99. PMID: 25582987. 10.1007/s12160-014-9675-y 25582987
92 Franko DL, Cousineau TM, Trant M, . Motivation, self-efficacy, physical activity and nutrition in college students: Randomized controlled trial of an internet-based education program. Prev Med. 2008;47(4):369–77. PMID: 18639581. 10.1016/j.ypmed.2008.06.013 18639581
93 Fries E, Edinboro P, McClish D, . Randomized trial of a low-intensity dietary intervention in rural residents: the Rural Physician Cancer Prevention Project. Am J Prev Med. 2005;28(2):162–8. PMID: 15710271. 10.1016/j.amepre.2004.10.017 15710271
94 Gao S, Stone RA, Hough LJ, . Physical activity counseling in overweight and obese primary care patients: Outcomes of the VA-STRIDE randomized controlled trial. Prev Med Rep. 2016;3:113–20. PMID: 26844197. 10.1016/j.pmedr.2015.12.007 26844197
95 Gell NM, Wadsworth DD. The use of text messaging to promote physical activity in working women: A randomized controlled trial. J Phys Act Health. 2015;12(6):756–63. PMID: 25110303. 10.1123/jpah.2013-0144 25110303
96 Goldstein MG, Pinto BM, Marcus BH, . Physician-based physical activity counseling for middle-aged and older adults: a randomized trial. Ann Behav Med. 1999;21(1):40–7. PMID: 18425653. 10.1007/BF02895032 18425653
97 Grandes G, Sanchez A, Sanchez-Pinilla RO, . Effectiveness of physical activity advice and prescription by physicians in routine primary care: a cluster randomized trial. Archives of internal medicine. 2009;169(7):694–701. PMID: 19364999. 10.1001/archinternmed.2009.23 19364999
98 Green BB, McAfee T, Hindmarsh M, . Effectiveness of telephone support in increasing physical activity levels in primary care patients. Am J Prev Med. 2002;22(3):177–83. PMID: 11897462. 10.1016/S0749-3797(01)00428-7 11897462
99 Greene GW, Fey-Yensan N, Padula C, . Change in fruit and vegetable intake over 24 months in older adults: results of the SENIOR project intervention. Gerontologist. 2008;48(3):378–87. PMID: 18591363. 10.1093/geront/48.3.378 18591363
100 Halbert JA, Silagy CA, Finucane PM, . Physical activity and cardiovascular risk factors: effect of advice from an exercise specialist in Australian general practice. Med J Aust. 2000;173(2):84–7. PMID: 10937036. 10.5694/j.1326-5377.2000.tb139250.x 10937036
101 Hargreaves EA, Mutrie N, Fleming JD. A Web-Based Intervention to Encourage Walking (StepWise): Pilot Randomized Controlled Trial. JMIR Res Protoc. 2016;5(1):e14. PMID: 26810251. 10.2196/resprot.4288 26810251
102 Harland J, White M, Drinkwater C, . The Newcastle exercise project: a randomised controlled trial of methods to promote physical activity in primary care. Bmj. 1999;319(7213):828–32. PMID: 10496829. 10.1136/bmj.319.7213.828 10496829
103 Harris T, Kerry SM, Victor CR, . A primary care nurse-delivered walking intervention in older adults: PACE (pedometer accelerometer consultation evaluation)-Lift cluster randomised controlled trial. PLoS Med. 2015;12(2):e1001783. PMID: 25689364. 10.1371/journal.pmed.1001783 25689364
104 Hivert MF, Langlois MF, Bérard P, . Prevention of weight gain in young adults through a seminar-based intervention program. Int J Obes (Lond). 2007;31(8):1262–9. PMID: 17356531. 10.1038/sj.ijo.0803572 17356531
105 Jacobs N, Clays E, De BD, . Effect of a tailored behavior change program on a composite lifestyle change score: a randomized controlled trial. Health Educ Res. 2011;26(5):886–95. PMID: 21712501. 10.1093/her/cyr046 21712501
106 Jeffery RW, French SA. Preventing weight gain in adults: the pound of prevention study. Am J Public Health. 1999;89(5):747–51. PMID: 10224988. 10.2105/ajph.89.5.747 10224988
107 John JH, Ziebland S, Yudkin P, . Effects of fruit and vegetable consumption on plasma antioxidant concentrations and blood pressure: a randomised controlled trial. Lancet. 2002;359(9322):1969–74. PMID: 12076551. 10.1016/S0140-6736(02)98858-6 12076551
108 Kallings LV, Sierra JJ, Fisher RM, . Beneficial effects of individualized physical activity on prescription on body composition and cardiometabolic risk factors: results from a randomized controlled trial. Eur J Cardiovasc Prev Rehabil. 2009;16(1):80–4. PMID: 19237997. 10.1097/HJR.0b013e32831e953a 19237997
109 Kattelmann KK, Bredbenner CB, White AA, . The effects of Young Adults Eating and Active for Health (YEAH): A theory-based web-delivered intervention. Journal of Nutrition Education and Behavior. 2014;46(6):S27–S41. PMID: 25457733. 10.1016/j.jneb.2014.08.007 25457733
110 Katz DL, Shuval K, Comerford BP, . Impact of an educational intervention on internal medicine residents’ physical activity counselling: the Pressure System Model. J Eval Clin Pract. 2008;14(2):294–9. PMID: 18324934. 10.1111/j.1365-2753.2007.00853.x 18324934
111 Kerr DA, Harray AJ, Pollard CM, . The connecting health and technology study: A 6-month randomized controlled trial to improve nutrition behaviours using a mobile food record and text messaging support in young adults. Int. 2016;13(1):52. PMID: 27098449. 10.1186/s12966-016-0376-8 27098449
112 King AC, Castro CM, Buman MP, . Behavioral Impacts of Sequentially versus Simultaneously Delivered Dietary Plus Physical Activity Interventions: the CALM Trial. Ann Behav Med. 2013;46(2):157–68. PMID: 23609341. 10.1007/s12160-013-9501-y 23609341
113 King AC, Friedman R, Marcus B, . Ongoing physical activity advice by humans versus computers: the Community Health Advice by Telephone (CHAT) trial. Health Psychol. 2007;26(6):718–27. PMID: 18020844. 10.1037/0278-6133.26.6.718 18020844
114 Kinmonth AL, Wareham NJ, Hardeman W, . Efficacy of a theory-based behavioural intervention to increase physical activity in an at-risk group in primary care (ProActive UK): a randomised trial. Lancet. 2008;371(9606):41–8. PMID: 18177774. 10.1016/S0140-6736(08)60070-7 18177774
115 Kolt GS, Schofield GM, Kerse N, . Effect of telephone counseling on physical activity for low-active older people in primary care: a randomized, controlled trial. J Am Geriatr Soc. 2007;55(7):986–92. PMID: 17608869. 10.1111/j.1532-5415.2007.01203.x 17608869
116 Kristal AR, Curry SJ, Shattuck AL, . A randomized trial of a tailored, self-help dietary intervention: the Puget Sound Eating Patterns study. Prev Med. 2000;31(4):380–9. PMID: 11006063. 10.1006/pmed.2000.0711 11006063
117 Lawton BA, Rose SB, Elley CR, . Exercise on prescription for women aged 40-74 recruited through primary care: two year randomised controlled trial. Bmj. 2008;337:a2509. PMID: 19074218. 10.1136/bmj.a2509 19074218
118 Lewis BA, Williams DM, Martinson BC, . Healthy for life: A randomized trial examining physical activity outcomes and psychosocial mediators. Ann Behav Med. 2013;45(2):203–12. PMID: 23229158. 10.1007/s12160-012-9439-5 23229158
119 Lutz SF, Ammerman AS, Atwood JR, . Innovative newsletter interventions improve fruit and vegetable consumption in healthy adults. J Am Diet Assoc. 1999;99(6):705–9. PMID: 10361533. 10.1016/S0002-8223(99)00169-8 10361533
120 Mailey EL, McAuley E. Impact of a brief intervention on physical activity and social cognitive determinants among working mothers: a randomized trial. J Behav Med. 2014;37(2):343–55. PMID: 23338616. 10.1007/s10865-013-9492-y 23338616
121 Marcus BH, Dunsiger SI, Pekmezi DW, . The Seamos Saludables study: A randomized controlled physical activity trial of Latinas. Am J Prev Med. 2013;45(5):598–605. PMID: 24139773. 10.1016/j.amepre.2013.07.006 24139773
122 Marcus BH, Napolitano MA, King AC, . Telephone versus print delivery of an individualized motivationally tailored physical activity intervention: Project STRIDE. Health Psychol. 2007;26(4):401–9. PMID: 17605559. 10.1037/0278-6133.26.4.401 17605559
123 Marsaux CF, Celis-Morales C, Fallaize R, . Effects of a Web-Based Personalized Intervention on Physical Activity in European Adults: A Randomized Controlled Trial. J Med Internet Res. 2015;17(10):e231. PMID: 26467573. 10.2196/jmir.4660 26467573
124 Marshall AL, Bauman AE, Owen N, . Population-based randomized controlled trial of a stage-targeted physical activity intervention. Ann Behav Med. 2003;25(3):194–202. PMID: 12763714. 10.1207/s15324796abm2503_05 12763714
125 Martinson BC, Crain AL, Sherwood NE, . Maintaining physical activity among older adults: six-month outcomes of the Keep Active Minnesota randomized controlled trial. Prev Med. 2008;46(2):111–9. PMID: 17904629. 10.1016/j.ypmed.2007.08.007 17904629
126 Mosca L, Mochari H, Liao M, . A novel family-based intervention trial to improve heart health: FIT Heart: results of a randomized controlled trial. Circ Cardiovasc Qual Outcomes. 2008;1(2):98–106. PMID: 20031796. 10.1161/CIRCOUTCOMES.108.825786 20031796
127 Napolitano MA, Whiteley JA, Papandonatos G, . Outcomes from the women’s wellness project: a community-focused physical activity trial for women. Prev Med. 2006;43(6):447–53. PMID: 16919322. 10.1016/j.ypmed.2006.06.011 16919322
128 Norris SL, Grothaus LC, Buchner DM, . Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30(6):513–23. PMID: 10901494. 10.1006/pmed.2000.0673 10901494
129 Parekh S, King D, Boyle FM, . Randomized controlled trial of a computer-tailored multiple health behaviour intervention in general practice: 12-month follow-up results. Int. 2014;11(1):41. PMID: 24646165. 10.1186/1479-5868-11-41 24646165
130 Pekmezi DW, Neighbors CJ, Lee CS, . A culturally adapted physical activity intervention for Latinas: a randomized controlled trial. Am J Prev Med. 2009;37(6):495–500. PMID: 19944914. 10.1016/j.amepre.2009.08.023 19944914
131 Pinto BM, Friedman R, Marcus BH, . Effects of a computer-based, telephone-counseling system on physical activity. Am J Prev Med. 2002;23(2):113–20. PMID: 12121799. 10.1016/S0749-3797(02)00441-5 12121799
132 Pinto BM, Goldstein MG, Ashba J, . Randomized controlled trial of physical activity counseling for older primary care patients. Am J Prev Med. 2005;29(4):247–55. PMID: 16242586. 10.1016/j.amepre.2005.06.016 16242586
133 Roderick P, Ruddock V, Hunt P, . A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. Br J Gen Pract. 1997;47(414):7–12. PMID: 9115804. https://bjgp.org/cgi/pmidlookup?view=long&pmid=9115804 9115804
134 Ruffin MT, Nease DE, Jr., Sen A, . Effect of preventive messages tailored to family history on health behaviors: the Family Healthware Impact Trial. Ann Fam Med. 2011;9(1):3–11. PMID: 21242555. 10.1370/afm.1197 21242555
135 Sacerdote C, Fiorini L, Rosato R, . Randomized controlled trial: effect of nutritional counselling in general practice. Int J Epidemiol. 2006;35(2):409–15. PMID: 16157616. 10.1093/ije/dyi170 16157616
136 Simkin-Silverman L, Wing RR, Hansen DH, . Prevention of cardiovascular risk factor elevations in healthy premenopausal women. Prev Med. 1995;24(5):509–17. PMID: 8524727. 10.1006/pmed.1995.1081 8524727
137 Smith BJ, Cinnadaio N, Cheung NW, . Investigation of a lifestyle change strategy for high-risk women with a history of gestational diabetes. Diabetes Res Clin Pract. 2014;106(3):e60–3. PMID: 25451910. 10.1016/j.diabres.2014.09.035 25451910
138 Springvloet L, Lechner L, de Vries H, . Short- and medium-term efficacy of a Web-based computer-tailored nutrition education intervention for adults including cognitive and environmental feedback: randomized controlled trial. J Med Internet Res. 2015;17(1):e23. PMID: 25599828. 10.2196/jmir.3837 25599828
139 Stewart AL, Verboncoeur CJ, McLellan BY, . Physical activity outcomes of CHAMPS II: a physical activity promotion program for older adults. J Gerontol A Biol Sci Med Sci. 2001;56(8):M465–M70. PMID: 11487597. 10.1093/gerona/56.8.M465 11487597
140 Thompson JL, Allen P, Helitzer DL, . Reducing diabetes risk in American Indian women. Am J Prev Med. 2008;34(3):192–201. PMID: 18312806. 10.1016/j.amepre.2007.11.014 18312806
141 Thompson WG, Kuhle CL, Koepp GA, . “Go4Life” exercise counseling, accelerometer feedback, and activity levels in older people. Arch Gerontol Geriatr. 2014;58(3):314–9. PMID: 24485546. 10.1016/j.archger.2014.01.004 24485546
142 Tinker LF, Bonds DE, Margolis KL, . Low-fat dietary pattern and risk of treated diabetes mellitus in postmenopausal women: the Women’s Health Initiative randomized controlled dietary modification trial. Archives of internal medicine. 2008;168(14):1500–11. PMID: 18663162. 10.1001/archinte.168.14.1500 18663162
143 Tokunaga-Nakawatase Y, Nishigaki M, Taru C, . Computer-supported indirect-form lifestyle-modification support program using Lifestyle Intervention Support Software for Diabetes Prevention (LISS-DP) for people with a family history of type 2 diabetes in a medical checkup setting: A randomized controlled trial. Prim Care Diabetes. 2014;8(3):207–14. PMID: 24529485. 10.1016/j.pcd.2014.01.007 24529485
144 Valve P, Lehtinen-Jacks S, Eriksson T, . LINDA - a solution-focused low-intensity intervention aimed at improving health behaviors of young females: a cluster-randomized controlled trial. BMC Public Health. 2013;13:1044. PMID: 24188719. 10.1186/1471-2458-13-1044 24188719
145 Van Hoecke AS, Delecluse C, Bogaerts A, . The long-term effectiveness of need-supportive physical activity counseling compared with a standard referral in sedentary older adults. J Aging Phys Act. 2014;22(2):186–98. PMID: 23628840. 10.1123/japa.2012-0261 23628840
146 van Stralen MM, de VH, Bolman C, . Exploring the efficacy and moderators of two computer-tailored physical activity interventions for older adults: a randomized controlled trial. Ann Behav Med. 2010;39(2):139–50. PMID: 20182833. 10.1007/s12160-010-9166-8 20182833
147 Vandelanotte C, De B, I, Sallis JF, . Efficacy of sequential or simultaneous interactive computer-tailored interventions for increasing physical activity and decreasing fat intake. Ann Behav Med. 2005;29(2):138–46. PMID: 15823787. 10.1207/s15324796abm2902_8 15823787
148 Vrdoljak D, Markovic BB, Puljak L, . Lifestyle intervention in general practice for physical activity, smoking, alcohol consumption and diet in elderly: a randomized controlled trial. Arch Gerontol Geriatr. 2014;58(1):160–9. PMID: 24012131. 10.1016/j.archger.2013.08.007 24012131
149 Wadsworth DD, Hallam JS. Effect of a web site intervention on physical activity of college females. Am J Health Behav. 2010;34(1):60–9. PMID: 19663753. 10.5993/AJHB.34.1.8 19663753
150 Warner LM, Wolff JK, Ziegelmann JP, . Revisiting self-regulatory techniques to promote physical activity in older adults: null-findings from a randomised controlled trial. Psychol Health. 2016:1–21. PMID: 27145328. 10.1080/08870446.2016.1185523 27145328
151 Gill DP, Blunt W, Boa Sorte Silva NC, . The HealtheSteps TM lifestyle prescription program to improve physical activity and modifiable risk factors for chronic disease: a pragmatic randomized controlled trial. BMC Public Health. 2019;19(1):841. PMID: 31253112. 10.1186/s12889-019-7141-2 31253112
152 Vidoni M, Lee M, Mitchell-Bennett L, . Home Visit Intervention Promotes Lifestyle Changes: results of an RCT in Mexican Americans. Am J Prev Med. 2019; 57(5): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02009315/full.
153 Patel M, Small D, Harrison J, . Effectiveness of Behaviorally Designed Gamification Interventions with Social Incentives for Increasing Physical Activity among Overweight and Obese Adults Across the United States: the STEP UP Randomized Clinical Trial. JAMA Intern Med. 2019;179(12):1–9. PMID: 31498375. 10.1001/jamainternmed.2019.3505 31498375
154 Walthouwer MJ, Oenema A, Lechner L, . Comparing a Video and Text Version of a Web-Based Computer-Tailored Intervention for Obesity Prevention: A Randomized Controlled Trial. J Med Internet Res. 2015;17(10):e236. PMID: 26481772. 10.2196/jmir.4083 26481772
155 Wing RR, Tate DF, Espeland MA, . Innovative Self-Regulation Strategies to Reduce Weight Gain in Young Adults: The Study of Novel Approaches to Weight Gain Prevention (SNAP) Randomized Clinical Trial. JAMA Intern Med. 2016;176(6):755–62. PMID: 27136493. 10.1001/jamainternmed.2016.1236 27136493
156 Larsen BA, Benitez TJ, Mendoza-Vasconez AS, . Randomized Trial of a Physical Activity Intervention for Latino Men: Activo. Am J Prev Med. 2020;59(2):219–27. PMID: 32448552. 10.1016/j.amepre.2020.03.007 32448552
157 Guagliano JM, Armitage SM, Brown HE, . A whole family-based physical activity promotion intervention: Findings from the Families Reporting Every Step to Health (FRESH) pilot randomised controlled trial. The International Journal of Behavioral Nutrition and Physical Activity Vol 17 2020, ArtID 120. 2020;17. PMID: 2020-72184-001. 10.1186/s12966-020-01025-3
158 van Keulen HM, Mesters I, Ausems M, . Tailored print communication and telephone motivational interviewing are equally successful in improving multiple lifestyle behaviors in a randomized controlled trial. Ann Behav Med. 2011;41(1):104–18. PMID: 20878293. 10.1007/s12160-010-9231-3 20878293
159 Harris T, Kerry SM, Limb ES, . Physical activity levels in adults and older adults 3-4 years after pedometer-based walking interventions: Long-term follow-up of participants from two randomised controlled trials in UK primary care. PLoS Med. 2018;15(3):e1002526. PMID: 29522529. 10.1371/journal.pmed.1002526 29522529
160 Harris T, Limb ES, Hosking F, . Effect of pedometer-based walking interventions on long-term health outcomes: Prospective 4-year follow-up of two randomised controlled trials using routine primary care data. PLoS Med. 2019;16(6):e1002836. PMID: 31237875. 10.1371/journal.pmed.1002836 31237875
161 Prentice RL, Aragaki AK, Howard BV, . Low-Fat Dietary Pattern among Postmenopausal Women Influences Long-Term Cancer, Cardiovascular Disease, and Diabetes Outcomes. J Nutr. 2019;08:08. PMID: 31175807. 10.1093/jn/nxz107 31175807
162 Howard BV, Van HL, Hsia J, . Low-fat dietary pattern and risk of cardiovascular disease: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. Jama. 2006;295(6):655–66. PMID: 16467234. 10.1001/jama.295.6.655 16467234
163 Prentice RL, Aragaki AK, Van Horn L, . Low-fat dietary pattern and cardiovascular disease: results from the Women’s Health Initiative randomized controlled trial. Am J Clin Nutr. 2017;106(1):35–43. PMID: 28515068. 10.3945/ajcn.117.153270 28515068
164 Assaf AR, Beresford SA, Risica PM, . Low-Fat Dietary Pattern Intervention and Health-Related Quality of Life: The Women’s Health Initiative Randomized Controlled Dietary Modification Trial. J Acad Nutr Diet. 2016;116(2):259–71. PMID: 26384466. 10.1016/j.jand.2015.07.016 26384466
165 D’Agostino RB, Sr., Vasan RS, Pencina MJ, . General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117(6):743–53. PMID: 18212285. 10.1161/circulationaha.107.699579 18212285
166 Harris T, Kerry SM, Limb ES, . Effect of a Primary Care Walking Intervention with and without Nurse Support on Physical Activity Levels in 45- to 75-Year-Olds: The Pedometer And Consultation Evaluation (PACE-UP) Cluster Randomised Clinical Trial. PLoS Med. 2017;14(1):e1002210. PMID: 28045890. 10.1371/journal.pmed.1002210 28045890
167 Kerse N, Elley CR, Robinson E, . Is physical activity counseling effective for older people? A cluster randomized, controlled trial in primary care. J Am Geriatr Soc. 2005;53(11):1951–6. PMID: 16274377. 10.1111/j.1532-5415.2005.00466.x 16274377
168 Allison MA, Aragaki AK, Ray RM, . A Randomized Trial of a Low-Fat Diet Intervention on Blood Pressure and Hypertension: Tertiary Analysis of the WHI Dietary Modification Trial. Am J Hypertens. 2016. PMID: 26708006. 10.1093/ajh/hpv196 26708006
169 Hall WD, Feng Z, George VA, . Low-fat diet: effect on anthropometrics, blood pressure, glucose, and insulin in older women. Ethn Dis. 2003;13(3):337–43. PMID: 12894958. https://pubmed.ncbi.nlm.nih.gov/12894958/ 12894958
170 Mochari-Greenberger H, Terry MB, Mosca L. Sex, age, and race/ethnicity do not modify the effectiveness of a diet intervention among family members of hospitalized cardiovascular disease patients. J Nutr Educ Behav. 2011;43(5):366–73. PMID: 21906549. 10.1016/j.jneb.2011.01.014 21906549
171 Shah M, Jeffery RW, Laing B, . Hypertension Prevention Trial (HPT): food pattern changes resulting from intervention on sodium, potassium, and energy intake. Hypertension Prevention Trial Research Group. J Am Diet Assoc. 1990;90(1):69–76. PMID: 2404050. https://pubmed.ncbi.nlm.nih.gov/2404050/ 2404050
172 The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. Jama. 1992;267(9):1213–20. PMID: 1586398. 10.1001/jama.1992.03480090061028 1586398
173 The Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. Archives of internal medicine. 1997;157(6):657–67. PMID: 9080920. 10.1001/archinte.1997.00440270105009 9080920
174 Whelton PK, Carey RM, Aronow WS, . 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA Guideline for the Prevention, Detection, Evaluation, and Management of High Blood Pressure in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Hypertension. 2018;71(6):e13–e115. PMID: 29133356. 10.1161/hyp.0000000000000065 29133356
175 Lewington S, Clarke R, Qizilbash N, . Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet. 2002;360(9349):1903–13. PMID: 12493255. 10.1016/s0140-6736(02)11911-8 12493255
176 Flint AC, Conell C, Ren X, . Effect of Systolic and Diastolic Blood Pressure on Cardiovascular Outcomes. N Engl J Med. 2019;381(3):243–51. PMID: 31314968. 10.1056/NEJMoa1803180 31314968
177 Prospective Studies Collaboration, Lewington S, Whitlock G, . Blood cholesterol and vascular mortality by age, sex, and blood pressure: a meta-analysis of individual data from 61 prospective studies with 55,000 vascular deaths. Lancet. 2007;370(9602):1829–39. PMID: 18061058. 10.1016/S0140-6736(07)61778-4 18061058
178 Emerging Risk Factors Collaboration, Sarwar N, Gao P, . Diabetes mellitus, fasting blood glucose concentration, and risk of vascular disease: a collaborative meta-analysis of 102 prospective studies. Lancet. 2010;375(9733):2215–22. PMID: 20609967. 10.1016/S0140-6736(10)60484-9 20609967
179 Emerging Risk Factors Collaboration, Rao Kondapally Seshasai S, Kaptoge S, . Diabetes mellitus, fasting glucose, and risk of cause-specific death. N Engl J Med. 2011;364(9):829–41. PMID: 21366474. 10.1056/NEJMoa1008862 21366474
180 Aune D, Sen A, Prasad M, . BMI and all cause mortality: systematic review and non-linear dose-response meta-analysis of 230 cohort studies with 3.74 million deaths among 30.3 million participants. Bmj. 2016;353:i2156. PMID: 27146380. 10.1136/bmj.i2156 27146380
181 Global BMI Mortality Collaboration, Di Angelantonio E, Bhupathiraju Sh N, . Body-mass index and all-cause mortality: individual-participant-data meta-analysis of 239 prospective studies in four continents. Lancet. 2016;388(10046):776–86. PMID: 27423262. 10.1016/s0140-6736(16)30175-1 27423262
182 Prospective Studies Collaboration, Whitlock G, Lewington S, . Body-mass index and cause-specific mortality in 900 000 adults: collaborative analyses of 57 prospective studies. Lancet. 2009;373(9669):1083–96. PMID: 19299006. 10.1016/S0140-6736(09)60318-4 19299006
183 Bhaskaran K, Dos-Santos-Silva I, Leon DA, . Association of BMI with overall and cause-specific mortality: a population-based cohort study of 3·6 million adults in the UK. Lancet Diabetes Endocrinol. 2018;6(12):944–53. PMID: 30389323. 10.1016/s2213-8587(18)30288-2 30389323
184 US Department of Agriculture and US Department of Health and Human Services. Dietary Guidelines for Americans, 2020-2025 9th Edition. 2020.
185 Wang X, Ouyang Y, Liu J, . Fruit and vegetable consumption and mortality from all causes, cardiovascular disease, and cancer: systematic review and dose-response meta-analysis of prospective cohort studies. Bmj. 2014;349:g4490. PMID: 25073782. 10.1136/bmj.g4490 25073782
186 Aune D, Giovannucci E, Boffetta P, . Fruit and vegetable intake and the risk of cardiovascular disease, total cancer and all-cause mortality-a systematic review and dose-response meta-analysis of prospective studies. Int J Epidemiol. 2017;46(3):1029–56. PMID: 28338764. 10.1093/ije/dyw319 28338764
187 Beresford SA, Johnson KC, Ritenbaugh C, . Low-fat dietary pattern and risk of colorectal cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. Jama. 2006;295(6):643–54. PMID: 16467233. 10.1001/jama.295.6.643 16467233
188 Howard BV, Manson JE, Stefanick ML, . Low-fat dietary pattern and weight change over 7 years: the Women’s Health Initiative Dietary Modification Trial. Jama. 2006;295(1):39–49. PMID: 16391215. 10.1001/jama.295.1.39 16391215
189 Prentice RL, Caan B, Chlebowski RT, . Low-fat dietary pattern and risk of invasive breast cancer: the Women’s Health Initiative Randomized Controlled Dietary Modification Trial. Jama. 2006;295(6):629–42. PMID: 16467232. 10.1001/jama.295.6.629 16467232
190 Li Y, Hruby A, Bernstein AM, . Saturated Fats Compared With Unsaturated Fats and Sources of Carbohydrates in Relation to Risk of Coronary Heart Disease: A Prospective Cohort Study. J Am Coll Cardiol. 2015;66(14):1538–48. PMID: 26429077. 10.1016/j.jacc.2015.07.055 26429077
191 Wang DD, Li Y, Chiuve SE, . Association of Specific Dietary Fats With Total and Cause-Specific Mortality. JAMA Intern Med. 2016;176(8):1134–45. PMID: 27379574. 10.1001/jamainternmed.2016.2417 27379574
192 Harcombe Z. Dietary fat guidelines have no evidence base: where next for public health nutritional advice? BJSM online. 2017;51(10):769–74. PMID: 27797736. 10.1136/bjsports-2016-096734 27797736
193 Chowdhury R, Warnakula S, Kunutsor S, . Association of dietary, circulating, and supplement fatty acids with coronary risk: a systematic review and meta-analysis. Ann Intern Med. 2014;160(6):398–406. PMID: 24723079. 10.7326/M13-1788 24723079
194 Zhu Y, Bo Y, Liu Y. Dietary total fat, fatty acids intake, and risk of cardiovascular disease: a dose-response meta-analysis of cohort studies. Lipids Health Dis. 2019;18(1):91. PMID: 30954077. 10.1186/s12944-019-1035-2 30954077
195 US Department of Health and Human Services. Physical Activity Guidelines for Americans. 2nd ed. Wasington, DC: US Dept of Health and Human Services; 2018. https://health.gov/paguidelines/second-edition/pdf/Physical_Activity_Guidelines_2nd_edition.pdf. Accessed: May 25, 2019.
196 Kraus WE, Powell KE, Haskell WL, . Physical Activity, All-Cause and Cardiovascular Mortality, and Cardiovascular Disease. Med Sci Sports Exerc. 2019;51(6):1270–81. PMID: 31095084. 10.1249/MSS.0000000000001939 31095084
197 World Health Organization. WHO Guidelines Approved by the Guidelines Review Committee. WHO Guidelines on Physical Activity and Sedentary Behaviour. Geneva: World Health Organization © World Health Organization 2020.; 2020.
198 Blond K, Brinkløv CF, Ried-Larsen M, . Association of high amounts of physical activity with mortality risk: a systematic review and meta-analysis. Br J Sports Med. 2020;54(20):1195–201. PMID: 31406017. 10.1136/bjsports-2018-100393 31406017
199 Ekelund U, Tarp J, Steene-Johannessen J, . Dose-response associations between accelerometry measured physical activity and sedentary time and all cause mortality: systematic review and harmonised meta-analysis. Bmj. 2019;366:l4570. PMID: 31434697. 10.1136/bmj.l4570 31434697
200 Kurth AE, Miller TL, Woo M, . Understanding Research Gaps and Priorities for Improving Behavioral Counseling Interventions: Lessons Learned From the U.S. Preventive Services Task Force. Am J Prev Med. 2015;49(3 Suppl 2):S158–65. PMID: 26296550. 10.1016/j.amepre.2015.06.007 26296550
201 McNellis RJ, Ory MG, Lin JS, . Standards of evidence for behavioral counseling recommendations. Am J Prev Med. 2015;49(3 Suppl 2):S150–7. PMID: 26296549. 10.1016/j.amepre.2015.06.002 26296549
202 Krist AH, Baumann LJ, Holtrop JS, . Evaluating Feasible and Referable Behavioral Counseling Interventions. Am J Prev Med. 2015;49(3 Suppl 2):S138–49. PMID: 26296548. 10.1016/j.amepre.2015.05.009 26296548
203 Curry SJ, Whitlock EP. Behavioral Counseling Interventions Expert Forum: Overview and Primer on U.S. Preventive Services Task Force Methods. Am J Prev Med. 2015;49(3 Suppl 2):S129–37. PMID: 26296547. 10.1016/j.amepre.2015.04.017 26296547
204 Curry SJ, McNellis RJ. Behavioral Counseling in Primary Care: Perspectives in Enhancing the Evidence Base. Am J Prev Med. 2015;49(3 Suppl 2):S125–8. PMID: 26296546. 10.1016/j.amepre.2015.06.004 26296546
205 US Department of Health and Human Services. The Community Guide. https://www.thecommunityguide.org/. Accessed: 2021.
206 US Department of Health and Human Services. Evidence-Based Cancer Control Programs (EBCCP). https://ebccp.cancercontrol.cancer.gov/index.do. Accessed: 2021.
207 United States Department of Agriculture. Scientific Report of the 2015 Dietary Guidelines Advisory Committee. Washington DC: United States Department of Agriculture; 2015.
208 Grant RW, Schmittdiel JA, Neugebauer RS, . Exercise as a vital sign: A quasi-experimental analysis of a health system intervention to collect patient-reported exercise levels. J Gen Intern Med. 2014;29(2):341–8. PMID: 24309950. 10.1007/s11606-013-2693-9 24309950
209 Michie S, Wood CE, Johnston M, . Behaviour change techniques: the development and evaluation of a taxonomic method for reporting and describing behaviour change interventions (a suite of five studies involving consensus methods, randomised controlled trials and analysis of qualitative data). Health Technol Assess. 2015;19(99):1–188. PMID: 26616119. 10.3310/hta19990 26616119
210 Morze J, Danielewicz A, Hoffmann G, . Diet Quality as Assessed by the Healthy Eating Index, Alternate Healthy Eating Index, Dietary Approaches to Stop Hypertension Score, and Health Outcomes: A Second Update of a Systematic Review and Meta-Analysis of Cohort Studies. J Acad Nutr Diet. 2020;120(12):1998–2031 e15. PMID: 33067162. 10.1016/j.jand.2020.08.076 33067162
211 Nguyen P, Le LK, Nguyen D, . The effectiveness of sedentary behaviour interventions on sitting time and screen time in children and adults: an umbrella review of systematic reviews. Int J Behav Nutr Phys Act. 2020;17(1):117. PMID: 32958052. 10.1186/s12966-020-01009-3 32958052
212 Brynjolfsson E, Horton J, Ozimek A, . COVID-19 and Remote Work: An Early Look at US Data. National Bureau of Economic Research. 2020. 10.3386/w27344
213 Rosenberg DE, Gell NM, Jones SM, . The Feasibility of Reducing Sitting Time in Overweight and Obese Older Adults. Health Educ Behav. 2015;42(5):669–76. PMID: 25794518. 10.1177/1090198115577378 25794518
214 U. S. Preventive Services Task Force, Grossman DC, Bibbins-Domingo K, . Behavioral Counseling to Promote a Healthful Diet and Physical Activity for Cardiovascular Disease Prevention in Adults Without Cardiovascular Risk Factors: US Preventive Services Task Force Recommendation Statement. Jama. 2017;318(2):167–74. PMID: 28697260. 10.1001/jama.2017.7171 28697260
215 U. S. Preventive Services Task Force, Curry SJ, Krist AH, . Behavioral Weight Loss Interventions to Prevent Obesity-Related Morbidity and Mortality in Adults: US Preventive Services Task Force Recommendation Statement. Jama. 2018;320(11):1163–71. 10.1001/jama.2018.13022 30326502
216 Davidson KW, Barry MJ, Mangione CM, . Screening for Prediabetes and Type 2 Diabetes: US Preventive Services Task Force Recommendation Statement. Jama. 2021;326(8):736–43. PMID: 34427594. 10.1001/jama.2021.12531 34427594
217 Mozaffarian D, Benjamin EJ, Go AS, . Heart Disease and Stroke Statistics-2016 Update: A Report From the American Heart Association. Circulation. 2016;133(4):e38–360. 10.1161/cir.0000000000000350 26673558
218 Higgins J, Savović J, Page M, . Chapter 8: Assessing risk of bias in a randomized trial. In: Higgins J, Thomas J, Chandler J, Cumpston M, Li T, Page M, ., editors. Cochrane Handbook for Systematic Reviews of Interventions version 6.1 (updated September 2020): Cochrane, 2020.
219 Hartman SJ, Pekmezi D, Dunsiger SI, . Physical Activity Intervention Effects on Sedentary Time in Spanish-Speaking Latinas. J Phys Act Health. 2020;17(3):343–8. PMID: 32035412. 10.1123/jpah.2019-0112 32035412