# Acknowledgments

We gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions; Tess Harris, MD, Penny Kris-Etherton, PhD, RD, Karen Goldstein, MD, and Jill Huber MD, who provided expert review of the draft report; Erin Abramsoh, DrPH, MPH, on behalf of the Centers for Disease Control and Prevention, Regine Douthard, MD, MPH, and Elena Gorodetsky, MD, PhD, with the Office of Research on Women’s Health, Josephine Boyington, PhD, MPH, Alison Brown, PhD, and Laura Friedman Donze, PhD, on behalf of the Cardiovascular Sciences Prevention and Population Science Program of the National Heart, Lung, and Blood Institute, and Amanada Alise Price, PhD, with the Office of Extramural Programs/Division of Extramural Science Programs at the National Institute of Nursing Research for providing federal review of our draft report. We also thank Melinda Davies, MA, and Jill Pope at the Kaiser Permanente Center for Health Research for technical and editorial assistance.