# Chapter 4 Discussion

## Summary of Evidence

In 2017, the USPSTF recommended that primary care professionals individualize the decision to offer or refer adults who do not have obesity and who do not have hypertension, dyslipidemia, abnormal blood glucose levels, or diabetes to behavioral counseling to promote a healthful diet and physical activity (C grade).^1^ We conducted this systematic review to assist the USPSTF in updating this recommendation. The current review focuses specifically on the effectiveness and harms of primary care–relevant interventions in persons without known CVD or CVD risk factors. The Task Force has a separate review^5^ and recommendation^6^ on the effectiveness and harms of these interventions among those with CVD risk factors.

We included 113 unique trials, just over a quarter of which (33 trials) were published since the previous USPSTF review. The pooled effect estimates found in our updated systematic review are generally consistent in magnitude with the 2017 review on this topic^3^ and lower in magnitude than the effects seen with the 2020 review among persons at high risk for CVD.^5^ The number of studies that contributed to each meta-analysis stayed the same or increased slightly but included higher quality and more relevant literature.

Table 8 summarizes the findings for this evidence review. We found that healthy diet and physical activity behavioral interventions in persons without CVD risk factors were associated with very modest reductions in continuous measures of blood pressure, LDL cholesterol, and adiposity at approximately 6 to 12 months of followup compared with control conditions. Given the consistency in the effect estimates and precision in those estimates over time for each intermediate outcome, we are moderately confident that our pooled estimates lie close to the true effects, although the body of evidence is still fairly small (~20 trials for most outcomes) and there is considerable variation in the interventions. Most pooled analyses resulted in moderate or substantial statistical heterogeneity, reflecting the clinical heterogeneity across studies. There was evidence of a dose-response relationship, with increasing intervention intensity being associated with larger improvements in some intermediate outcomes. Most of the interventions of higher intensity—for which we saw a benefit on intermediate outcomes—included healthy diet messages, with or without physical activity messages, and recruited persons outside of the primary care setting.

Table 8 Summary of Evidence, by Key Question

KQ | No. of RCTs (No. of observations) | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ1 | 15 RCTs (58,286); (6/15 trials identified in update) | Three good-quality trials (n=48,382) reported CVD-related health outcomes at up to 4 years and 13.4 years of followup. Largest trial (n=47,179) among post-menopausal women found no difference in all-cause or CVD-related mortality or CVD events between women in dietary counseling group vs. control group over median follow-up of 8.5 and 13.4 years. Two other trials of 12-week pedometer-based physical activity interventions found low CVD event rates for all participants, with statistically significant intervention effects on nonfatal and fatal CVD events at 4 years when the data from both trials was combined (n=1,203).; Patient-reported measures of QOL were sparsely reported and showed no clear pattern of clinically important benefit at 6 to 12 months followup (15 trials [n=58,286]). | Mortality and CVD events: Inconsistent, Imprecise; QOL: Inconsistent, Imprecise | Sparsely reported outcomes; High variability in measures and reporting of QOL outcomes, with possible selective reporting bias | Mortality and CVD events: Low for no benefit; QOL: Low for no benefit | Mortality and CVD event data limited to one large trial among post-menopausal women in the US and two primary care-based trials in the UK. Most participants were middle aged (>45 years) and older adults (>60 years) who were predominantly white females, without a history of CVD.; QOL data limited to mostly physical activity trials.
KQ2 | 43 RCTs (77,898); (14/43 trials identified in update) | Healthy diet and physical activity behavioral interventions were associated with small, statistically significant reductions in blood pressure, LDL cholesterol, and measures of adiposity at 6 to 12 months followup. Pooled differences in mean changes were:; - SBP: −0.80 (−1.30 to −0.31), k=23 RCTs (n=57,079); - DBP: −0.42 (−0.80 to −0.04), 24 RCTs (n=57,148); - LDL-C: −2.20 (−3.80 to −0.60), 15 RCTs (n=6,350); - BMI: −0.32 (−0.51 to −0.13), 27 RCTs (n=59,239); - Weight: −1.07 (−1.62 to −0.52), 24 RCTs (n=51,812); Evidence of dose-response effect with increasing intervention contact and duration associated with larger improvements in intermediate outcomes.; No evidence of an association with total cholesterol, HDL cholesterol, or fasting glucose. | Reasonably consistent and reasonably precise | Evidence for each intermediate outcome drawn from subsample of full body of evidence; Limited evidence beyond 12 months or for incidence of hypertension, dyslipidemia, or diabetes.; Considerable statistical heterogeneity (I^2^>90%) for meta-analyses of adiposity outcomes. | Moderate for benefit | Generally applicable to adults not at risk for CVD.; High-intensity interventions were more likely to include both healthy diet and physical activity messages and take place outside of primary care.
KQ3 | 109 RCTs (125,878); (30/109 trials identified in update) | Magnitude and precision in differences for [underlined: dietary outcomes] were variable across studies and resulted in considerable heterogeneity in meta-analysis. Pooled analyses indicated statistically significant associations between healthy diet interventions (with or without PA messages) and measures of saturated fat (SMD, 0.53 [95% CI, −0.78 to −0.27], 16 RCTs), fiber (SMD, 0.24 [95% CI, 0.05 to 0.43], 13 RCTs), and fruit and vegetable intake (MD, 1.11 [95% CI, 0.41 to 1.81], 17 RCTs) at 6 to 12 months followup. Sodium intake was infrequently reported.; Small, statistically significant association with behavioral interventions and [underlined: physical activity] in favor of interventions over controls (SMD, 0.19 [95% CI, 0.14 to 0.25]; 59 trials [n=20,801]), or a mean difference of approximately 33 minutes of physical activity per week between groups (MD, 33.0 min [95% CI, 21.9 to 44.2], 37 RCTs). Additionally, intervention participants had significantly higher odds of meeting PA recommendations (150 min/week of PA) vs. control group participants (OR=1.41 [95% CI, 1.18 to 1.67], 24 RCTs).; No clear evidence of an association between interventions and [underlined: sedentary behaviors], though few studies included messages regarding changes in sedentary behaviors (15 RCTs). | Reasonably consistent, reasonably precise | Almost all outcomes based on self-report. Instruments, recall periods, and summary measures were extremely heterogeneous with varying evidence of validity and reliability. | Diet: Low for benefit; Physical activity: Moderate for benefit; Sedentary behavior: Low for no benefit | Generally applicable to adults not at risk for CVD.; Larger effect sizes for physical activity outcomes were seen for persons with lower levels of physical activity at baseline.; Few interventions explicitly mentioned targeting changes in sedentary behaviors.
KQ4 | 23 RCTs (12,452); (12/23 trials identified in update) | Adverse events related to diet and physical activity interventions were very rare, with generally no statistically significant increased risk of harm.; Twelve trials (n=5,771) including physical activity counseling reported generally no differences in rates of musculoskeletal injuries or falls between intervention and control groups. | Reasonably consistent, reasonably precise | Harms were sparsely reported, and few details provided about how harms were recorded and specific events that occurred. | Moderate for no harms^*^ | Applies to harms related to counseling interventions, and any subsequent behavior changes that occurred. Most trials reporting harms included physical activity messages.

* Despite the relatively limited number of studies that reported harms related to interventions, we are moderately confident that there are no serious harms related to behavioral counseling interventions for healthful diet and physical activity.

Abbreviations: BMI=body mass index; CI=confidence interval; CV=cardiovascular; CVD=cardiovascular disease; DPB=diastolic blood pressure; FBG=fasting blood glucose; HDL-C=high-density lipoprotein cholesterol; HR=hazard ratio; k=trials; KQ=key question; LDL-C=low-density lipoprotein; MD=mean difference; min=minutes; mm=millimeter(s); No.=number; OR=odds ratio; PA=physical activity; QOL=quality of life; RCT=randomized clinical trial; SBP=systolic blood pressure; SD=standard deviation; SMD=standardized mean difference; TC=total cholesterol; US=United States.

There was considerably more evidence for behavioral outcomes, with almost all included trials reporting the effects of counseling interventions on dietary intake, physical activity, and/or sedentary behaviors. The direction of effects for all behavioral outcomes were reasonably consistent and suggested small to moderate benefits for dietary and physical activity outcomes. There was less evidence on the effects of interventions on sedentary behaviors, and no clear evidence of a benefit. Data on the long-term effects of interventions (i.e., more than 1-year post-intervention) on behavioral and intermediate outcomes were limited.

Eight trials that were included in the 2017 review were excluded from this update, mostly due to the included population (e.g., having elevated blood pressure or other chronic conditions). The effect of removing these trials was particularly evident for health outcomes (KQ1), where the removal of the Hypertension Prevention Trial^171^ and the Trials of Hypertension Prevention I and II^172,^ ^173^ resulted in less included evidence for all-cause and CVD-related mortality and CVD events. Furthermore, the pooled results found here for blood pressure were slightly smaller in magnitude than the pooled effects found in 2017. All three of these trials focused on preventing hypertension, through intensive sodium restriction, among adults with high-normal blood pressure and are now included in the USPSTF related review among persons at high risk for CVD.^5^ Given the changes in thresholds defining elevated and high blood pressure,^174^ conceptually, this evidence is better synthesized with the companion review.

We have limited certainty in the evidence for the effects of lifestyle interventions on longer-term health outcomes, including all-cause and CVD-specific mortality, CVD events, and quality of life. The evidence for these outcomes was sparse and inconsistent in the effects, precluding a robust conclusion.

Finally, despite a relatively smaller body of evidence related to harms, we are moderately confident that there are no serious adverse events associated with behavioral counseling for healthy diet and physical activity.

## Applicability of Findings and Intervention Approaches

By design, the current review excluded studies that specifically recruited individuals at high risk of CVD—defined only by the presence of hypertension, dyslipidemia, or impaired fasting glucose. In all other ways, the persons represented in the trials exhibited a broad range of sociodemographic and behavioral characteristics. Many included studies were limited to subpopulations for which particular CVD risk factors and dietary and activity habits may differ from their counterparts, including women (in particular, the large WHI dietary modification trial [n=48,835]), older adults (60 years or older), racial/ethnic minority groups, those with a family history of CVD or diabetes, and persons who are overweight or have obesity. Furthermore, nearly half of the studies limited enrollment to persons with suboptimal levels of physical activity, inadequate dietary habits, or both. The remaining studies were conducted among unselected adults with varying sociodemographic and clinical characteristics. Unfortunately, very few trials reported the underlying CVD risk of participants at baseline (i.e., the proportion of participants with existing hypertension or dyslipidemia). While this review was designed to represent persons not at risk of CVD, we cannot confidently say that all participants within the included evidence were of “average” CVD risk; we just know that they were not recruited into these trials because of an underlying risk.

Although the majority of studies recruited participants directly (via invitations through primary care, the broader health care system, or some other convenience sample rather than relying on community volunteers), the adults who took part in these studies may have been more motivated to change their behaviors than those not represented in these trials. Indeed, we saw generally high rates of retention (>80% at 12 months) over the course of the studies and good adherence to the interventions—rates that may not be seen in real-world scenarios. Given the broad representation across population characteristics and the fact that most of the studies took place in the United States, we believe the findings of this review are generalizable to a U.S. primary care population, although the magnitude of the effects may be slightly lower when applied to general practice.

There was some evidence, at least for intermediate outcomes, that increasing intervention intensity—in terms of time spent with an interventionist, the number of cumulative intervention sessions, and the total duration of the intervention—was related to greater benefit. It is difficult to disentangle differences in the various intervention, population, and broader study characteristics, however, when attempting to explain the effectiveness of the interventions on these outcomes. Most of the studies that reported intermediate outcomes implemented relatively intense interventions and most of these interventions focused messages on dietary changes and may or may not have included messages about increasing physical activity. Even within the high-intensity interventions, the estimated intervention contact (minutes of counseling) ranged considerably—from 375 minutes (6 hours and 15 minutes) to 2,310 minutes (38.5 hours) over the course of 4 weeks to 6 years. Furthermore, most of these high-intensity interventions took place outside of the primary care setting and may represent persons with higher motivation to change their behaviors. Similarly, the effects seen for dietary outcomes were mostly for medium- or high-intensity interventions, whereas the effects for physical activity outcomes included trials testing mostly low- and medium-intensity interventions. There was no evidence of a dose-response relationship with intervention intensity and physical activity outcomes, but there was evidence that trials targeting persons with baseline activity below recommended levels saw larger improvements in physical activity participation than trials in which participants were already achieving higher levels of physical activity.

Based on the included literature, we are not able to define either the minimum necessary intervention components for an effective intervention or identify a single optimal or representative intervention. No two studies had exactly the same goals, behavior change messages, modes of delivery, or delivery schedule, although some explicitly built on learnings from earlier trials (for example, the STRIDE,^122^ COSTRIDE,^82^ and VA-STRIDE^94^ trials and the PACE-Lift^103^ and PACE-UP trials^50^). Though we broadly focused on studies related to the primary prevention of CVD among healthy adults, the specific aims of each trial differed and appropriately resulted in different intervention goals and components. For most trials, the primary aim was improving behavioral outcomes. Across all interventions, most included tailored advice and materials and encouraged goal setting and self-monitoring. A substantial number of the trials, many of the newer studies, included interventions that were administered completely remotely—either via telephone, print materials, or were computer- or e-mail-based.

Although we largely saw consistency in the direction of beneficial effects among all the trials, there was variation in the magnitude of the effects and there was often wide variation within studies. This variation likely reflects that even within studies, some participants can achieve greater change while others may not. Most likely, the ideal counseling intervention for any given person will depend on consideration of their specific clinical characteristics, including existing diet and physical activity behaviors, and the larger context of other prevention or screening priorities, given the limited time for a typical primary care encounter. Furthermore, it is likely that there are many social determinants of health at play (e.g., food insecurity) that may impact the size of the effects seen. Again, unfortunately, very limited data was provided on the underlying social conditions (i.e., risks and inequities) present among the included samples.

## Observational Evidence on the Association Between Differences in Intermediate and Behavioral Outcomes and Health Outcomes

Due to limited direct trial evidence on the effect of healthy diet and physical activity interventions on health outcomes included in this review, we present observational data to contextualize the results. This evidence likely represents an upper bound of potential benefit given that most of the observational evidence also includes adults at high risk of CVD. This also assumes an optimistic outlook that any behavior modifications, and hence changes in intermediate outcomes, are maintained over time. Nevertheless, overall, observational data from very large prospective studies and individual participant data (IPD) meta-analyses of prospective cohort studies show that small differences in intermediate outcomes (e.g., blood pressure, non-HDL cholesterol, and BMI) translate into small reductions in the risk of cardiovascular-related and all-cause mortality. Table 9 summarizes the relationship between each intermediate and health outcome using both the original hazard ratio (HR) reported in the observational studies as well as a converted HR for the pooled between-group differences found in this review.

Table 9 Association Between Changes in Intermediate Outcomes and Mortality Outcomes, Based on Individual Patient Data Meta-Analysis of Epidemiological Studies

Intermediate Outcome | Mortality Outcome | Age, years | Original Increment Difference | HR (95% CI) for Health Outcome for Original Increment Change in Intermediate Outcome | Converted Increment Difference | HR (95% CI) for Health Outcome for Converted Increment Change in Intermediate Outcome
SBP^175^ | IHD | 40-49 | ↓20 mm Hg | 0.49 (0.45 to 0.53)^*^ | ↓0.5 mm Hg | 0.982 (0.980 to 0.984)
SBP^175^ | IHD | 60-69 | ↓20 mm Hg | 0.54 (0.53 to 0.55)^*^ | ↓0.5 mm Hg | 0.985 (0.984 to 0.985)
SBP^175^ | Stroke | 40-49 | ↓20 mm Hg | 0.36 (0.32 to 0.40)^*^ | ↓0.5 mm Hg | 0.975 (0.972 to 0.977)
SBP^175^ | Stroke | 60-69 | ↓20 mm Hg | 0.43 (0.41 to 0.45)^*^ | ↓0.5 mm Hg | 0.979 (0.978 to 0.980)
Non-HDL-C^177^ | IHD | 40-59 | ↓1 mmol/L | 0.57 (0.52 to 0.62)^†^ | ↓3 mg/dL | 0.957 (0.950 to 0.964)
Non-HDL-C^177^ | IHD | 60-69 | ↓1 mmol/L | 0.66 (0.61 to 0.71)^†^ | ↓3 mg/dL | 0.968 (0.962 to 0.974)
TC^177^ | IHD | 40-49 | ↓1 mmol/L | 0.44 (0.42 to 0.48)^§^ | ↓2 mg/dL | 0.958 (0.956 to 0.963)
TC^177^ | IHD | 60-69 | ↓1 mmol/L | 0.72 (0.69 to 0.74)^§^ | ↓2 mg/dL | 0.983 (0.981 to 0.985)
TC^177^ | Stroke | 40-59 | ↓1 mmol/L | 0.90 (0.84 to 0.97)^**^ | ↓2 mg/dL | 0.995 (0.991 to 0.998)
TC^177^ | Stroke | 60-69 | ↓1 mmol/L | 1.02 (0.97 to 1.08)^**^ | ↓2 mg/dL | 1.001 (0.998 to 1.004)
FBG^††^ | F+NF CHD^††^,^178^ | 56^‡‡^ | ↑1 mmol/L | 1.12 (1.08 to 1.15) | ↓2 mg/dL | 1.013 (1.009 to 1.016)
FBG^††^ | Vascular^179^ | 53^‡‡^ | ↑18.02 mg/dL | 1.13 (1.11 to 1.15) | ↓2 mg/dL | 1.014 (1.012 to 1.016)
FBG^††^ | All-cause^179^ | 53^‡‡^ | ↑18.02 mg/dL | 1.10 (1.09 to 1.11) | ↓2 mg/dL | 1.011 (1.010 to 1.012)
BMI^§§^ | IHD^182^ | 35-89 | ↑5 kg/m^2^ | 1.39 (1.34 to 1.44) | ↓0.3 kg/m^2^ | 0.980 (0.982 to 0.978)
BMI^§§^ | IHD^182^ | 35-59 | ↑5 kg/m^2^ | 1.50 (1.39 to 1.62) | ↓0.3 kg/m^2^ | 0.976 (0.980 to 0.972)
BMI^§§^ | IHD^182^ | 60-69 | ↑5 kg/m^2^ | 1.40 (1.32 to 1.49) | ↓0.3 kg/m^2^ | 0.980 (0.984 to 0.976)
BMI^§§^ | CHD^181^ | 35-89 | ↑5 kg/m^2^ | 1.42 (1.35 to 1.49) | ↓0.3 kg/m^2^ | 0.979 (0.982 to 0.976)
BMI^§§^ | Stroke^182^ | 35-89 | ↑5 kg/m^2^ | 1.39 (1.31 to 1.48) | ↓0.3 kg/m^2^ | 0.980 (0.984 to 0.977)
BMI^§§^ | Stroke^182^ | 35-59 | ↑5 kg/m^2^ | 1.76 (1.52 to 2.04) | ↓0.3 kg/m^2^ | 0.967 (0.975 to 0.958)
BMI^§§^ | Stroke^182^ | 60-69 | ↑5 kg/m^2^ | 1.49 (1.34 to 1.67) | ↓0.3 kg/m^2^ | 0.976 (0.983 to 0.970)
BMI^§§^ | All-cause^181^ | 35-89 | ↑5 kg/m^2^ | 1.31 (1.29 to 1.33) | ↓0.3 kg/m^2^ | 0.984 (0.985 to 0.983)
BMI^§§^ | All-cause^181^ | 35-49 | ↑5 kg/m^2^ | 1.52 (1.47 to 1.56) | ↓0.3 kg/m^2^ | 0.975 (0.977 to 0.974)
BMI^§§^ | All-cause^181^ | 50-69 | ↑5 kg/m^2^ | 1.37 (1.35 to 1.39) | ↓0.3 kg/m^2^ | 0.981 (0.982 to 0.980)
BMI^§§^ | All-cause^181^ | 70-89 | ↑5 kg/m^2^ | 1.21 (1.17 to 1.25) | ↓0.3 kg/m^2^ | 0.989 (0.991 to 0.987)

* For SBP above 115 mm Hg. Adjusted for age (within range being considered), sex, and study. Adjustments for lipids, diabetes, weight, alcohol, and smoking did not change results.

† Adjusted for age (within range being considered), sex, and study. Formal test for heterogeneity NS for sex (significant for age).

‡ Directionality inverted from negative to positive.

§ Adjusted for age (within range being considered), sex, and study. Result slightly attenuated by adjustment for SBP and unaltered by adjustment for smoking. Formal test for heterogeneity NS for sex for age <69 years; formal test for heterogeneity significant for age.

** Adjusted for age (within range being considered), sex, and study. Result attenuated with adjustment for SBP and minimal increase in HR with further adjustment for smoking for 40-59-year group only.

†† For FBG above 100 mg/dL and assuming log-linear association. Adjusted for age, smoking, BMI, SBP.

‡‡ Mean age.

§§ For BMI above 25 kg/m^2^.

Abbreviations: BMI=body mass index; CHD=coronary heart disease; CI=confidence interval; dL=deciliter; F+NF=fatal plus nonfatal; FBG=fasting blood glucose; HDL-C=high-density lipoprotein cholesterol; Hg=mercury; HR=hazard ratio; IHD=ischemic heart disease; kg=kilogram(s); m=meter(s); mg=milligram(s); mm=millimeter(s);mmol=millimole(s); NS=not significant; SBP=systolic blood pressure; TC=total cholesterol.

We found that behavioral counseling interventions in persons without CVD risk factors were associated with a −0.80 and −0.42-mm Hg difference in SBP and DBP, respectively, compared with control groups. According to an IPD meta-analysis of 61 prospective observational studies conducted by the Prospective Studies Collaboration, a strong and direct relationship was found between blood pressure and age-specific mortality for stroke, ischemic heart disease, and other vascular causes after controlling for lipid levels, diabetes, weight, alcohol intake, and smoking.^175^ When associations from this analysis, expressed as HRs per 20-mm Hg difference in SBP and per 10-mm Hg difference in DBP, were converted into smaller increments more consistent with our results, the findings suggested that a small blood pressure difference in SBP of 0.5 mm Hg in adults ages 40 to 49 years is associated with an ischemic heart disease (IHD) mortality reduction of 2 percent and a stroke mortality reduction of 3 percent (Table 9). These associations were similar in magnitude for DBP when estimated for increments of 0.5 mm Hg. A recent, separate analysis extended these findings to show that important associations between blood pressure and CVD events exist regardless of threshold (e.g., 140/90 mm Hg vs. 130/90 mm Hg) and when using real-world clinical databases that do not use research-quality blood pressure measurements.^176^

Our meta-analysis of lipid outcomes suggested an association between healthy diet and physical activity counseling and LDL cholesterol, with a magnitude of approximately a 2 mg/dL difference in favor of interventions. Based on a separate IPD meta-analysis by the Prospective Studies Collaboration, there is evidence of a strong positive relationship between non-HDL cholesterol level (reported instead of LDL cholesterol in the IPD meta-analysis) and ischemic heart disease mortality, where a decrease in non-HDL cholesterol of 1 mmol/L was associated with a 43 percent reduction in IHD mortality among 40 to 59-year-olds (Table 9).^177^ Converting this to a difference of 3 mg/dL results in a 4 percent reduction in fatal IHD risk at ages 40 to 59 years and a 3 percent reduction at ages 60 to 69 years (Table 9).

Our pooled analysis of interventions of all levels of intensity did not find a significant effect for diet or physical activity counseling interventions on fasting glucose. Epidemiologic evidence suggests that maintaining a normoglycemic level is associated with the best cardiovascular outcomes and incremental increases beyond normoglycemia increases cardiovascular mortality.^178,^ ^179^

By design, we excluded trials that explicitly focused on weight loss. Nevertheless, small improvements in BMI, weight, and waist circumference were found to be associated with diet and physical activity interventions at 6 to 12 months of followup. The statistical heterogeneity for these pooled effects was considerable, however, and therefore some uncertainty in the average effects remains. The between-group differences found in our included trials suggested a reduction in BMI of approximately −0.30 kg/m^2^. Several large studies and meta-analyses have found strong associations between BMI and all-cause mortality and that even modest changes in BMI may be associated with small reductions in all-cause and cardiovascular related mortality.^180–182^ In an IPD meta-analysis of 189 prospective studies (n=3,951,455 never smokers without chronic diseases) all-cause mortality was minimal at BMIs of 20 to 25.0 kg/m^2^ and increased significantly both for BMIs just below this range and throughout the overweight and obesity range.^181^ For BMI over 25.0 kg/m^2^, mortality increased approximately log-linearly with BMI; the HR per 5 kg/m^2^ units higher BMI was 1.31 (95% CI, 1.29 to 1.33).^181^ Similarly, a recent population-based cohort study of nearly 4 million adults in the UK reported a J-shaped association between BMI and all-cause mortality.^183^ The estimated all-cause mortality HR per 5 kg/m^2^ increase in BMI was 0.81 (95% CI, 0.80 to 0.82) for individuals with a BMI below 25 kg/m^2^ and 1.21 (95% CI, 1.20 to 1.22) in individuals with BMI above 25 kg/m^2^.^183^

Among studies investigating cardiovascular mortality, increased BMI has generally been associated with increased risk,^181,^ ^182^ but it is less clear at what BMI risk begins. In the most recent IPD meta-analysis, the HR per 5 kg/m^2^ higher BMI among those with a BMI greater than 25.0 kg/m^2^ was 1.42 for CHD and stroke mortality.^181^ Similarly, another IPD meta-analysis of 57 prospective studies found that for those with BMIs above 25 kg/m^2^, each 5 kg/m^2^ higher BMI was associated with about 40 percent higher risk of IHD and stroke mortality.^182^ Applying conversions to determine the impact of a BMI change comparable to that found in our review, a BMI decrease of 0.3 kg/m^2^ was associated with an approximate 2 to 3 percent lower risk of all-cause mortality, IHD mortality, CHD, and fatal stroke, regardless of age, among adults with a BMI above 25 kg/m^2^.

For dietary outcomes, the impact of individual diet components is difficult to evaluate, as the totality of the diet is most important.^184^ One meta-analysis of 16 cohort studies found a 5 percent lower risk of all-cause mortality for an increment of one serving of fruit and vegetables per day,^185^ consistent with the findings of our review. A recent meta-analysis of 95 prospective cohort studies reported associations between 200 grams per day of fruit and vegetable intake and reduced risk of CVD and CHD (risk ratio [RR]=0.92), stroke (RR=0.84), and all-cause mortality (RR=0.90).^186^

The findings on intake of different types of dietary fats are less clear, although evidence suggests that a fat-modified diet may not assist with weight loss or decrease CVD and cancer mortalities.^162,^ ^187–189^ Evidence suggests that replacing 5 percent of energy from saturated fats with other types of fats or whole-grain carbohydrates is associated with health benefits,^190,^ ^191^ but not all researchers agree with this conclusion.^192–194^ Further, a 5 percent change is larger than the 2 percent difference in change that we found in this review.

There is a strong body of evidence showing substantial health benefits associated with physical activity, and current evidence suggests that there is no minimum threshold for benefits to occur.^195–197^ Recent evidence confirms that higher levels of physical activity are associated with a lower risk of both all-cause and CVD-related mortality.^198,^ ^199^ The greatest risk reductions in all-cause mortality are seen when comparing those classified in the second quarter for activity level compared with those in the lowest quarter, which are separated by approximately 5 minutes/day of moderate-to-vigorous physical activity (a value which is fairly equivalent to the between group difference of approximately 35 minutes/week we found in this review). The maximal risk reduction for all-cause mortality is seen at about 24 minutes/day of moderate-to-vigorous intensity physical activity.^199^

## Limitations of Our Approach

There are limitations of this review that arose from scoping and analytic decisions that should be acknowledged. First, this updated review represents only a subset of the literature focused on dietary and physical activity counseling. To avoid duplication of literature addressed in other reviews for the USPSTF, we excluded some related bodies of evidence, including studies focused on persons with known disease (e.g., coronary heart disease, diabetes, impaired fasting glucose, hypertension, dyslipidemia), trials focused on weight loss or weight loss maintenance, and trials focused on dietary or physical activity counseling to prevent or manage other health risks and conditions (e.g., falls, cognitive impairment, cancer).

Although we focused this review specifically on adults “without known CVD risk factors,” exceptionally few studies reported the underlying cardiovascular risk of the population. We excluded studies that explicitly enrolled participants based on known elevated blood pressure or hypertension, dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors. We did, however, include studies among adults who may otherwise be at increased risk for CVD due to being overweight or having obesity, family history, or suboptimal dietary or physical activity behavior at baseline. Despite these operational criteria, there was still some subjectivity in determining risk and deciding which review (or reviews) each trial best fit (i.e., the current review, which focused on adults not at high risk, and/or the separate review which focused on high-risk adults). Most of the studies included in this review represented an unselected population or persons selected based on suboptimal behaviors, but did not report baseline values of blood pressure, lipid levels, glucose levels, current smoking, or adiposity.

This review was limited to interventions that were conducted in primary care or those that we felt may be feasible to conduct in or refer from primary care. Defining what interventions are “feasible for” or “referable from” primary care, however, is an ongoing challenge as it applies to USPSTF-related behavioral counseling interventions.^200–204^ Only 24 of the included trials actually took place in a primary care setting or involved primary care staff in the delivery of the intervention. An additional 26 trials recruited participants through mailings or phone calls from their primary care office or health insurance provider, but the interventions themselves were delivered in a research setting, at home, or elsewhere and did not include primary care staff. The remaining 63 trials had no connection to the primary care setting; however, we judged them to be relevant to primary care given the nature of the intervention components (e.g., print material, telephone counseling, computer based) or interventionists (e.g., health educators, trained staff). Many of these latter studies recruited participants through community venues, including mass advertising or through existing convenience lists (e.g., existing research cohorts), and therefore may represent populations with higher levels of motivation to change their behaviors or participate in research. We excluded interventions delivered through worksites, churches, and other community organizations as well as interventions that focused on environmental and policy changes that may not be easily replicated or implemented solely through primary care. For readers interested in the evidence on these interventions, we refer to The Community Guide^205^ and the National Cancer Institute’s Evidence-Based Cancer Control Programs.^206^

Additionally, our review focused on counseling to improve dietary and activity habits and did not review the evidence on the observational relationship between certain dietary patterns or physical activity levels and health outcomes. The Scientific Report of the 2015 Dietary Guidelines Advisory Committee^207^ and the World Health Organization’s Guidelines on Physical Activity and Sedentary Behaviour^197^ provide thorough reviews of this evidence. Furthermore, our review excluded observational studies examining whether the introduction of physical activity as a vital sign within health systems’ electronic medical records increases the documentation of exercise behaviors and referrals for lifestyle-related counseling (e.g., Grant et al.^208^).

With complex interventions such as those included here, describing and synthesizing intervention characteristics is difficult. The included interventions varied considerably in terms of the nature of the advice, mode of delivery, and delivery schedule. We diligently abstracted as much detail as possible about each intervention, used an established taxonomy for describing the behavior change techniques used in the interventions,^38,^ ^209^ and carefully summarized this detail in tabular and narrative format. We used consistent rules for estimating the total minutes of contact (i.e., intensity) across studies and used our established^3,^ ^5^ cutpoints to categorize each intervention arm as low intensity (≤30 minutes), medium intensity (31 to 360 minutes), or high intensity (>360 minutes). Despite this consistency, the rules are still somewhat arbitrary, and many medium-intensity interventions were quite intensive in terms of participant contact (e.g., nearly 5 hours of participation). Furthermore, in many cases, detailed reporting of the number and length of sessions was lacking, so we had to make several assumptions.

Finally, our meta-analyses pooled a body of literature that was heterogeneous with respect to clinical and demographic characteristics, interventions, and settings. For most outcomes, the statistical heterogeneity was unimportant (I^2^<40%) or moderate (I^2^=30% to 60%) and therefore still reasonable to allow for interpreting of pooled estimates. However, given the clinical heterogeneity, looking at the confidence intervals for each point estimate helps us to understand the true magnitude of effects on the individual outcomes. There was considerable heterogeneity (I^2^>90%) in the meta-analyses of adiposity and dietary outcomes, which is consistent with both the clinical variability of included populations and the variability in interventions among the included studies as well as the continuous nature of the data. Nevertheless, the high statistical heterogeneity may indicate that the pooled average effect of the interventions should be interpreted with caution. Studies were also limited to the English language.

## Limitations of the Studies and Future Research Needs

Several limitations related to this evidence base should be noted which point to important research needs.

First, few studies were included that reported measures of intermediate cardiometabolic outcomes, and even fewer were included that reported longer term health outcomes. As the prevalence and rate of these health outcomes are lower in lower risk groups (by definition), these studies require larger sample sizes and longer followup to observe an effect of an intervention in a low-risk group of participants.^201^ Without this, enhanced methods for using observational data to understand the effect of small differences in behavioral and intermediate outcomes on long-term health outcomes are needed. Additionally, future research should consistently measure and report quality of life and other related patient-centered outcomes.

Second, very few of the included trials explored whether effectiveness of the interventions varied among important subpopulations. Such analyses could assist in identifying groups of adults who might benefit more from behavioral interventions and help reduce the disparities that exist related to cardiovascular-related health. Furthermore, given this review’s focus on adults without known cardiovascular risk, it would be extremely helpful if all publications included a more robust description of the characteristics of the participants included in the trials, particularly related to underlying CVD risk factors.

Third, given that behavioral outcomes were the primary outcomes in almost all the included studies, there is a crucial need for better standardization related to the collection and reporting of these outcomes. Our call for this need is not something new or unique.^201^ In this review, there was extensive variability in the instruments used to measure dietary intake and physical activity, and even more variation in the specific outcomes and unit of measurement used to present results. Dietary intake was generally measured by food frequency questionnaires, entries in food diaries, or 24-hour food recalls. Very few studies used a dietary patterns approach for measuring, analyzing, or reporting results and rather reported results related to independent dietary components (e.g., saturated fat). A dietary pattern approach reflects that a composite of foods and beverages is more likely to influence health or chronic disease than will any single food or nutrient.^184^ Including index-based dietary pattern measurement (i.e., a dietary index), using scores such as the Healthy Eating Index (HEI), the alternate Healthy Eating Index, or the Dietary Approaches to Stop Hypertension (DASH) score, is strongly encouraged in future intervention research aiming to change dietary habits of participants.^210^ A distinct advantage of using these structured indices is the comparability of study findings. Similarly, while we understand that physical activity researchers must fit the specific measurement instruments and summary variables to the needs of their particular study aims, research protocols, and sample characteristics, we encourage investigators and publishers to strive for more uniformity in the outcomes required to be reported to measure physical activity benefit. Setting clear thresholds for benefit, such as achieving 150 minutes/week of MVPA or a certain counts per minute for accelerometer data (e.g., ≥1952 counts per minute), and dichotomizing participants as having achieved that threshold or not would also be helpful.

Finally, given the overwhelming evidence that greater time spent in sedentary behavior is independently associated with all-cause and CVD mortality^199^ and clear guidance on limiting the amount of time spent being sedentary,^197^ there is an urgent need for trials evaluating interventions designed to reduce sedentary behaviors. Most of the research in this area to date has taken place in workplace settings, a setting where high levels of sitting (while at a desk or driving, for instance) takes place.^211^ Given the recent increase in the number of workers now working from home,^212^ it is even more imperative to evaluate interventions designed to reduce prolonged sitting, including their impact on important health outcomes. A handful of studies have tested the feasibility and acceptability of interventions to reduce sitting time using activity monitors in non-workplace settings in nonrandomized or short-term studies (for example, the I-STAND intervention^213^). Replication of these interventions in RCTs with followup of at least 6 months is encouraged.

We searched ClinicalTrials.gov to identify any ongoing trials of relevance that might contribute to this body of evidence in the future. We identified nine trials, only two of which are being conducted in United States, currently under way that address interventions to prevent CVD (Appendix I). It is not clear, however, what the underlying CVD risk of the included samples are and to what extent they may contribute to this evidence base.

## Conclusions

The results of this systematic review update are consistent with the 2017 review on this topic. Healthy diet and physical activity behavioral interventions for persons without a known risk of CVD were associated with very small but statistically significant benefits across a variety of important intermediate health outcomes and small-to-moderate effects on dietary and physical activity behaviors. Very limited evidence exists regarding the health outcomes or harmful effects of these interventions.