# Chapter 3 Results

## Description of Included Studies

Our literature search yielded 7,485 unique citations. From these, we provisionally accepted 411 articles for review based on titles and abstracts (Appendix A Figure 1). After reviewing the full-text articles and performing critical appraisal, we included 113 studies^46–158^ that were reported in 204 publications. Appendix B contains a full list of the 204 included articles. We carried forward 80 studies from the prior review; 33 new studies were added.

For the 411 articles that were reviewed in full, the most common reasons for exclusion were: relevant outcome (k=224), not an included study design (i.e., not an RCT; k=67), not a relevant study aim (k=31), or not an included population (i.e., studies were among adults at high risk for CVD, who had CVD, or who had other known chronic disease; k=28). Appendix C contains a list of all excluded trials and reasons for their exclusion.

Of the 113 included studies, 15 trials reported health outcomes (KQ 1) (e.g., CVD events, self-reported quality of life), 43 trials reported intermediate health outcomes (KQ 2) (e.g., lipid, blood pressure, and glucose levels; weight measures), and 109 trials reported behavioral outcomes (KQ 3) (objective or self-reported measures of diet, physical activity, or sedentary time). Twenty-three trials explicitly reported on harms (or the lack thereof) of a counseling intervention (KQ 4).

A summary of the study and population characteristics across all studies can be found in Table 3. Details of each included study, by author, can be found in Appendix D Table 1.

Table 3 Summary of Study and Population Characteristics of All Included Trials

Characteristics (No. RCTs reporting) | All studies
Characteristics (No. RCTs reporting) | No. RCTs | %
All studies | 113 | 100
Key questions
KQ1. Health outcomes | 15 | 13.3
KQ2. Intermediate outcomes | 43 | 38.0
KQ3. Behavioral outcomes | 109 | 96.5
KQ4. Harms | 23 | 20.4
Study design
RCT | 93 | 82.3
Cluster RCT | 20 | 17.7
New study | 33 | 29.2
Good quality rating | 23 | 20.4
Conducted in the US | 60 | 53.1
Median sample size (IQR) | 314 (200–710) | Range: 32–48,835
Median % followup at 12 months or closest (IQR) | 86 (77–91) | Range: 38–100
Population selection^*^
Unselected | 53 | 46.9
Suboptimal behavior | 46 | 40.7
Elevated risk | 14 | 12.4
Recruitment setting
Primary care | 37 | 32.7
Community volunteer | 23 | 20.4
Direct mailing | 15 | 13.3
Mixed | 20 | 17.7
Other | 17 | 15.0
Not reported | 1 | 0.9
| Weighted mean or percent | SD or k/K
Age; Mean (k=105) | 54.1 | 11.9
% of trials restricted to older adults (minimum age ≥60) | 13.3 | 15/113
Female; % (k=113)^†^ | 79.9 | 20.2
Current smokers; % (k=41) | 10.1 | 7.1
BMI; Mean kg/m^2^ (k=79) | 27.8 | 2.0
% of trials restricted to persons with excess weight | 9.7 | 11/113
% of trials majority Hispanic or non-white^‡^,^§,**^ | 33.3 | 20/60
% of trials targeted low socioeconomic status population^††^ | 12.4 | 14/113

* According to trial eligibility criteria. “Unselected” includes a general population sample representing “all comers” or those recruited based on a sociodemographic characteristic alone. “Suboptimal behavior” includes samples selected because they were not meeting specific thresholds for dietary or physical activity behaviors. “Elevated risk” includes samples that were selected because they may have elevated risk for CVD based on family history, personal history (e.g., gestational diabetes), or being overweight or having obesity. Trials limited to those with CVD risk factors (e.g., elevated blood pressure, dyslipidemia or elevated lipid levels, impaired fasting glucose or impaired glucose tolerance, or multiple risk factors) were excluded.

† 26 trials were limited to women.

‡ 13 trials were limited to Hispanic or non-white persons.

§ Limited to trials in the US (60 trials).

** Where >50% of sample was non-white or Hispanic; assumed majority white, non-Hispanic if race/ethnicity not reported

†† Study described targeting a low-resource community or recruitment resulted in a sample with high unemployment, low educational attainment, or very low income.

Abbreviations: IQR=Interquartile range; k=number of trials with the stated characteristics; K=total number of trials in the analysis; No.=Number; RCT=randomized clinical trial; SD=standard deviation; US=United States.

### Study Characteristics

All the included studies were RCTs—20 were cluster RCTs with randomization occurring at the physician, clinic, health care center, town, or household level.^50–52,^ ^55,^ ^62,^ ^72,^ ^78,^ ^85,^ ^89,^ ^96,^ ^97,^ ^103,^ ^110,^ ^128,^ ^133,^ ^134,^ ^144,^ ^146,^ ^148,^ ^157^ The majority of the trials (60 trials) took place in the United States. The remaining trials were conducted in Europe (31 trials), Australia (11 trials), New Zealand (4 trials), Canada (5 trials), Puerto Rico (1 trial), and Japan (1trial). Samples sizes for the included trials ranged from 32 to 48,835 participants, and the median sample size was 314. We required that included trials report followup data at a minimum of 6-months; more than half of the trials (k=63) reported outcomes at 12 months or greater. Only six trials reported longer term outcomes at 3 or more years.^106,^ ^136,^ ^142,^ ^155,^ ^159,^ ^160^ Fewer than half of the studies were conducted within or recruited participants from primary care or the broader health care system (51 trials). The remaining studies recruited community volunteers through mass media, targeted recruitment, or larger population-based cohorts (e.g., registered voters, research cohorts).

### Included Populations

Trials included a wide range of populations in terms of age, sociodemographic features, and clinical characteristics. The mean age of the samples ranged from 18.5 to 79.5 years (interquartile range, 39.7 to 55.4 years). Fifteen trials specifically targeted adults age 60 years or older; the mean age in those trials ranged from 65.8 to 79.5 years.^54,^ ^79,^ ^80,^ ^83,^ ^99,^ ^100,^ ^103,^ ^108,^ ^115,^ ^132,^ ^139,^ ^141,^ ^145,^ ^148,^ ^150^ Most of the studies (73 trials) included both men and women, but one study was limited to men only (specifically Hispanic men)^156^ and 26 studies were limited to women only.^46,^ ^48,^ ^56–58,^ ^61,^ ^62,^ ^64,^ ^65,^ ^69,^ ^73,^ ^77,^ ^86,^ ^91,^ ^95,^ ^117,^ ^120,^ ^121,^ ^127,^ ^130,^ ^136,^ ^137,^ ^140,^ ^142,^ ^144,^ ^149^ Most of the studies limited to women were further restricted to specific racial/ethnic groups (e.g., American Indian,^140^ Chinese,^56^ Hispanic,^46,^ ^48,^ ^61,^ ^121,^ ^130^ Black^77^), age groups (college age),^144,^ ^149^ to women with postpartum status^136,^ ^142^ and to women who were mothers of young children.^48,^ ^56,^ ^73,^ ^91^ Among the 69 studies that reported the race/ethnicity of the sample, in only 17 of these studies was more than two thirds of the sample nonwhite. This included 13 trials that were limited to racial or ethnic minority groups including: Hispanic (8 trials), Black (1 trial), South Asian (1 trial), Chinese (1 trial), American Indian (1 trial) and immigrant Hispanic, Somali, and Sudanese families (1 trial). For studies that reported the education level of participants, the proportion of participants with more than a high school education (i.e., some college, vocational or technical school, or more) ranged considerably from 12.6 to 100 percent.

Among the 113 trials, 46 studies limited inclusion to persons with suboptimal levels of physical activity (e.g., <150 minutes of moderate- to vigorous-intensity physical activity per week), inadequate dietary habits (e.g., suboptimal intake of fruits, vegetables, red and processed meats, whole-fat dairy foods, or whole grains), or both. Fourteen of the 113 trials were specifically among persons at higher risk for CVD (but without levels of traditional CVD risk factors reaching diagnostic thresholds), including those with a family history of type 2 diabetes^81,^ ^114,^ ^143^ or CVD;^126^ women who were overweight or had obesity and a history of gestational diabetes^137^; and those who were overweight or had obesity.^46,^ ^49,^ ^52,^ ^56,^ ^57,^ ^77,^ ^94,^ ^108,^ ^153^

In the remaining 53 studies, participants represented a general, unselected population (i.e., were not selected based on baseline behavior, cardiovascular risk, or specific sociodemographic group). While we excluded trials conducted exclusively among persons with elevated blood pressure, dyslipidemia, or impaired fasting glucose, a few of the studies reported and included some participants with hypertension (2.8% to 70.7% of participants), dyslipidemia (11.3% to 33.8%), impaired fasting glucose (13.0% to 21.0%), or diabetes (4.2% to 27.8%). Of the 79 studies that reported baseline mean body mass index (BMI), the range was 22.4 to 38.3 kg/m^2^ (mean, 27.8 kg/m^2^). The mean BMI was in the overweight range (25.0 to 29.9 kg/m^2^) in nearly half of the studies (k=54) and in the obese range (≥30 kg/m^2^) in 18 studies. The proportion of current smokers included in the studies ranged from 1.9 to 39.1 percent in the few studies that reported it.

### Included Interventions

Within the 113 trials there were 157 distinct intervention arms included (some trials included more than one active intervention arm). A summary of the interventions can be found in Table 4. Detailed intervention characteristics for each trial can be found in Appendix E Tables 1, 2 and 3. Fifty-one intervention groups (32.5%) focused on both healthy diet and physical activity, 30 groups (19.1%) focused on healthy diet only, and 76 groups (48.1%) focused on physical activity. Most of the newly added trials (published from 2016 to the present) focused on improving diet and physical activity (14 of 33 new trials) or just physical activity (14 of 33 new trials). Only five of the new trials focused on improving diet alone.

Table 4 Summary of Intervention Characteristics of All Included Trials (113 Trials, 157 Intervention Groups Studies), Overall and by Intervention Intensity

Characteristics | All interventions (157 groups) | | High contact interventions (>6 hrs) (31 groups) | | Medium contact interventions (31 min-6 hrs) (79 groups) | | Low contact interventions (≤30 min) (47 groups)
| No. | % | No. | % | No. | % | No. | %
Behavioral target
Diet and physical activity | 51 | 32.5 | 16 | 51.6 | 25 | 31.6 | 10 | 21.3
Diet only | 30 | 19.1 | 9 | 29.0 | 11 | 13.9 | 10 | 21.3
Physical activity only | 76 | 48.1 | 6 | 19.4 | 43 | 54.4 | 27 | 57.4
Intensity level *
Low (0-30 min) | 47 | 29.9
Medium (31 min-6 hrs) | 79 | 50.3
High (>6 hrs) | 31 | 19.8
Primary care clinician involvement ^†^
Delivered all/most | 11 | 7.3 | 1 | 3.2 | 7 | 8.9 | 3 | 6.4
1-time brief message | 8 | 5.3 | 0 | 0 | 5 | 6.3 | 3 | 6.4
No involvement | 131 | 87.3 | 29 | 93.5 | 64 | 81.0 | 38 | 80.8
Intervention format ^‡^
Individual sessions, in-person | 71 | 45.2 | 19 | 61.3 | 46 | 58.2 | 6 | 12.8
Group sessions, in-person | 26 | 16.6 | 16 | 51.6 | 10 | 2.7 | 0 | 0
Telephone calls | 52 | 33.1 | 15 | 48.4 | 35 | 44.3 | 2 | 4.3
Technology-based^§^ | 54 | 34.4 | 7 | 22.6 | 32 | 40.5 | 15 | 31.9
Print materials | 84 | 53.5 | 14 | 45.2 | 36 | 45.6 | 34 | 72.3
Print materials only | 24 | 15.3 | 0 | 0 | 0 | 0 | 24 | 51.1
Behavior change technique ^‡^
Goals and planning | 132 | 84.1 | 26 | 83.9 | 71 | 89.9 | 35 | 74.5
Feedback and monitoring | 100 | 63.7 | 22 | 71.0 | 52 | 65.8 | 26 | 55.3
Social support | 49 | 31.2 | 14 | 45.2 | 26 | 32.9 | 9 | 19.2
Comparison of outcomes | 58 | 36.9 | 12 | 38.7 | 30 | 38.0 | 16 | 34.0
Self-belief | 77 | 49.0 | 14 | 45.2 | 46 | 58.2 | 17 | 36.2
Motivational interviewing | 20 | 12.7 | 4 | 12.9 | 14 | 17.7 | 2 | 4.3
5 A’s | 6 | 3.8 | 0 | 0 | 4 | 5.1 | 2 | 4.3
Dietary recommendation **
General heart healthy, or not described | 105 | 66.9 | 14 | 45.2 | 61 | 77.2 | 30 | 63.8
Low sodium | 5 | 3.2 | 2 | 6.4 | 0 | 0 | 3 | 6.4
Fruit and vegetable intake | 55 | 35.0 | 18 | 58.1 | 20 | 25.3 | 17 | 36.2
Fat intake | 33 | 21.0 | 12 | 38.7 | 12 | 15.2 | 9 | 19.2
Focus on weight gain prevention | 12 | 7.6 | 6 | 19.4 | 6 | 7.6 | 0 | 0
Intervention Contact | Median (IQR) | Range | Median (IQR) | Range | Median (IQR) | Range | Median (IQR) | Range
Intervention duration, months | 6 3 – 12) | 0 – 72 | 12 (6 – 24) | 1 - 72 | 6 (3 – 9) | 0 - 24 | 6 (2 – 6) | 0 – 36
Est. contact hours^**^ | 2.7 (1 – 5.9) | 0 – 38.5 | 10 (7 – 18) | 6.3 – 38.5 | 2.3 (1.3 – 3.1) | 0.7 – 5.9 | 0.3 (0.1 – 0.4) | 0 – 0.5
Number of contacts^††^ | 7 (3 – 16) | 1 - 168 | 18 (15 – 25) | 5 - 106 | 5 (3 – 8) | 1 - 168 | 2 (1 – 4) | 1 - 32
Number of in-person contacts | 1 (0 – 2) | 0 – 39 | 8 (1 – 16) | 0 - 39 | 1 (0 – 2) | 0 - 6 | 0 (0 – 0) | 0 - 1
Control group (113 trials) | No. of trials | % of trials | No. of trials | % of trials | No. of trials | % of trials | No. of trials | % of trials
No intervention/waitlist | 34 | 30.1 | 10 | 41.7 | 16 | 25.4 | 8 | 30.8
Usual care | 21 | 18.6 | 4 | 16.7 | 10 | 15.9 | 7 | 26.9
Minimal intervention | 34 | 30.1 | 7 | 29.2 | 24 | 38.1 | 3 | 11.5
Attention control | 24 | 21.2 | 3 | 12.5 | 13 | 20.6 | 8 | 30.8

* Contacts involving in-person or telephone-based sessions with an interventionist, web- or computer-based sessions, e-mails, and text messages. Contact time was estimated when not provided (individual counseling session=30 minutes, group counseling session=60 minutes, telephone session=15 minutes, computer-based session=15-30 minutes, e-mails=1-2 minutes, text messages ≤1 minute.

† Seven intervention groups did not report if primary care clinician was involved.

‡ Intervention could include more than one delivery format and behavior change technique.

§ Includes computer- or web-based sessions, e-mails, or text/SMS messages.

** Interventions may advocate multiple diet approaches (e.g., low sodium and low fat).

†† Includes all in-person, telephone, computer, e-mail, and text message contacts. Does not include print materials.

Abbreviations: 5A’s=5A’s intervention strategy (Ask, Advise, Assess, Assist, and Arrange); Est.=Estimated; Hrs=hours; IQR=Interquartile range; No.=Number; SD=Standard deviation; US=United States.

The mode of delivery of the interventions was highly variable. Most of the interventions (83/157, 52.9%), included at least one face-to-face counseling session with an interventionist, either individually or in groups. There were typically 5 sessions or fewer (median: 2, range 1-39), with individual sessions taking approximately 30–60 minutes per session and group sessions lasting 60-120 minutes per session on average. Many of the in-person counseling interventions also included booster telephone calls, emails, or text messages.

Another substantial proportion of the interventions (67/157 groups, 42.7%) were delivered completely remotely—either through technology only (i.e., web-, computer-, or text message-based) (24 groups in 14 trials), mailed print materials only (24 intervention groups in 16 trials), telephone calls only (four intervention groups in four trials), or a combination of print materials, telephone calls, and/or web-based activities (16 groups in 15 trials). Six additional interventions (in three trials, 6/157, 3.8%) took place in-person and had participants complete computer-based sessions in a computer lab or research setting but included no face-to-face counseling with an interventionist.

We estimated the “intensity” of the included interventions based on the number of contacts and contact time with an interventionist (in person or over the phone) or during interactive technology-based sessions. Thirty-one (19.8%) of the interventions offered high-contact interventions—that is, over 6 hours of contact time over the course of the full intervention. Seventy-nine (50.3%) offered medium-contact interventions, or an estimated 31 minutes to 6 hours of contact, and 47 (29.9%) were low-contact interventions with 30 minutes of less of contact. The median (interquartile range [IQR]) number of contacts was 7 (3 to 16). The duration of the interventions ranged from 1 day to 8.5 years, with most interventions taking place for 6 months or less (median, 6 months [IQR, 3 to 12 months]).

Figure 2 shows the distribution of intervention groups by contact time and by intervention focus. Most of the interventions that included messages about both healthy diet and physical activity were considered to have high- or medium-contact (41 out of 51 groups), whereas the physical activity only interventions were rarely high intensity (i.e., over 6 hours of contact time). Interventions that included counseling on healthy diet only were evenly distributed in terms of the amount of total intervention time.

Figure 2 Distribution of Intervention Arms by Contact Time and Focus

* Intervention contact time defined as: Low: 0-30 min, Medium: 31-360 min, High: >360 min.

Abbreviations: HD=healthy diet only; HD + PA=healthy diet and physical activity; min=minutes; PA=physical activity only.

Figure 2 is a distribution of intervention arms by contact time (minutes) and intervention focus. The contact time is also depicted in three categories: 0 to 30 minutes (low), 31 to 360 minutes (medium), and >360 minutes (high).

The interventionists varied among the studies and included health educators, health coaches, behavioral health specialists, exercise specialists, nutritionists, registered dieticians, and study staff trained in behavior change and lifestyle coaching. Very few interventions (17/157, 10.8%) involved primary care clinicians in delivering all or part of the intervention.^50,^ ^54,^ ^72,^ ^76,^ ^78,^ ^89,^ ^93,^ ^94,^ ^96–98,^ ^103,^ ^108,^ ^110,^ ^126,^ ^128,^ ^132,^ ^135,^ ^148^ Two of the interventions specifically focused on training primary care physicians on how to counsel patients on healthy lifestyle topics.^110,^ ^148^ Community health workers or promotoras were the primary interventionist in four trials that included group sessions or home visits.^46,^ ^48,^ ^140,^ ^152^

Similar messages were used across all the interventions (Appendix E Table 2 and Table 3). Diet messages typically focused on general heart-healthy eating patterns, including increased fruit and vegetable intake (specifically 5 to 9 servings/day), decreased fat consumption and salt intake, and increased fiber consumption; fewer mentioned specific messages about increasing intake of whole grains, reducing consumption of red and processed meats, or decreasing intake of sugar-sweetened beverages. The largest trial, the Women’s Health Initiative Dietary Modification Trial (WHI-DMT) (n=48,835), delivered one of the most intense interventions consisting of 18 group sessions in the first year followed by quarterly sessions over a median of 8.5 years, and focused on a 20-percent low-fat dietary pattern with goals of 5 or more daily servings of fruits and vegetables and 6 or more daily servings of grains.^142^

Physical activity messages emphasized gradually increasing aerobic activities to recommended levels (i.e., 150 minutes of moderate-intensity physical activity per week), with many interventions emphasizing walking. Eight trials included specific messages about decreasing sedentary behavior (e.g., reducing television viewing, substituting sitting with standing).^54–56,^ ^59,^ ^66,^ ^71,^ ^87,^ ^151^ Nine trials focused on weight gain prevention or included intervention strategies designed to help those who were overweight to lose weight.^56,^ ^57,^ ^62,^ ^65,^ ^68,^ ^77,^ ^133,^ ^154,^ ^155^

Many interventions provided educational counseling related to reading food labels; planning, purchasing, and preparing foods and meals; finding local physical activity opportunities; and overcoming barriers related to desired behavior changes. Optional activities included group exercise classes, free memberships to community exercise facilities, weight loss materials or courses, grocery shopping trips with a dietitian, and cooking demonstrations. Additionally, many interventions included tangible tools to facilitate behavior change, such as pedometers and diaries or apps for self-monitoring. Almost all the interventions distributed print materials to participants; some materials were standard educational information only, while others were tailored with normative or motivational feedback.

Of those trials that reported the theoretical basis of the intervention, the majority were based on principles of the transtheoretical model (i.e., stages of change), social cognitive theory, or both (Appendix E Table 3). As such, most interventions included behavior change techniques focused on the broad areas of goals and planning, monitoring and feedback (e.g., using food logs, dietary analysis with feedback, pedometers, activity logs, and web-based applications), increasing efficacy and motivation for healthy eating or physical activity, improving social support, and general education and advice regarding the benefits of specific behavioral changes. Seventeen trials (20 intervention arms) specifically mentioned using principles of motivational interviewing^47,^ ^49,^ ^60,^ ^62,^ ^67,^ ^71,^ ^73,^ ^75,^ ^77,^ ^108,^ ^110,^ ^111,^ ^115,^ ^145,^ ^152,^ ^156,^ ^158^ and six trials based their counseling, at least in part, on the “5 A’s” model (assess, advise, agree, assist, and arrange).^72,^ ^90,^ ^96,^ ^107,^ ^108,^ ^126^

#### Intervention Fidelity and Participant Adherence

Adherence to the interventions was variable and reporting of adherence was very heterogeneous (Appendix E Table 2). Overall, however, the rates of participation appeared generally high, particularly for those with less total contact time. In most cases, typically more than 80 percent of participants reported reading most of the print materials provided, taking part in all or most face-to-face individual counseling sessions, or participating in most or all planned counseling telephone calls or web-based activities. There did not appear to be any differences in the level of adherence between the healthy diet and physical activity versus healthy diet-only or physical activity-only interventions. Adherence to the interventions with higher contact time or longer duration, especially the group-based interventions, was slightly lower than adherence to those with less planned contact.

#### Control Arms

Within the 113 trials, nearly half of them (55/113, 48.7%) used a no-intervention (18 trials), waitlist (16 trials), or usual care (21 trials) control group. Usual care was typically described as “routine” or “standard” care that included standard heart healthy prevention messages, generic print materials, or was otherwise not described. One new trial acknowledged a community-wide campaign focused on heart health that was occurring during the trial which both intervention and control groups could have been exposed to.^152^ The remaining studies had a minimal intervention (34 trials) or attention control (24 trials) comparator.

Minimal intervention groups were variable, including generic print materials or standard internet resources regarding the benefits of healthy diet and/or physical activity, non-personalized in-person or web-based educational sessions, and tailored or self-help programs. A few of the minimal intervention groups provided participants with pedometers or tailored walking maps and encouraged self-monitoring of activity. In all cases, minimal intervention control groups were less intensive than interventions categorized as low contact interventions. The attention control groups usually followed the same intervention schedule as the study’s intervention group but focused on a different health topic (e.g., stress management, general health and wellness, women’s health). By design, we excluded trials with control groups where participants were specifically asked not to change their diet or physical activity habits.

### Study Quality

We rated 23 of the 113 trials as good-quality and the remaining 90 as fair-quality. Twenty trials were excluded for poor quality (Appendix C). Common threats to internal validity of these poor-quality studies included very high attrition (generally >40%), with differential attrition between intervention arms (>20%); lack of baseline comparability between groups without adjustment; and issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, questionable validity of randomization and allocation concealment procedures). In general, the 23 trials rated as good-quality were characterized by appropriate randomization procedures; comparable groups at baseline (or adequate adjustment for known baseline differences in the analysis); high followup rate (i.e., ≥85% retention at 6 months); the use of reliable and valid measurement instruments applied equally across arms and blinding of outcome assessors for nonobjective measures; well-described interventions with high implementation fidelity; no evidence of selective reporting; and appropriate analyses, including intention-to-treat principles using multiple imputation or other conservative data imputation procedures for missing data. Some common limitations of the fair-quality studies included lack of reporting details about allocation concealment, small differences in baseline characteristics between treatment arms, no or unclear blinding for outcomes assessment (particularly for interviewer-administered questionnaires), relatively higher attrition (i.e., >20%) and differential attrition between groups, and no attempt (or lack of reporting) to account for missing data.

## KQ 1 Do Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior Improve Health Outcomes in Adults?

### Summary of Results

Fifteen of the 113 included trials reported health outcomes (15/113, 13.3%; n=58,286). Six of these trials were identified as part of this update. Three trials reported all-cause or CVD related mortality, as well as CVD events such as myocardial infarction (MI) or stroke. The three trials included the very large Women’s Health Initiative Dietary Modification Trial (WHI-DMT) that tested the effects of a high-intensity low-fat dietary group counseling intervention among postmenopausal women (n=47,179 without a history of CVD)^142^ and the PACE-UP and PACE-Lift physical activity trials by Harris and colleagues (n=1,203 participants without a previous CVD diagnosis).^50,^ ^103^ Overall, few deaths and nonfatal events were reported across the three trials, and few differences were observed between treatment and control groups over 1 to 13 years of followup. When data from both the PACE-UP and PACE-Lift trials were combined, a statistically significant intervention effect was seen for both nonfatal CVD events as well as nonfatal plus fatal CVD events.

Fifteen trials reported health-related quality of life outcomes, including eleven trials of physical activity interventions, three trials of mixed interventions that included both healthy diet and physical activity or sedentary behavior components, and the WHI dietary modification study. The included trials used a variety of measures to assess quality of life including the 12 or 36-item Short-Form Health Survey (SF-12; SF-36), the EuroQol-5 Dimensions or Visual Analogue Scales (EQ-5D; EQ-VAS), the World Health Organization Well-being Index (WHO-5), or study-developed measures. Few studies demonstrated statistically significant, nor clinically significant, changes in quality of life as a result of these interventions.

### Detailed Results by Outcome

#### CVD and Mortality

Three good-quality trials (n=48,382) (with relevant results in 7 publications) reported CVD-related health outcomes.^50,^ ^103,^ ^142,^ ^160–163^ Only one trial was newly identified for this update;^50^ longer-term data was published for both of the other trials in 2019 and is included in this summary.^160,^ ^161^ All three trials reported health outcomes among subsamples of participants without a history of CVD at enrollment, which is reported here. Overall, these trials reported relatively low event rates that in some cases suggested potential benefit of lifestyle interventions, with followup of up of 4 or 13.4 years (Appendix F Table 1).

In the WHI-DMT, postmenopausal women aged 50–79 years (mean=62.3 years) were randomized to either a very intense dietary counseling intervention – consisting of up to 8.5 years of group counseling—or a minimal intervention regarding healthy dietary habits.^142^ The trial included 47,179 women without a history of CVD (96.6% of the full sample). Intervention goals were to reduce fat intake from ∼35% to 20% of total energy, in conjunction with increasing vegetables and fruit to 5 servings/day and grains to 6 servings/day—goals which were achieved.

Total mortality was not statistically significantly different between intervention and control groups over a median cumulative followup of 8.5 years (hazard ratio [HR], 0.96 [95% CI, 0.88 to 1.04]) or 13.4 years (HR, 0.97 [95% CI, 0.94 to 1.01]) (Appendix F Table 1).^161^ Likewise, time-to-event analyses did not show significant differences between intervention and comparison groups for coronary heart disease (CHD, defined as nonfatal myocardial infarction plus CHD death), total stroke (ischemic plus hemorrhagic stroke), or total CVD events (CHD plus coronary artery bypass graft or percutaneous coronary intervention plus stroke), either over the intervention period (8.5 years) or over longer followup (13.4 years). The restriction to this baseline cohort of those without a history of CHD yielded results that were consistent with those for the full sample. In an analysis stratified by whether participants without prior CVD were normotensive (54%) or who had hypertension (46%) at enrollment, a significant reduction in CHD incidence occurred among baseline normotensive participants (HR, 0.70 [95% CI, 0.56 to 0.87]) whereas there was no evidence for an intervention effect among participants with hypertension at baseline, with a highly significant contrast between the two at both the end of the intervention period (p=0.003) and the full followup (p=0.003).^161^ This CHD benefit in healthy normotensive women was partially offset by an increase in stroke incidence (HR, 1.29 [95% CI, 1.00 to 1.66]), and more specifically, ischemic stroke incidence.^163^ There was some evidence of greater HR reductions among women who were classified as having obesity at baseline (38.2%), however these analyses were exploratory and all tests of interaction were not significant.^161^

The two other trials that reported health outcomes evaluated three different 12-week primary care pedometer-based walking interventions among adults (PACE-UP, n=1,023, age range, 45–75 years)^50^ and older adults (PACE-Lift, n=298, age range, 60–75 years),^103^ in the United Kingdom. The trials were similar in their recruitment of participants and intervention delivery, incorporating similar behavior change techniques and baseline characteristics (besides age and socioeconomic status [SES]) were similar within each trial. Both trials showed similar effects on changes in physical activity at up to 3 and 4 years of followup (i.e., ~30 minutes more of physical activity per week among intervention vs. control participants).^159^ Primary care data related to long-term health outcomes (at 1 year [end of the initial trial followup] and 4 years) was downloaded directly from the primary care practices that were randomized. Analyses related to CVD outcomes were recorded for those with and without preexisting CVD. Overall, 85 percent of PACE-UP and 69 percent of PACE-Lift participants had 4 years of complete data.^160^

Within both studies, event rates were low (≤10 per group) for all outcomes at 1 and 4 years (Appendix F Table 1).^160^ For nonfatal CVD events (MI, coronary artery bypass graft, angioplasty, transient ischemic attack, and stroke), in both trials, the proportion of events was lower in the intervention than in the control group at 4 years. When trial data were combined, there was a statistically significant intervention effect for nonfatal CVD events (HR, 0.27 [95% CI, 0.08 to 0.88], p=0.03). When fatal cardiovascular events were included and trial data were combined, results were similar (HR, 0.31 [95% CI, 0.11 to 0.93], p=0.04).^160^ The authors reported a number needed to treat (NNT) to show benefit from the intervention at 4 years, among those with no previous cardiac diagnosis, of 62 (95% CI, 50 to 386) (absolute risk reduction [ARR], 1.6 [95% CI, 0.3 to 2.0]) for nonfatal cardiovascular events and an NNT of 60 (95% CI, 46 to 562), ARR, 1.7 [95% CI, 0.2 to 2.2]) for total fatal and nonfatal CV events.^160^

#### Quality of Life

Fifteen fair- to good-quality trials (n=58,286) reported the effect of a healthy diet and/or physical activity intervention on quality of life, ten of which focused on physical activity only (Appendix F Table 2).^49,^ ^50,^ ^55,^ ^69,^ ^89,^ ^97,^ ^100,^ ^103,^ ^114,^ ^115,^ ^128,^ ^145,^ ^151,^ ^157,^ ^164^ Five trials were newly identified for this updated review.^49,^ ^50,^ ^55,^ ^69,^ ^151^ The SF-36 was used to measure quality of life in seven of the 14 trials;^89,^ ^97,^ ^100,^ ^114,^ ^115,^ ^128,^ ^164^ the SF-12,^69^ EQ-5D,^50,^ ^103,^ ^157^ EQ-VAS,^151^ WHO-5,^49^ or study developed measures^55,^ ^145^ were used in the remaining seven trials. For studies reporting results based on the SF-12 or SF-36, only those reporting results for the mental and physical component scores are included in the table. Six additional studies reported only individual subscales of the SF-36 and are not included in the table.^89,^ ^100,^ ^114,^ ^115,^ ^128,^ ^164^

While many studies showed trends toward improved quality of life, few studies demonstrated statistically significant differences between intervention and control groups (Appendix F Table 2). In most cases, very small improvements (e.g., less than a 1-point improvement on the SF-36 score) were seen in both intervention and control groups. Of the trials not included in the table, three trials reported statistically significant differences between groups on some, but not all subscales. One study reported that SF-36 measures of self-rated “general health,” “role physical,” “vitality,” and “bodily pain” improved significantly in the intervention group compared to the usual care group (p < .05).^89^ Likewise, another small trial reported small to moderate effect sizes ranging from 0.20 to 0.51 on several subscales of the SF-36, with intervention participants scoring better on six of the eight subscales.^114^ The WHI-DMT found that at 1 year women in the dietary modification group had small improvements on all of the subscales while women in the control group declined or stayed the same. These differences were statistically significant (p<0.001) for all of the scales except social functioning, depression symptoms, and role-emotional health.^164^ The remaining three studies reported either no differences between groups on SF-36 scores^115,^ ^128^ or significant worsening of SF-36 scores in both groups.^100^

## KQ 2 Do Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior Improve Intermediate Outcomes Associated With CVD in Adults?

### Summary of Results

Forty-three of the included trials (43/113, 38.1%; n=77,965) reported the effects of a behavioral intervention on at least one intermediate outcome at 6 months or more followup (Table 3). Fifteen of the 43 trials were newly identified as part of this update; the remaining 29 were included in our original review. Most of these 43 studies were of medium- or high-intensity interventions and focused on healthy diet, with or without physical activity components.

When results of these trials were pooled in meta-analyses, healthy diet and/or physical activity interventions were associated with small but statistically significant improvements in blood pressure, low-density lipoprotein (LDL) cholesterol, and all measures of adiposity compared with controls at 6 months or more (Table 5). Average intervention effects were between-group differences in mean change (MDs) of −0.80 mm Hg (95% CI, −1.30 to −0.31) for systolic blood pressure (SBP), −0.42 mm Hg (95% CI, −0.80 to −0.04) for diastolic blood pressure (DBP), −2.20 mg/dL (95% CI, −3.80 to −0.60) for LDL cholesterol—all in favor of intervention versus control arms. For adiposity outcomes, interventions were associated with improvements in BMI (MD, −0.32 kg/m^2^ [95% CI, −0.51 to −0.13]), weight (MD, −1.07 kg [95% CI, −1.62 to −0.52]), and waist circumference (MD, −0.81cm [95% CI, −1.32 to −0.30]), although there was considerable statistical heterogeneity in these analyses, so the average effect sizes should be interpreted with caution. There was no evidence of an association between healthy diet and/or physical activity counseling and total cholesterol levels, high-density lipoprotein (HDL) cholesterol, or fasting glucose, though the direction of effects generally favored the intervention.

Table 5 Pooled Results of Intermediate Outcomes

Outcome | Difference in Mean Changes (95% CI) | RCTs (n) | I^2^, %
SBP, mm Hg | −0.80 (−1.30 to −0.31) | 23 (57,079) | 11.3
DBP, mm Hg | −0.42 (−0.80 to −0.04) | 24 (57,148) | 35.8
Total cholesterol, mg/dL^*^ | −1.58 (−4.21 to 1.04) | 21 (10,122) | 68.8
Low-density lipoprotein cholesterol, mg/dL^*^ | −2.20 (−3.80 to −0.60) | 15 (6,350) | 25.7
High-density lipoprotein cholesterol, mg/dL^*^ | −0.12 (−1.04 to 0.80) | 17 (7,527) | 51.4
Fasting glucose, mg/dL^†^ | −0.34 (−1.24 to 0.55) | 14 (7,468) | 42.7
BMI, kg/m^2^ | −0.32 (−0.51 to −0.13) | 27 (59,239) | 94.6
Weight, kg^‡^ | −1.07 (−1.62 to −0.52) | 24 (51,812) | 91.2
Waist circumference, cm^§^ | −0.81 (−1.32 to −0.30) | 23 (52,128) | 96.1

* To convert mg/dL to mmol/L, multiply by 0.0259.

† To convert mg/dL to mmol/L, multiply by 0.0555.

‡ To convert kg to lbs, multiply by 2.205.

§ To convert cm to inches, multiply by 0.394.

Abbreviations: BMI=body mass index; BP=blood pressure; CI=confidence interval; cm=centimeter(s); DBP=diastolic blood pressure; dL=deciliter; I^2^=I squared (the percentage of total variation across studies that is due to heterogeneity rather than chance); kg=kilogram(s); L=liter; lb(s)=pound(s); m=meter(s); mg=milligram(s); min=minute(s); mmHg=millimeters of mercury; mmol=millimoles; RCT=randomized clinical trial; SBP=systolic blood pressure.

Among the intermediate outcomes showing a statistically significant positive association, dose-response effects were evident, with increasing intervention intensity associated with larger differences between groups in intermediate outcomes. High-intensity interventions (i.e., ≥6 hours of contact) were consistently associated with statistically significant benefit on intermediate outcomes, and the effect sizes were slightly higher in analyses limited to the subset of high-intensity interventions compared with the results of combining trials of all level of intensity.

Based on the Egger’s test^42^ and visual inspection of funnel plots, we found no evidence of small-study effects (an indicator of publication bias) for any of the intermediate outcomes.

### Detailed Results by Outcome

#### Blood Pressure

Twenty-four of the 113 included trials (21.2%) (n=66,249) reported the effects of interventions on a measure of blood pressure (Appendix G Table 1).^46,^ ^52,^ ^55,^ ^65,^ ^66,^ ^74,^ ^77,^ ^86,^ ^89,^ ^97,^ ^101,^ ^104,^ ^107,^ ^108,^ ^114,^ ^117,^ ^126,^ ^133,^ ^135,^ ^136,^ ^140–142,^ ^151^ By review design, trials that were limited to those with elevated blood pressure were excluded. The weighted mean blood pressure of participants across included studies was 124/76 mm Hg.

Individually, very few of the trials found statistically significant differences in changes in SBP or DBP between intervention and control groups. However, the pooled average difference between groups in blood pressure reductions showed statistically significant associations with mean differences of −0.80 mm Hg for SBP (95% CI, −1.30 to −0.31; 23 trials [n=57,079]; I^2^=11.3%) (Figure 3) and −0.42 mm Hg for DBP (95% CI, −0.80 to −0.04; 24 trials [n=57,148]; I^2^=35.8%) (Figure 4), respectively, at 6 to 18 months compared with controls (Table 5).

Figure 3 Pooled Analysis of Change in Systolic Blood Pressure (mm Hg) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CG=control group; CI=confidence interval; Diff=difference; HD=healthy diet; Hrs=hours; IG=intervention group; Mins=minutes; mm Hg=millimeters of mercury; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=Standard deviation; SBP=systolic blood pressure.

Figure 3 is a forest plot of the change in systolic blood pressure (mmHg) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

Figure 4 Pooled Analysis of Change in Diastolic Blood Pressure (mm Hg) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CI=confidence interval; DBP=diastolic blood pressure; Diff=difference; HD=healthy diet; Hrs=hours; IG=intervention group; CG=control group; mm Hg=millimeters of mercury; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 4 is a forest plot of the change in diastolic blood pressure (mmHg) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

Results of meta-regressions and subgroup analyses based on various study, population, and intervention characteristics showed that there were consistent intervention effects on SBP and DBP regardless of these varying characteristics. The largest between-group differences were seen for the 11 interventions with the highest intervention contact (MD for SBP, −1.05 [95% CI, −1.90 to −0.21] [Figure 3] and MD for DBP, −0.63 [95% CI, −0.76 to −0.50] [Figure 4]); however, the tests of subgroup differences (testing the differences between high-intensity vs. medium- or low-intensity interventions) were not statistically significant. Furthermore, meta-regression exploring the relationship between continuous measures of intervention contact (total minutes of intervention contact, minutes of in-person contact, and intervention duration) were not statistically significant. The other variables that were tested and found not be associated with effect size were: study quality (good vs. fair), country (US vs. other), primary care involvement (linked to primary care vs. not), population selection (unselected, suboptimal behavior, or other), intervention target (diet and physical activity, diet only, or physical activity only), and intervention delivery (remote only vs. not, and print only vs. not).

Exploratory sensitivity analyses removing the largest and most intense intervention—the WHI DMT among postmenopausal women (n=42,299)—resulted in mixed effects for SBP and DBP. That is, for SBP, the total variation in the effects due to heterogeneity (I^2^) increased (from 11% to 22%) and slightly increased the effect estimate (MD, −0.90 [95% CI, −1.60 to −0.20]; n=14,780) whereas the heterogeneity decreased in the pooled analysis for DBP (from 36% to 26%) and resulted in a difference in mean change that was no longer statistically significant (MD, −0.38 [95% CI −0.82 to 0.06]; n=14,854).

There was no consistent pattern in the effects of the interventions on blood pressure over time. Six studies reported additional measures of SBP and DBP after 12 months of followup.^52,^ ^77,^ ^117,^ ^136,^ ^140,^ ^142^ Mean between-group reductions in blood pressure remained consistent (and not statistically significant) in four of the trials after 1 to 1.5 years,^52,^ ^77,^ ^117,^ ^140^ whereas they attenuated and lost significance in two other long-term trials of 1.5^136^ and 6 years.^142^

Only three trials reported the prevalence or incidence of hypertension in addition to continuous measures of blood pressure.^66,^ ^74,^ ^142^ Two of the trials found no appreciable differences between the percent of participants with elevated or high blood pressure at 6 or 12 months.^66,^ ^74^ In the WHI-DMT, women in the intervention group had a 4 percent lower overall risk of developing incident hypertension than women in the control group (HR, 0.96 [95% CI, 0.93 to 0.99]) over 8 years of followup.^142^

#### Lipids

Twenty-one trials (21/113, 18.6%; n=12,026) reported at least one lipid measure, including LDL, total, or HDL cholesterol levels (Appendix G Table 2).^46,^ ^52,^ ^65,^ ^71,^ ^74,^ ^76,^ ^77,^ ^81,^ ^89,^ ^97,^ ^101,^ ^104,^ ^107,^ ^108,^ ^114,^ ^117,^ ^126,^ ^133,^ ^136,^ ^140,^ ^141^ Within the individual trials, very few found statistically significant differences in the mean change over time for any lipid outcome and the small sample sizes of each trial (most had n<350) resulted in wide confidence intervals. Baseline levels of cholesterol were generally optimal or near optimal among these samples: mean LDL and total cholesterol levels were 115 and 197 mg/dL, respectively.

All 21 trials were included in at least one meta-analysis of lipid outcomes. For LDL cholesterol, meta-analysis of 15 trials resulted in a statistically significant difference in mean change of −2.20 mg/dL (approximately 0.057 mmol/L) at 6 to 18 months of followup (95% CI, −3.80 to −0.60; n=6,350; I^2^=25.7%) (Figure 5). When stratified by intervention intensity, this decrease was significant only among the eight high-intensity interventions, with an average effect of −3.88 mg/dL (95% CI, −6.15 to −1.61); results from meta-regression confirmed a statistically significant dose-response effect with more benefit seen as intensity increased (p=0.014). Similarly, a dose-response effect was seen with greater effect sizes associated with increasing duration of the intervention (p=0.002), the number of total intervention sessions (p=0.027), and the number of in-person sessions (p=0.003). The effect of the interventions on LDL was not associated with any other study or population characteristic that was explored.

Figure 5 Pooled Analysis of Change in Low-Density Lipoprotein Cholesterol (mg/dL) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CI=confidence interval; Diff=difference; HD=healthy diet; Hrs=hours; IG=intervention group; CG=control group; LDL-C=low-density lipoprotein cholesterol; mg/dL=milligrams per deciliter; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 5 is a forest plot of the change in low-density lipoprotein cholesterol (mg/dL) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

There was no evidence of an association between healthy diet and/or physical activity interventions and levels of total cholesterol (Figure 6) or HDL cholesterol (Figure 7) in pooled analyses. Mean between-group differences in change in total cholesterol levels were inconsistent across trials, ranging from absolute differences of 14.7 mg/dL in favor of the intervention groups to 14.7 mg/dL in favor of the control group at 6 months to 2 years of followup.

Figure 6 Pooled Analysis of Change in Total Cholesterol (mg/dL) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CI=confidence interval; Diff=difference; HD=healthy diet; Hrs=hours; IG=intervention group; CG=control group; mg/dL=milligrams per deciliter; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation; TC=total cholesterol.

Figure 6 is a forest plot of the change in total cholesterol (mg/dL) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

Figure 7 Pooled Analysis of Change in High-Density Lipoprotein Cholesterol (mg/dL) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CI=confidence interval; Diff=difference; HD=healthy diet; HDL-C=high-density lipoprotein cholesterol; Hrs=hours; IG=intervention group; CG=control group; mg/dL=milligrams per deciliter; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 7 is a forest plot of the change in high-density lipoprotein (mg/dL) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

Only five trials reported effect of the interventions on lipid outcomes beyond 12 months of followup.^52,^ ^77,^ ^104,^ ^136,^ ^140^ In all cases, the difference between groups attenuated over time. None of the trials reported the between-group difference in the proportion of participants with high cholesterol after the intervention.

#### Fasting Glucose Level

Eighteen trials (18/113, 15.9%; n=60,269) reported the effect of a counseling intervention on one or more indicators of diabetes, including fasting blood glucose level, hemoglobin A1c (HbA1c) level, and incident diabetes (Appendix G Table 3).^46,^ ^52,^ ^65,^ ^66,^ ^71,^ ^74,^ ^77,^ ^81,^ ^86,^ ^97,^ ^108,^ ^114,^ ^117,^ ^126,^ ^136,^ ^140–142^ There were inconsistent results across studies that reported MDs in changes in fasting glucose, and with a few exceptions,^114,^ ^136^ none of the individual trials reported statistically significant differences in changes in fasting glucose at 6 months or more followup. Furthermore, our meta-analysis of 14 trials found no evidence of an association between interventions and changes in fasting glucose versus control groups at 6 to 12 months (MD, −0.34 mg/dL [0.02 mmol/L] [95% CI, −1.24 to 0.55]; n=7,468; I^2^=42.7%) (Table 5, Figure 8).

Figure 8 Pooled Analysis of Change in Fasting Glucose (mg/dL) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CI=confidence interval; Diff=difference; FBG=fasting blood glucose; HD=healthy diet; Hrs=hours; IG=intervention group; CG=control group; mg/dL=milligrams per deciliter; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 8 is a forest plot of the change in fasting glucose (mg/dL) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity.

The largest changes in fasting glucose level were seen in a small trial of adults with a family history of type 2 diabetes.^81^ Participants randomized to a high-intensity counseling intervention focused on healthy diet plus physical activity (n=24) or to a high-intensity healthy diet-only intervention (n=25) experienced larger reductions in fasting glucose levels at 12 months than the minimal intervention group (n=19) (reductions of −7.7, −5.9, and −3.8 mg/dL, respectively). However, there were no statistically significant differences between groups.

Six of these trials also reported the effects of the interventions on HbA1c (not pooled). Results were similarly inconsistent as with the fasting blood glucose results, with only one trial among older adults who were overweight suggesting a benefit of the intervention on HbA1c level (MD, −0.25 mg/dL [95% CI, −0.37 to −0.12]) (Appendix G Table 3).^108^

Only three trials reported the prevalence or incidence of diabetes.^66,^ ^74,^ ^142^ In one trial (n=348), the proportion of participants with diabetes (defined as fasting glucose ≥126 mg/dL) decreased from 12.1 to 9.8 percent in the intervention group (p<0.0001) and increased slightly (from 4.0% to 5.2%) in the control group at 6 months (odds ratio [OR], 1.99 [95% CI, 0.86 to 4.58]).^74^ In another relatively small trial (n=337), the percent of self-reported diabetes increased approximately 1 percentage point among both intervention (12.4% to 13.4%) and control (11.5% to 12.7%) group participants after one year (OR, 1.06 [95% CI 0.56 to 2.00]).^66^ In the very large WHI-DMT, focused on low-fat dietary patterns, 7.1 versus 7.4 percent of intervention and control participants, respectively, reported incident diabetes after 8 years of followup (HR, 0.96 [95% CI, 0.90 to 1.03]).^142^

#### Adiposity

Thirty-eight trials (38/113, 33.6%; n=76,501) reported an adiposity-related outcome, such as BMI, weight, or waist circumference (Appendix G Table 4).^46,^ ^50,^ ^52,^ ^55,^ ^56,^ ^58,^ ^62,^ ^65,^ ^68,^ ^71,^ ^74,^ ^77,^ ^81,^ ^82,^ ^86,^ ^89,^ ^97,^ ^104,^ ^106–109,^ ^111,^ ^114,^ ^116,^ ^117,^ ^126,^ ^133,^ ^135,^ ^136,^ ^140–142,^ ^144,^ ^149,^ ^151,^ ^155,^ ^157^ Given the number of trials that reported each outcome, we were able to pool the results for BMI, weight, and waist circumference separately. Although we excluded trials that addressed weight loss as a direct goal of the interventions, these trials reported small improvements in BMI, weight, and waist circumference (Table 5). The results of each meta-analysis showed small but statistically significant associations between healthy diet and/or physical activity interventions and reductions in BMI, weight, and waist circumference at approximately 6 to 12 months (Figures 9–11). Considerable statistical heterogeneity (I^2^>90%) was present in all analyses due to wide variation in effect estimates and precision around those estimates, which likely reflects clinical variability among the included studies. Thus, the pooled average intervention effects should be interpreted with caution.

Figure 9 Pooled Analysis of Change in Body Mass Index (kg/m^2^) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: BMI=body mass index; CG=control group; CI=confidence interval; Diff=difference; HD=healthy diet; Hrs=hours; IG=intervention group; kg/m^2^=kilograms per meters squared; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 9 is a forest plot of the change in body mass index (kg/m2) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

Figure 10 Pooled Analysis of Change in Weight (kg) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CI=confidence interval; Diff=difference; HD=healthy diet; Hrs=hours; IG=intervention group; CG=control group; kg=kilograms; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 10 is a forest plot of the change in weight (kg) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

Figure 11 Pooled Analysis of Change in Waist Circumference (cm) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Intervention Intensity

Abbreviations: CI=confidence interval; Cir=circumference; Cm=centimeters; Diff=difference; HD=healthy diet; Hrs=hours; IG=intervention group; CG=control group; Mins=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 11 is a forest plot of the change in waist circumference (cm) in healthy diet and/or physical activity interventions compared with controls, organized by intervention intensity. This figure is discussed in the Results section.

Seventeen trials presented both BMI and weight outcomes and were included in meta-analyses for each of these outcomes.^46,^ ^52,^ ^65,^ ^74,^ ^77,^ ^81,^ ^86,^ ^104,^ ^108,^ ^109,^ ^111,^ ^114,^ ^133,^ ^136,^ ^142,^ ^151,^ ^157^ Ten additional studies were unique to the BMI plot and seven studies were unique to the weight plot. Thus, these two outcomes represent slightly different sets of trials. The meta-analysis of BMI measures showed a pooled difference in mean change of −0.32 kg/m^2^ (95% CI, −0.51 to −0.13; 27 trials [n=59,239]; I^2^=94.6%) related to healthy diet and physical activity interventions (Figure 9). The range in between-group differences in change in BMI was 0.7 kg/m^2^ in favor of the control group and 1.3 kg/m^2^ in favor of the intervention group, although most trials suggested intervention benefit. Three trials reported large, nearly statistically significant effects in an unexpected direction (i.e., favoring the control group).^65,^ ^82,^ ^114^ There was minimal difference in the pooled result in a sensitivity analysis removing data from the WHI DMT (pooled result of sensitivity analysis, MD, −0.30 [95% CI, −0.50 to −0.11]; 26 trials [n=17,236]; I^2^=92.1%).

The subset of 12 high-intensity interventions consistently showed benefit of the interventions on BMI, with a pooled difference in mean change of −0.69 kg/m^2^ supporting the intervention (95% CI, −0.99 to −0.40); no such benefit was seen among the subsets of medium- or low-intensity interventions (Figure 9). Furthermore, a dose-response effect was seen, with increasing intensity (that is, total minutes of intervention contact) and the total number of in-person intervention sessions being statistically significantly associated with increasing effect estimates in meta-regression (p<0.01). Most of the studies categorized as high-intensity also focused on both healthy diet and physical activity messages and took place outside of primary care.

A separate meta-analysis showed a statistically significant association with weight in favor of behavioral interventions over control conditions, although again the statistical heterogeneity was considerable (MD, −1.07 kg [95% CI, −1.62 to −0.52]; 24 trials (n=51,812); I^2^=91.2%) (Figure 10). This finding translates into an MD of −2.4 lbs (95% CI, −3.6 to −1.1). The dose-response effect of intervention intensity (p=0.001) and number of in-person contacts (p=0.013) with weight was also evident. The difference in mean change was minimally reduced after removing data from the WHI DMT (MD, −1.02 [95% CI, −1.58 to −0.45]; 23 trials [n=9,809]; I^2^=86.2%).

Eight trials reported adiposity outcomes over time; consistent or slightly attenuated effects were seen for BMI or weight outcomes from 6 months to 6 years of followup across trials.^46,^ ^52,^ ^55,^ ^77,^ ^104,^ ^136,^ ^140,^ ^142^

There was no trend in the effect estimates for BMI or weight according to the samples’ mean BMI or weight at baseline. For example, while one of the largest differences in BMI reduction was seen among the sample with the highest BMI at baseline—the Aldana study,^74^ in which the mean baseline BMI was 32.3 kg/m^2^ and the difference in change was −1.3 kg/m^2^ at 6 months—relatively large differences were also seen among samples with a mean BMI reflecting normal or borderline overweight status (e.g., studies by Brekke,^81^ Simkin-Silverman^136^). Across adiposity outcomes, five trials required participants to be overweight or have obesity upon study entry (mean BMI range, 25.0 to 38.3).^52,^ ^56,^ ^68,^ ^77,^ ^108^

Five trials could not be included in the meta-analyses for BMI^58,^ ^68,^ ^149^ or weight^116,^ ^140^ because of limitations in data reporting (e.g., no measure of dispersion). Results of these trials were mixed, with two trials generally showing no change in adiposity within or between groups,^58,^ ^140^ two trials showing a difference in mean weight change in favor of the intervention versus control group but no estimate of the confidence in the effect,^68,^ ^116^ and one trial showing a slightly better improvement in BMI among control group participants (−1.3 kg/m^2^) versus those participating in a web-based intervention (−0.6 kg/m^2^).^149^

Twenty-four studies (all of which also reported BMI or weight outcomes) presented a measure of waist circumference at 6 months to 2 years of followup. Pooled analyses suggested a reduction of approximately −0.81 cm (0.3 in) in waist circumference related to a diet and/or physical activity intervention (95% CI, −1.32 to −0.30; 23 trials [n=52,128]; I^2^=96.1%) (Figure 11). Mean baseline waist circumference ranged considerably, from 72 cm in a sample of young adults (mean age, 19.7 years)^104^ to 105 cm among samples of older adults.^108,^ ^141^

#### Cardiovascular Risk

Six trials used the Framingham risk equation^165^ to report the effects of a diet or physical activity intervention on multivariate cardiovascular risk status (n=7,087).^47,^ ^52,^ ^66,^ ^89,^ ^97,^ ^126^ The results for this outcome were consistent with the results of other intermediate outcomes reported by each respective trial. Most trials reported reductions in 4- or 10-year risk of coronary heart disease among both intervention and control group participants at 6 to 18 months, with no statistically significant differences between groups.

#### Cardiorespiratory Fitness

Measures of cardiorespiratory fitness were only reported in eight trials (n=5,628).^65,^ ^82,^ ^97,^ ^104,^ ^114,^ ^122,^ ^140,^ ^157^ Five interventions focused on increasing physical activity only, while two focused on improving both physical activity and diet and one focused on diet only. Most of the studies reported maximal oxygen capacity (VO_2_max) at baseline and followup (6 months up to 2 years) based on maximal or submaximal treadmill or cycle ergometer tests. Most studies reported that mean VO_2_max improved slightly more in the intervention groups (from 0.1 to 1.8 mL/kg/min) than control groups (from 0.01 to 1.3 mL/kg/min), although these differences were not statistically significant. In one study among women,^140^ there was a slight improvement in cardiorespiratory fitness in the control group but not the intervention group at 6 months, 12 months, or 1.5 years, although this difference was reported as not statistically significant.

## KQ 3 Do Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior Improve Associated Health Behaviors in Adults?

### Summary of Results

All but four^47,^ ^68,^ ^144,^ ^155^ of the 113 included trials were included for KQ 3 (109/113, 96.5%; n=125,878). A quarter of the trials that reported behavioral outcomes 30 of 113 trials, 26.5%) were newly identified as part of this update. Most of the behavioral outcomes were based on self-report and the instruments, modes of administration, and summary measures were highly variable among the trials.

Between-group differences in mean change for dietary outcomes showed consistent benefit of the intervention versus control groups, but the precision in the magnitude of effects was quite variable across the trials that reported each respective outcome (Table 6). Furthermore, there was considerable statistical heterogeneity (I^2^>90%) present in most meta-analyses. Nevertheless, meta-analysis indicated statistically significant associations between healthy diet counseling interventions (with or without physical activity messages) and measures of saturated fat (standardized mean difference [SMD], −0.53 [95% CI, −0.78 to −0.27]), fruit and vegetables (MD 1.11 servings/day [95% CI, 0.41 to 1.81]), and fiber (SMD, 0.24 [95% CI, 0.05 to 0.43]). The magnitude of difference ranged from −4.1 to −0.3 percentage points in the percent of calories from saturated fat, −0.2 to 5.6 servings/day of fruits and vegetables, and −0.2 to 2.5 grams per day of fiber in favor of the intervention groups compared with control groups. Among trials reporting it, interventions were associated with statistically significantly increased odds of meeting fruit and vegetable intake recommendations (i.e., 5–9 servings/day) compared with controls. Sodium intake was infrequently reported and there was no clear finding for this outcome.

Table 6 Pooled Results of Behavioral Outcomes for All Interventions

Outcome | Effect size (95% CI) | No. of RCTs (n)^*^ | I^2^, %
Saturated fat
Standardized mean difference | −0.53 (−0.78 to −0.27) | 16 (48,661) | 97.4
Mean difference in % of energy from fat | −2.01 (−3.19 to −0.84) | 9 (46,772) | 98.1
Fruits and vegetables
Mean difference in servings per day | 1.11 (0.41 to 1.81) | 17 (53,711) | 99.3
Fiber
Standardized mean difference | 0.24 (0.05 to 0.43) | 13 (47,571) | 93.9
g/day | 1.05 (0.59 to 1.51) | 8 (2,414) | 0%
Sodium^†^
mg/day | Range: −4.9 to −383.0^‡^ | 4 (n=1,444) | NA
Physical activity
Standardized mean difference | 0.19 (0.14 to 0.25) | 59 (20,801) | 65.4
Mean difference in minutes/week | 33.0 (21.9 to 44.2) | 37 (15,015) | 76.0
Meeting PA recommendations | OR=1.41 (1.18 to 1.67) | 24 (17,338) | 55.1
Sedentary behavior
Standardized mean difference | −0.22 (−0.47 to 0.03) | 15 (3,479) | 89.9

* Number of trials included in meta-analyses. Not all trials reporting each outcome could be included in meta-analyses given units or data reported. Total number of trials and observations reporting outcome were: dietary fat (17 trials, n=57,470), fruits and vegetables (35 trials, n=80,366), fiber (14 trials, n=58,541), sodium (4 trials, n=1,444), physical activity (85 trials, n=52,838), and sedentary behavior (14 trials, n=5,595).

† Not meta-analyzed given few trials reporting this outcome.

‡ Only 2 studies reported the mean change in sodium mg/day. One study^74^ found a statistically significant mean difference in change of 383 mg/day (95% CI, −590 to −176) in intervention vs. control groups while the other^62^ found no difference between groups. The other two studies reported sodium scores and found no differences between groups.

Abbreviations: CI=confidence interval; g=gram(s); I^2^=I squared (the percentage of total variation across studies that is due to heterogeneity rather than chance); mg=milligram; min=minute(s); OR=odds ratio; PA=physical activity; RCT=randomized clinical trial.

Physical activity interventions (with or without dietary components) resulted in an approximate 33-minute increase in physical activity per week compared with controls (MD, 33.0 minutes/week [95% CI, 21.9 to 44.2]). Additionally, intervention group participants had a 41 percent higher odds of meeting physical activity recommendations compared with those in the control group (pooled OR, 1.41 [95% CI, 1.18 to 1.67]). Studies that limited enrollment to participants with suboptimal levels of physical activity at baseline (generally below the recommended level of 150 minutes per week) resulted in greater increases in physical activity compared with those that did not limit enrollment based on baseline physical activity levels. In contrast to findings for intermediate outcomes, there was no evidence of effect modification based on intervention intensity. Likewise, there was no evidence of a difference in effects for interventions focused only on physical activity messages versus those focused on both physical activity and healthy diet messages.

There was no evidence of small-study effects for either dietary or physical activity outcomes based on Egger’s test^42^ (for continuous data) or Peters’ test^43^ (for percent meeting physical activity recommendations).

### Detailed Results by Outcomes

#### Diet

Forty-five of the included trials (45/113, 39.8%; n=89,140) reported one or more dietary outcome, including measures of dietary fat intake, fruits and vegetables, fiber, sodium, and overall diet quality.^46,^ ^48,^ ^49,^ ^52,^ ^54,^ ^55,^ ^57,^ ^58,^ ^60,^ ^62,^ ^64–66,^ ^74–76,^ ^78,^ ^79,^ ^81,^ ^83,^ ^84,^ ^86,^ ^88,^ ^92,^ ^93,^ ^99,^ ^105,^ ^107,^ ^109,^ ^111,^ ^112,^ ^116,^ ^119,^ ^126,^ ^129,^ ^133–138,^ ^140,^ ^142,^ ^151,^ ^158^ We limited our abstraction and analyses to these five specific dietary outcomes for consistency with the original review and to focus our results. Many trials, however, reported the effects of the interventions on other important dietary outcomes, such as intake of total energy, carbohydrates, protein, cholesterol, milk/dairy, potassium, and whole grains. All trials relied on self-reported dietary intake; however, the instruments to assess dietary intake were extremely heterogeneous and evidence of validity and reliability varied. Recall periods ranged from 1 to 7 days, with many studies not reporting the specific recall period. Only five of the 45 studies were rated as good quality. Fifteen of the 45 trials were newly identified as part of this update and 30 studies were carried forward from the previous review.

##### Dietary Fat

For this review, we abstracted outcomes related to intake of saturated fat, monounsaturated fatty acids (MUFAs), and polyunsaturated fatty acids (PUFAs). Seventeen trials (n=57,470) reported at least one of these measures of dietary fat intake, although the outcome units varied and included grams per day, percent of energy from fat, percent of calories per day from fat, and a study-defined score (Appendix H Table 1).^52,^ ^60,^ ^62,^ ^74,^ ^81,^ ^84,^ ^86,^ ^88,^ ^105,^ ^112,^ ^126,^ ^133,^ ^136–138,^ ^140,^ ^142^ Regardless of measure, there was consistent evidence of an effect of the interventions on dietary fat outcomes at 6 to 12 months of followup. When all measures of saturated fat were pooled regardless of the unit, the standardized mean difference (SMD) indicated a statistically significant medium effect size in the direction of benefit (SMD, −0.53 [95% CI, −0.78 to −0.27], 16 RCTs [n=48,661]; I^2^=97.4%) (Figure 12, Table 6). Removal of the large WHI DMT—which targeted change in fat intake—only slightly attenuated the pooled result (MD, −0.47 [95% CI, −0.71 to −0.22]), 15 trials [n=6,362]) and still resulted in substantial heterogeneity (I^2^=94%).

Figure 12 Pooled Analysis of Change in Saturated Fat Intake (Standardized Mean Difference) in Healthy Diet and Physical Activity Interventions Compared With Controls

Abbreviations: CI=confidence interval; HD=healthy diet; IG=intervention group; CG=control group; g=grams; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation; SMD=standardized mean difference.

Figure 12 is a forest plot of the change in saturated fat intake (standardized mean difference) in healthy diet interventions (with or without physical activity) compared with controls. This figure is discussed in the Results section.

Looking specifically at the nine trials that reported the daily percent of energy from saturated fat, the magnitude of between-group differences was from approximately −0.3 to −4.1 percentage points in the reduction of saturated fat intake, in favor of the intervention groups (MD, −2.01 [95% CI, −3.19 to −0.83]; 9 RCTs [n=46,772]; I^2^=98.1%) (Table 6, plot not shown), with mean baseline percent of energy from saturated fat ranging from approximately 10 to 15 percent. The difference between groups in grams per day of saturated fat was more variable across studies – ranging from 0.2 to 11.6 grams per day.

##### Fruits and Vegetables

In general, healthy diet interventions resulted in small increases in fruit and vegetable intake compared with controls (37 RCTs, n=82,195) (Appendix H Table 1).^48,^ ^49,^ ^52,^ ^54,^ ^57,^ ^58,^ ^60,^ ^62,^ ^64–66,^ ^74,^ ^75,^ ^79,^ ^83,^ ^84,^ ^86,^ ^88,^ ^92,^ ^99,^ ^105,^ ^107,^ ^109,^ ^111,^ ^112,^ ^116,^ ^119,^ ^126,^ ^129,^ ^133–135,^ ^138,^ ^140,^ ^142,^ ^151,^ ^158^ The pooled between-group difference in mean change was 1.11 servings of fruits and vegetables per day for intervention vs. control groups at 6 to 12 months followup (95% CI, 0.41 to 1.81; 17 RCTs [n=53,711]; I^2^=99.3%) (Figure 13, Table 6). The direction of the effects was consistent, with the exception of two trials^111,^ ^126^ that showed essentially no change in either group. The mean change in fruit and vegetable intake ranged from a decrease of 0.1 to an increase of 6.5 servings/day among intervention groups and a decrease of 0.3 to an increase of 2.3 servings/day among control groups. Baseline servings of fruits and vegetables ranged from approximately 1.0 to 5.8 servings/day across all participants. Eighteen trials reported changes in fruit and vegetable intake separately, with most trials reporting no differences in change in either fruit intake and vegetable intake between intervention vs. control group participants. In almost all cases, the mean fruit and vegetable intake increased or decreased by less less than a half a serving, respectively, among both groups.

Figure 13 Pooled Analysis of Change in Fruit and Vegetable Intake (Servings per Day) in Healthy Diet and Physical Activity Interventions Compared With Controls

Abbreviations: CI=confidence interval; Diff=difference; HD=healthy diet; IG=intervention group; CG=control group; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation.

Figure 13 is a forest plot of the change in fruit and vegetable intake (servings/day) in healthy diet interventions (with or without physical activity) compared with controls. This figure is discussed in the Results section.

Six trials reported the proportion of participants meeting recommendations for fruit and/or vegetable intake at 6 to 12 months followup (Appendix H Table 1).^49,^ ^54,^ ^112,^ ^129,^ ^134,^ ^151^ In all but one trial,^151^ interventions were associated with a statistically significant increased odds of meeting recommendations compared with control groups. For instance, in the good-quality CALM trial (n=200), a higher proportion of participants in all three telephone counseling groups reported consuming 5-9 servings of fruits and vegetables per day (54% to 81.2%) compared with the attention control group participants (32.7%) at 12 months followup.^112^ Similarly, the 10 Small Steps Study (n=4,676) reported that 21.1 percent of participants receiving two computer-tailored print mailings (OR, 1.94 [95% CI, 1.52 to 2.47], p≤0.05) and 18.8 percent of participants receiving one computer-tailored mailing (OR, 1.67 [95% CI, 1.31 to 2.12], p≤0.05) compared with 12.2 percent of control group participants reported meeting fruit and vegetable recommendations (i.e., 5–9 servings/day) at 12 months followup.^129^

##### Fiber

Fewer trials (14 RCTs; n=58,541) reported the effects of interventions on fiber intake (Appendix H Table 1).^52,^ ^62,^ ^65,^ ^76,^ ^78,^ ^79,^ ^81,^ ^83,^ ^88,^ ^93,^ ^126,^ ^133,^ ^137,^ ^142^ Eight of the trials reported fiber intake in terms of grams per day, whereas the remaining five trials only reported grams per 1,000 kilocalories per day or a study-defined fiber score. All but one of the 14 trials are shown in the forest plot that presents the SMD in fiber intake (SMD, 0.24 [95% CI, 0.05 to 0.43]; 13 RCTs [n=47,571]; I^2^=93.9%) (Figure 14, Table 6). The remaining trial did not present within-group variance but reported a statistically significantly greater increase in grams of fiber per day among intervention versus control participants (adjusted MD, 1.00 g/day [95% CI, 0.40 to 1.60]).^88^ In general, all but two of the trials suggested a benefit of the intervention on fiber intake; five of these trials reported greater benefit versus the control group that was statistically significant.^76,^ ^81,^ ^83,^ ^88^ The largest effect size (0.84 [95% CI, 0.82 to 0.86]) was seen in the WHI DMT. A sensitivity analysis removing this data (n=42,299) considerably reduced the variation (I^2^ decreased from 94% to 39%) and resulted in a smaller effect size (SMD, 0.12 [95% CI, 0.01 to 0.24]; 12 trials [n=5,272]). Among studies reporting change in fiber intake as grams per day, the magnitude of between-group difference was approximately 1 to 2.5 g/day at 6 to 12 months in favor of the intervention groups (MD, 1.05 [95% CI, 0.59 to 1.51]; 8 RCTs [n=2,414]) (Table 6). The baseline levels of fiber intake were quite low in these samples, ranging from 6 to 25 g/day.

Figure 14 Pooled Analysis of Change in Fiber Intake (Standardized Mean Difference) in Healthy Diet and Physical Activity Interventions Compared With Controls

Abbreviations: CI=confidence interval; HD=healthy diet; IG=intervention group; CG=control group; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation; SMD=standardized mean difference.

Figure 14 is a forest plot of the fiber intake (standardized mean difference) in healthy diet interventions (with or without physical activity) compared with controls. This figure is discussed in the Results section.

##### Sodium

Only four trials reported sodium outcomes (n=1,444) (Appendix H Table 1).^57,^ ^62,^ ^74,^ ^84^ Two of the trials included specific messages about decreasing salt or sodium intake,^74,^ ^84^ including counseling on the Dietary Approaches to Stop Hypertension (DASH) diet,^84^ ^84^ ^84^ ^141^ ^82^ ^82^ ^82^ ^82^ whereas the other two trials emphasized general heart healthy diet messages.^57,^ ^62^ We did not pool these studies given the small number of trials and variability in the populations and measurement of sodium. Only one of the trials reported a statistically significantly greater reduction in sodium among intervention (−609 mg/day) versus control group (−226 mg/day) participants (MD, −383 mg/day [95% CI, −590 to −176]).^74^ The remaining trials reported small changes in study-defined sodium scores and sodium intake per day in favor of the intervention groups.

##### Dietary Pattern

Five trials (n=1,490) reported the differences in changes in dietary pattern scores between intervention and control groups after 6 to 12 months (Appendix H Table 1).^46,^ ^55,^ ^57,^ ^62,^ ^151^ The instruments used to measure healthful eating varied among the studies and included established indices (e.g., the Healthy Eating Index, Dietary Guideline Index) and study-developed measures. In all cases, dietary patterns improved in intervention participants and showed very little change in control group participants, and all differences were statistically significant. The clinical significance of these changes, however, are difficult to interpret.

#### Physical Activity

Eighty-seven trials (87/113, 77.0%; n=54,534) reported the effects of a behavioral intervention on participants’ physical activity levels (Appendix H Table 2).^46,^ ^49–51,^ ^53–57,^ ^59–63,^ ^65–67,^ ^69,^ ^70,^ ^72–74,^ ^77,^ ^80–83,^ ^85,^ ^87,^ ^89–92,^ ^94–98,^ ^100–106,^ ^108–110,^ ^112–115,^ ^117,^ ^118,^ ^120–132,^ ^134,^ ^136,^ ^137,^ ^139–141,^ ^143,^ ^145–154,^ ^156–158^ In most of these trials, physical activity was the primary outcome. The specific physical activity outcomes, however, were highly variable across studies and included continuous measures such as total physical activity, moderate- to vigorous-intensity physical activity (MVPA), walking, study-defined physical activity scores, and binary measures of the number of participants meeting physical activity recommendations (≥150 minutes of moderate-intensity or 75 minutes of vigorous-intensity physical activity per week). Likewise, the unit of measurement for each of these outcomes was very diverse (e.g., minutes/week, metabolic equivalent of task [MET]-minutes/week, days/week, steps/day, kcal/kg/day). Most of the studies relied on self-reported measures of physical activity (e.g., 7-day physical activity recall, International Physical Activity Questionnaire); however, 30 studies used accelerometers or pedometers to capture an objective measure of physical activity alone or in addition to self-report measures. Twenty-six trials were newly identified as part of this update and 61 were included in the original review.

##### Continuous Levels of Physical Activity

Overall, there was evidence that behavioral interventions increased participants’ physical activity levels (Table 6). The meta-analysis of the SMD in change in continuous measures of physical activity (e.g., minutes/week, kcal/kg/day, steps/day) showed a small but statistically significant association between physical activity interventions (with or without healthy diet messages) and an increase in physical activity levels compared with controls at 6 to 12 months of followup (SMD, 0.19 [95% CI, 0.14 to 0.25]; 59 trials [n=20,801]; I^2^=65.4%) (Figure 15).

Figure 15 Pooled Analysis of Change in Physical Activity (Standardized Mean Difference) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Population Selection

Note: Suboptimal PA indicates that participants were eligible to be included in the trial if they were not meeting current physical activity guidelines.

Abbreviations: CI=confidence interval; HD=healthy diet; hr=hour; IG=intervention group; CG=control group; kcal=kilocalorie; MET=metabolic equivalent; min=minutes; Mos=months; Obj=objective measurement; PA=physical activity; REE=resting energy expenditure; REML=restricted maximum likelihood; SD=standard deviation; SMD=standardized mean difference; SR=self-report; STD PA=standardized physical activity.

Figure 15 is a forest plot of the standardized mean difference in change in physical activity in physical activity interventions (with or without healthy diet) compared with controls, organized by population selection. This figure is discussed in the Results section.

Meta-regression revealed no evidence of effect modification for most pre-specified study, population, and intervention characteristics. For instance, there was no indication that larger or smaller effects were seen when comparing studies that collected physical activity measures via self-report (33 trials) versus those based on objective data collected via accelerometer or pedometer (e.g., steps/day) (26 trials). Similarly, no effect modification was evident based on study quality, setting (US vs. not or whether the intervention was conducted in primary care), intervention intensity (including total minutes of intervention contact, the duration of the intervention, and the total number of sessions) or whether the intervention was completely remotely delivered. In addition, there was no evidence that the effects differed between the subgroup of interventions focused only on increasing physical activity (SMD, 0.18 [95% CI, 0.12 to 0.24]; 39 trials [n=14,560]) versus those that focused on both physical activity and healthy diet goals (SMD, 0.22 [95% CI, 0.10 to 0.34]; 20 trials [n=6,241]).

There was evidence, however, of an interaction between intervention effectiveness and physical activity outcomes according to whether the sample was selected based on suboptimal behavior (i.e., not meeting physical activity recommendations or a specific threshold of physical activity). The pooled effect size for studies that limited enrollment to participants with suboptimal levels of physical activity (SMD, 0.29 [95% CI, 0.20 to 0.39]; 28 trials [n=10,309]; I^2^=73.8%) was statistically significantly higher than for studies that did not limit enrollment based on baseline physical activity levels (SMD, 0.12 [95% CI, 0.07 to 0.17]; 31 trials [n=8,770]; I^2^=35.4% (meta-regression, p=0.002). Review of the baseline levels of physical activity within each sample confirmed lower levels of baseline physical activity in general among participants selected for low levels of physical activity compared with those not selected on the basis of their baseline levels of physical activity (Appendix H Table 2). In most of the studies in which participants were selected on the basis of suboptimal behavior, participants were well below the recommended levels of physical activity at baseline (with mean baseline levels among most studies ranging from 2.5 to less than 75 minutes/week), whereas studies in which participants were enrolled regardless of their baseline physical activity levels had higher baseline values (with the mean baseline above 220 minutes/week in most studies). All but three of the studies that selected participants with suboptimal baseline physical activity were physical activity–only trials. Most interventions were of medium- or low-intensity (i.e., less than 6 hours of intervention contact over the duration of the intervention).

To assist with interpretation of our findings, we also conducted an analysis limited to studies that reported minutes per week of total physical activity, MVPA, or moderate-intensity physical activity (as opposed to measures such as MET minutes, accelerometer counts, or scale scores). Among the 37 trials that reported minutes per week of physical activity, this change amounted to approximately 33 additional minutes of physical activity per week for the intervention group compared with the control group (MD, 33.0 minutes/week [95% CI, 21.9 to 44.2]; n=15,015) (Figure 16). Statistical heterogeneity was still substantial within this meta-analysis (I^2^=76.0%), which was likely due to the clinical heterogeneity of the populations and interventions and the specific measurement of physical activity. There was considerable variation in the level of baseline physical activity across the studies. Physical activity ranged from 2 minutes/week among a sample of Hispanic women to 621 minutes/week (nearly 1.5 hours/day) among older adults (mean age 64.5 years) in the Netherlands. Absolute differences between groups at 6 months to 12 months ranged from approximately 14 minutes/week (in favor of the control group) to 160 minutes/week (in favor of the intervention group).

Figure 16 Pooled Analysis of Change in Physical Activity (Minutes/Week) in Healthy Diet and Physical Activity Interventions Compared With Controls, by Population Selection

Note: Suboptimal PA indicates that participants were eligible to be included in the trial if they were not meeting current physical activity guidelines.

Abbreviations: CI=confidence interval; Diff=difference; HD=healthy diet; IG=intervention group; CG=control group; Min=minutes; MnChg=mean change; Mos=months; Obj=objective measurement; PA=physical activity; REML=restricted maximum likelihood; SD=standard deviation; SR=self-report.

Figure 16 is a forest plot of the change in physical activity (min/week) in physical activity interventions (with or without healthy diet) compared with controls, organized by population selection. This figure is discussed in the Results section.

Thirteen studies that reported a physical activity outcome were not included in any of the physical activity meta-analyses due to a lack of reporting of detailed results (e.g., no within-group data, no variance) (Appendix H Table 2).^54,^ ^58,^ ^69,^ ^80,^ ^83,^ ^92,^ ^102,^ ^108,^ ^118,^ ^123,^ ^124,^ ^139,^ ^143,^ ^156^ Results of these studies varied. Eight trials reported beneficial effects of the intervention on at least one physical activity outcome^54,^ ^69,^ ^83,^ ^108,^ ^118,^ ^124,^ ^139,^ ^156^ whereas five trials reported no statistically significant effect of the intervention on levels of MVPA or total physical activity at 6 months to 12 months.^80,^ ^92,^ ^102,^ ^123,^ ^143^

##### Meeting Physical Activity Recommendations

Twenty-four trials reported the proportion of participants meeting recommended levels of physical activity at 6 months to 2 years of followup (Appendix H Table 2).^50,^ ^54,^ ^61,^ ^66,^ ^77,^ ^89,^ ^91,^ ^94,^ ^96,^ ^97,^ ^112,^ ^115,^ ^117,^ ^121,^ ^122,^ ^124,^ ^125,^ ^129,^ ^131,^ ^134,^ ^148,^ ^152,^ ^156,^ ^158^ The definition of meeting physical activity recommendations was generally the same in all of the trials—at least 150 minutes of MVPA per week. The meta-analysis of all 24 trials showed that physical activity interventions were associated with a 41 percent higher odds of meeting physical activity recommendations at 6 to 12 months of followup compared with those in the control group (pooled OR, 1.41 [95% CI, 1.18 to 1.67]; 24 trials [n=17,338]; I^2^=55.1%) (Figure 17). Across all of the trials, the proportion of participants meeting physical activity recommendations at followup ranged from 16.3 to 95.6 percent in the intervention groups and from 6 to 83.1 percent in the control groups, with an absolute difference ranging from −12.1 percentage points (in favor of the control group) to 20.5 percentage points (in favor of the intervention group). In most cases, the proportion of participants meeting the recommendation was based on self-reported measures. In a few cases that based this outcome on accelerometer-measured physical activity, more participants in the control groups were meeting recommendations than participants in the intervention groups (though differences were not statistically significant).^77,^ ^91^

Figure 17 Pooled Analysis of Odds of Meeting Physical Activity Recommendations in Healthy Diet and Physical Activity Interventions Compared With Controls, by Population Selection

Note: Suboptimal PA indicates that participants were eligible to be included in the trial if they were not meeting current physical activity guidelines.

Abbreviations: CI=confidence interval; HD=healthy diet; IG=intervention group; CG=control group; Mos=months; Obj=objective measurement; OR=odds ratio; PA=physical activity; REML=restricted maximum likelihood; SR=self-report.

Figure 17 is a forest plot of the odds of meeting physical activity recommendations in physical activity interventions (with or without healthy diet) compared with controls, organized by population selection. This figure is discussed in the Results section.

Seven trials reported this outcome at multiple time points; there was no pattern across studies in the persistence of effect over time (Appendix H Table 2).^61,^ ^94,^ ^97,^ ^117,^ ^121,^ ^122,^ ^152^ In some trials, a greater number of participants were meeting physical activity recommendations at longer compared with shorter followup (i.e., 12 months vs. 6 months), whereas in other trials, fewer participants were meeting recommendations over time. Similar patterns in the differences between groups were also evident, in that some trials found greater differences immediately following the interventions (i.e., 6 months) yet others found greater differences at longer (12 or 24 months) followup.

#### Sedentary Behavior

Sixteen trials (16/113, 14.2%; n=5,867) reported measures of sedentary behavior, independent of physical activity (Appendix H Table 3).^50,^ ^54,^ ^55,^ ^60–62,^ ^67,^ ^71,^ ^83,^ ^103,^ ^110,^ ^123,^ ^137,^ ^140,^ ^151,^ ^157^ Only one of these trials, the good-quality study by Aadahl et al.^71^ ^70^ (n=166), designed its intervention specifically to reduce daily television viewing and minimize sitting time.^71^ The remaining trials focused the intervention on increasing physical activity (with or without diet messages), with only a few mentioning messages about decreasing sedentary behavior. The instruments and measures used for this outcome were different among the studies including both accelerometer-measured and self-report sitting time, screen time, TV time, and total sedentary time (as minutes/week, hours/week or day, or scores). When measures were combined, the standardized effect of the interventions did not show a statistically significant difference between groups at 6 to 12 months followup, although the effect was in the direction of intervention benefit (SMD, −0.22 [95% CI, −0.47 to 0.03]; 15 trials [n=3,479]; I^2^=89.9%) (Table 6, Figure 18). The results across the studies were highly variable, with some showing decreases in sedentary time among intervention but not control groups and some showing increases in sedentary time among both intervention and control groups (but, to a lesser extent among intervention groups). One trial found that sedentary time increased significantly more among intervention than control group participants at both 6 and 12 months. Absolute hours of sedentary time at baseline were also highly variable ranging from to approximately 12 to 72 hours/week with changes in both groups ranging from 40 minutes more to 22 hours fewer of sedentary or screen time per week at 6 or 12 months.

Figure 18 Pooled Analysis of Change in Sedentary Behavior (Standardized Mean Difference) in Healthy Diet and Physical Activity Interventions Compared With Controls

Abbreviations: CI=confidence interval; HD=healthy diet; Hrs=hours; IG=intervention group; CG=control group; Min=minutes; MnChg=mean change; Mos=months; PA=physical activity; REML=restricted maximum likelihood; SMD=standardized mean difference.

Figure 18 is a forest plot of the change in sedentary behavior (standardized mean difference) in healthy diet interventions (with or without physical activity) compared with controls. This figure is discussed in the Results section.

### Concordance Between Intermediate and Behavioral Outcomes

Among trials that reported both intermediate and behavioral outcomes (38 trials), findings were generally concordant within studies (Table 7). That is, trials that reported a statistically significant benefit of the intervention on one or more intermediate outcomes also reported statistically significant benefit on dietary and/or physical activity behaviors at each given time point. Furthermore, the specific intermediate outcome showing benefit within each trial generally reflected the specific behavior changes targeted in that trial. For example, trials finding differences in between-group mean BMI and/or weight reductions also reported large between-group improvements in dietary intake outcomes (e.g., studies by Aldana^74^, Brekke,^81^ Coates,^86^ Lombard,^62^ Simkin-Silverman,^136^ and Tinker^142^). The limited number of studies that reported a statistically significant benefit of the intervention on LDL or total cholesterol reported concordant significant between-group reductions in saturated fat intake.^133,^ ^136^

Table 7 Summary of Findings Across Intermediate and Behavioral Outcomes, by Author

Author, Year | Intervention Focus | KQ 2. Intermediate outcomes | | | | | | | | | | KQ 3. Behavioral outcomes
Author, Year | Intervention Focus | SBP | DBP | LDL-C | TC | HDL-C | FBG | BMI | Weight | WC | CVD Risk | Diet^*^ | PA
Aadahl, 2014^71^ | PA | | | ↑ | ↑ | ↔ | ↔ | | ↑ | ↑↑ | | | ↑↑^†^
Aldana, 2006^74^ | HD+PA | ↓ | ↑ | ↑ | ↑ | ↓ | ↑ | ↑↑ | ↑↑ | | | ↑↑ | ↑↑
Anand, 2016^66^ | HD+PA | ↑ | ↔ | | | | ↔ | | | | ↔ | ↔ | ↑^‡^
Baron, 1990^76^ | HD | | | ↔ | ↔ | ↔ | | | | | | ↑↑
Bennett, 2013^77^ | HD+PA | ↔ | ↑ | ↑ | ↑ | ↔ | ↓ | ↑↑ | ↑↑ | ↑ | | | ↑
Brekke, 2005^81^ | HD+PA | | | ↑ | ↓ | ↓↓ | ↑ | ↑↑ | ↑↑ | ↑ | | ↑↑ | ↑^‡^,^§^
Bryan, 2013^82^ | PA | | | | | | | ↓ | | | | | ↑↑
Caplette, 2017^58^ | HD | | | | | | | ↔ | | | | ↑↑
Coates, 1999^86^ | HD | ↑↑ | ↔ | | | | ↑ | ↑↑ | ↑↑ | ↑↑ | | ↑↑
Elley, 2003^89^ | PA | ↑ | ↑ | | ↔ | | | ↔ | | | ↔ | | ↑↑
Gill, 2019^151^ | HD+PA | ↔ | ↔ | | | | | ↔ | ↔ | ↑ | | ↑↑^**^ | ↑↑
Grandes, 2009^97^ | PA | ↔ | ↓ | ↑ | ↔ | ↑↑ | ↔ | ↔ | | ↔ | ↔ | | ↑↑
Guagliano, 2020^157^ | PA | | | | | | | ↔ | ↔ | ↔ | | | ↑↑
Hargreaves, 2016^101^ | PA | | ↑ | | ↑ | | | | | | | | ↑↑
Harris, 2018^50^ | PA | | | | | | | ↔ | | ↔ | | | ↑↑
Hivert, 2007^104^ | HD+PA | ↑ | ↓ | ↑ | ↑ | - | | ↑↑ | ↑↑ | ↑ | | ↔ | ↑
Jeffery, 1999^106^ | HD+PA | | | | | | | | ↔ | | | ↔ | ↔
Jenkins, 2017^52^ | HD | ↔ | ↔ | ↔ | ↓ | ↔ | ↔ | ↔ | ↔ | ↔ | ↔ | ↔
John, 2002^107^ | HD | ↑↑ | ↑↑ | | ↔ | | | | ↔ | | | ↑↑
Kallings, 2009^108^ | PA | ↓ | ↓ | ↑ | ↑ | ↔ | ↑ | ↑↑ | ↑↑ | ↑ | | | ↑↑
Kattelmann, 2014^109^ | HD+PA | | | | | | | ↑ | ↑ | ↔ | | ↑↑ | ↔
Kerr, 2016^111^ | HD | | | | | | | ↑ | ↑ | | | ↔
Kinmonth, 2008^114^ | PA | ↔ | ↓ | ↓ | ↓ | ↓ | ↓↓ | ↓ | ↓ | ↓ | | | ↔
Koniak-Griffin, 2015^46^ | HD+PA | ↔ | ↑ | ↔ | ↑ | ↔ | ↔ | ↑ | ↑ | ↑↑ | | ↑↑ | ↑↑
Kristal, 2000^116^ | HD | | | | | | | | ↑^§^ | | | ↑↑
Lawton, 2008^117^ | PA | ↑ | ↔ | | ↑ | ↔ | ↔ | | ↑ | ↑ | | | ↑↑^††^
Lombard, 2016^62^ | HD+PA | | | | | | | | ↑↑ | ↑ | | ↑↑
Metzgar, 2016^65^ | HD | ↑↑ | ↓ | | | | ↓ | ↓ | ↓ | ↓ | | ↔ | ↑
Mosca, 2008^126^ | HD+PA | ↔ | ↑ | ↔ | ↓ | ↑ | ↔ | ↔ | | ↔ | ↔ | ↔ | ↑
Roderick, 1997^133^ | HD | ↑ | ↔ | | ↑↑ | | | ↔ | ↑↑ | | | ↑↑
Sacerdote, 2006^135^ | HD | ↔ | ↔ | | | | | ↑↑ | | | | ↑↑
Simkin-Silverman, 1995^136^ | HD+PA | ↑↑ | ↑ | ↑↑ | ↑↑ | ↓↓ | ↑↑ | ↑↑ | ↑↑ | ↑↑ | | ↑↑ | ↑↑
Sun, 2017^56^ | HD+PA | | | | | | | ↔ | ↑ | | | | ↑
Thompson, 2008^140^ | HD+PA | ↑ | ↔ | ↔ | ↔ | ↔ | ↔ | ↑ | ↔^§^ | ↑ | | ↔ | ↑
Thompson, 2014^141^ | PA | ↑ | ↑ | | ↑ | ↓ | ↓ | | ↔ | ↔ | | | ↑
Tinker, 2008^142^ | HD | ↑↑ | ↑↑ | | | | | ↑↑ | ↑↑ | ↑↑ | | ↑↑
Wadsworth, 2010^149^ | PA | | | | | | | ↓^§^ | | | | | ↑
Wieland, 2018^55^ | HD+PA | ↓ | ↓ | | | | | | ↑ | ↑ | | ↑↑ | ↑
Symbol Legend:; ↑↑=Statistically significant between-group difference in favor of intervention group.; ↑=Between-group difference in favor of intervention group, but not statistically significantly different.; ↔=No clear between-group difference. For blood pressure, between-group difference <0.5 mm Hg. For cholesterol and glucose, between-group difference of <1.0 mg/dL. For BMI, between-group difference of <0.25 kg/m2. For weight and waist circumference, between-group difference of <0.5 kg or cm, respectively. For CVD risk, between-group difference of 1 percentage points. For dietary outcomes, percent energy from saturated fat <1%, fiber <0.10 standardized mean difference, fruits and vegetables <0.5 serving/day. For physical activity, standardized mean difference <0.10.; ↓=Between-group difference in favor of control group, not statistically significantly different.; ↓↓= Statistically significant between-group difference in favor of control group.

* For majority of reported dietary outcomes. See Appendix H Table 1 for detailed dietary outcome results.

† Self-reported sitting time.

‡ For percent meeting physical activity recommendations.

§ Not included in meta-analysis.

** For meeting fruit and vegetable intake recommendation (≥3 servings per day).

†† For percent meeting physical activity recommendations.

Abbreviations: BMI=body mass index; CVD Risk=Multivariate risk status; CVD=cardiovascular disease; DBP=diastolic blood pressure; FBG=fasting blood glucose; HD+PA=healthy diet and physical activity; HD=healthy diet; HDL-C=high-density lipoprotein cholesterol; KQ=key question; LDL-C=low-density lipoprotein cholesterol; PA=physical activity; SBP=systolic blood pressure; TC=total cholesterol; TG=triglycerides; WC=waist circumference.

In many instances in which trials did not find any benefit in intermediate outcomes, the trials demonstrated statistically significant improvements in dietary intake and/or physical activity.^50,^ ^55,^ ^58,^ ^62,^ ^71,^ ^76,^ ^82,^ ^89,^ ^101,^ ^109,^ ^116,^ ^117,^ ^151^ Among the physical activity-only interventions that reported increased physical activity levels as a result of the interventions, statistically significant effects on intermediate outcomes were limited to waist circumference,^71^ HDL cholesterol level,^97^ or BMI or weight.^108^ There were two trials that reported statistically significant improvements in intermediate outcomes in the absence of concurrent improvements in behaviors. Both were weight gain prevention trials in which statistically significant differences were found between groups for adiposity outcomes, despite no substantial differences between groups in dietary intake or physical activity levels.^77,^ ^104^

## KQ 4 What Adverse Events Are Associated With Primary Care Behavioral Counseling Interventions to Improve Diet, Increase Physical Activity, and/or Reduce Sedentary Behavior in Adults?

### Summary of Results

We examined all 113 included trials for any reported harms, as defined by the study authors. Generally, the harms of included counseling interventions were sparsely reported and were inconsistently defined, which precluded pooling. Twenty-three of the 113 included trials (20.4%) specifically mentioned the occurrence of harms or lack of harms (n=12,452); 12 of these 23 trials were newly identified as part of this update. Across these studies, adverse events related to counseling were exceedingly rare with generally no statistically significant differences in any study for: any adverse events, serious adverse events, musculoskeletal injuries, or falls.

### Detailed Results

Twenty-three trials reported on the presence or absence of adverse events (AEs) related to the interventions.^50–52,^ ^54,^ ^62,^ ^63,^ ^69,^ ^72,^ ^77,^ ^80,^ ^83,^ ^89,^ ^103,^ ^113,^ ^115,^ ^117,^ ^128,^ ^135,^ ^141,^ ^151,^ ^153,^ ^155,^ ^157^ Most of the interventions focused specifically on increasing physical activity; only two trials focused only on improving dietary habits.

There was substantial variability in the level of detail in the reporting of harms across the 23 trials. Thirteen trials reported AEs or serious AEs of any kind,^50–52,^ ^54,^ ^62,^ ^69,^ ^72,^ ^77,^ ^83,^ ^103,^ ^135,^ ^153,^ ^157^ although seven of these trials simply reported that no AEs were reported or that no AEs related to the trial were evident but no additional details were provided.^54,^ ^62,^ ^72,^ ^83,^ ^135,^ ^153,^ ^157^ The other six trials found that rates of AEs were relatively similar across groups (ranging from 22.6% to 80% of intervention participants and 25.4% to 71% of control group participants), and none reported rates of any AEs to be statistically significantly different between groups.^50,^ ^51,^ ^52,^ ^69,^ ^77,^ ^103^ The weight gain prevention SNAP trial among young adults also monitored safety alerts related to: eating disorders, a BMI less than 18.5 kg/m^2^ at followup, and greater than 20 percent weight loss from baseline. No alerts among any groups were noted for eating disorders or a BMI less than 18.5 kg/m^2^ at followup and few cases (2, 2, and 3 cases in the two intervention groups and control group, respectively) of >20 percent weight loss were observed.^155^

Twelve trials (n=5,771), seven of which focused exclusively on physical activity, reported the incidence of musculoskeletal injuries, fractures, or falls and found primarily no differences between treatment groups.^50,^ ^63,^ ^80,^ ^89,^ ^103,^ ^113,^ ^115,^ ^117,^ ^128,^ ^141,^ ^151,^ ^155^ The absolute rates of musculoskeletal injuries and falls varied considerably among the trials, likely reflective of how the study defined these outcomes. In most cases, rates of injuries and falls were greater among intervention versus control group participants over the course of the trial, but only one trial found these differences to be statistically significant. This trial among sedentary women ages 40 to 74 years reported significantly more injuries (19% vs. 14%; p=0.03) and falls (37% vs. 29%, p<0.001) among participants in the intervention group, which received counseling that included a tailored physical activity prescription, than in the usual care control group over 24 months of followup.^117^

The most robust examination of AEs was provided by Harris and colleagues for the PACE-UP and PACE-Lift trials, the same trials that reported on CVD events as discussed within the KQ 1 results.^50,^ ^103,^ ^160,^ ^166^ Both trials tested 12-week physical activity pedometer-based interventions: the PACE-Lift trial^103^ was among older adults ages 60–75 years whereas the PACE-UP trial^50,^ ^166^ was among adults aged 45-75 years. In PACE-Lift, nearly identical rates of AEs of any kind (e.g., falls, fractures, injuries, and deterioration in health problems) were found between treatment groups at 12 months (55% vs. 56%; p=0.90). Similarly, total AEs (including any AE from primary care records or self-reported falls, fractures, sprains, and injuries) did not differ between groups immediately following the intervention (3 months) or at 12 months. There was also no between-group difference in trial-related serious adverse events reported for safety monitoring.^50,^ ^166^

In an analysis combining long-term data (up to 4 years) from both trials, an apparent protective effect of the intervention was found for rates of fractures. In the PACE-UP trial, the proportion of patients with a fracture during follow-up was lower in the intervention group (26/668, 3.9%) compared with the control group (28/333, 8.4%); for PACE-Lift both groups had identical proportions of fractures, 5.4 percent (8/149) in the intervention group and 5.4% (8/147) in the control group. The overall Cox regression HR when data for both trials were combined was 0.56 (95% CI 0.35 to 0.90, p=0.02).^160^ In terms of falls (which were medically-reported), PACE-UP trial, 94/668 (14.1%) intervention participants vs. 48/333 (14.4%) of control group participants experienced at least one fall during and after the inventions. The rates were similar in the PACE-Lift trial, where 21/149 (14.15) vs. 15/147 (10.2%) of intervention vs. control groups, respectively, experienced at least one fall. When trial data were combined the overall incident rate ratio for falls was 1.07 (95% CI, 0.78 to 1.46, p=0.67).^160^

### Impact of Population Characteristics on Effects

Direct within-study comparisons of the effectiveness of the intervention by different population subgroups were sparsely reported, often not prespecified (i.e., most were post-hoc, secondary or tertiary analyses), mostly from small studies, and rarely included interaction testing. Therefore, it is hard to draw any definitive conclusions about the differential effectiveness of interventions by subgroups.

Four trials reported subgroup results for intermediate outcomes based on age and none of them found differences in the effectiveness of the interventions on measures of blood pressure or weight change by different age categories.^62,^ ^155,^ ^167,^ ^168^ Two trials reported the results of the interventions on intermediate outcomes by race/ethnicity: both the WHI-DMT study (n=48,835) and the Women’s Health Trial Feasibility study (n=2,208) found no differences in the effects of the interventions on SBP or incident hypertension^168^ and blood pressure, glucose levels, or weight outcomes^169^ among women of different racial or ethnic groups. Likewise, four trials that reported the effectiveness of interventions by sex found no differences in the results for lipid levels and weight outcomes for men vs. women.^76,^ ^111,^ ^133,^ ^155^

For behavioral outcomes, five trials reported results related to dietary outcomes by age, sex, and/or race/ethnicity^76,^ ^86,^ ^111,^ ^116,^ ^170^ and eight trials reported results related to physical activity by these population characteristics.^50,^ ^54,^ ^63,^ ^97,^ ^100,^ ^139,^ ^146,^ ^167^ While there was some modest variation in the results by subgroup, none of the trials found evidence of effect modification that was statistically significant based on any of these characteristics.

Given the high potential for confounding by clinical differences in these samples and from other sources of clinical heterogeneity, such as intervention intensity, we did not perform indirect comparisons of subpopulation effects across trials (e.g., trials limited to women vs. those limited to men).

### Impact of Intervention Characteristics on Effects

As described under the outcome-specific results, there was some evidence that interventions of higher intensity—in terms of total minutes of planned intervention exposure, the number of sessions involving in-person contact with an interventionist, and the duration of the interventions—were associated with larger effects on intermediate health outcomes. These results should be interpreted with caution, however, given limiting reporting on intervention details, the subjective nature of abstracting data on intervention characteristics, as well as other factors may be confounding these findings. Furthermore, this association was only found for LDL cholesterol and adiposity measures, and not for measures of blood pressure.

Among the 43 trials that reported at least one intermediate outcome, there was a huge variation in the dose of each intervention, not only in the amount of time delivering the intervention but also the modes of delivery. The estimated total minutes of intervention contact ranged from 2 minutes to 38.5 hours (median: 2 hours and 40 minutes). Our estimate of intensity included time spent during in-person sessions, telephone calls, computer-based sessions, and the estimated time for reading e-mails or text message. Print-based materials and mailings did not contribute to the intensity value. Interventions that were solely print-based were always categorized as low intensity. These estimates were based on the planned (vs. actual) number and length of sessions; in several cases, we made assumptions and provided estimates regarding the number and length of sessions based on details provided in each article. Our methods for estimating intensity are described in detail in Chapter 2.

Intensity appears to be confounded by several factors. In general, interventions of higher intensity focused on healthy diet messages and may or may not have included physical activity messages. Very few interventions of higher intensity focused on physical activity only. In addition, higher intensity interventions were generally longer in duration (e.g., ≥1 year), although the bulk of the intensive phase of these interventions generally occurred in the first 6 months. Lastly, almost all the high-intensity interventions relied on volunteer or other convenience samples and did not occur in a primary care setting. Across the 43 studies that reported an intermediate outcome, only two studies in primary care^77,^ ^110^ were categorized as high intensity, with one focused on provider training.^110^

Thirty-three of the included trials had more than one active intervention arm designed to contrast specific approaches, including varying the mode of intervention delivery, different schedules of intervention delivery, different behavior change messages (e.g., diet only or diet plus physical activity) or behavior change techniques, and interventions with and without maintanence phases following the main intervention period.^50,^ ^53,^ ^59,^ ^60,^ ^63,^ ^65,^ ^69,^ ^70,^ ^72,^ ^75,^ ^81,^ ^84,^ ^87,^ ^92,^ ^102,^ ^106,^ ^111–114,^ ^119,^ ^122,^ ^123,^ ^127,^ ^129,^ ^138,^ ^145–147,^ ^150,^ ^153–155^ There was no consistent pattern within or across these trials to suggest that certain intervention characteristics were more favorable than others in improving any outcomes. Readers should interpret these findings with caution, however, since we did not include the full body of evidence related to the comparative effectiveness of different lifestyle interventions.