# Chapter 2 Methods

## Scope of Review

This is a systematic review update of a 2017 review.^2,^ ^3^ Only one substantive change was made from that review to this update. In the previous review, studies limited to adults with elevated blood pressure were included. These studies have been excluded in this update and are now considered in the USPSTF review among adults with known CVD risk factors.^4,^ ^5^

## Key Questions and Analytic Framework

We developed an Analytic Framework (Figure 1) and four Key Questions (KQs) to guide the literature search, data abstraction, and data synthesis.

Figure 1 Analytic Framework

*CVD risk factors include: hypertension or elevated BP, dyslipidemia or elevated lipids, impaired fasting glucose or impaired glucose tolerance, and mixed or multiple risk factors (e.g., 10-year CVD risk >7.5%, metabolic syndrome).

Abbreviations: BP=blood pressure, BMI=body mass index, CVD=cardiovascular disease.

Figure 1 is the analytic framework that depicts the four Key Questions to be addressed in the systematic review. The figure illustrates how counseling interventions for adults without known cardiovascular disease (CVD) risk factors (hypertension or elevated blood pressure, dyslipidemia or elevated lipids, impaired fasting glucose or impaired glucose tolerance, and mixed or multiple risk factors) may result in improved health outcomes (cardiovascular events and related morbidity, cardiovascular and all-cause mortality, and quality of life measures) (Key Question 1). Additionally, the figure illustrates how counseling interventions for adults without known CVD risk factors may have an impact on intermediate outcomes (change in CVD risk factors: blood pressure, lipids, blood glucose, cardiorespiratory fitness, body mass index, weight, waist circumference, dichotomized versions of CVD risk factors, and calculated 10-year CVD risk) (Key Question 2) and intermediate behavioral outcomes (dietary intake, physical activity, and sedentary behavior) (Key Question 3). This figure also depicts a question related to potential harms resulting from counseling interventions for adults without known CVD risk factors (Key Question 4).

### KQs

1. Do primary care–relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior improve cardiovascular disease (CVD) and related health outcomes (e.g., morbidity and mortality) in adults without known CVD risk factors*?
2. Do primary care–relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior improve intermediate outcomes associated with CVD (g., blood pressure, lipid levels, blood glucose levels, and body mass index) in adults without known CVD risk factors*?
3. Do primary care–relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior improve intermediate behavioral outcomes (e.g., diet, physical activity, and sedentary behavior) in adults without known CVD risk factors*?
4. What are the harms of primary care–relevant behavioral counseling interventions to improve diet, increase physical activity, and reduce sedentary behavior in adults without known CVD risk factors*?

*CVD risk factors include hypertension or elevated blood pressure, dyslipidemia or elevated lipid levels, impaired fasting glucose or impaired glucose tolerance, and mixed or multiple risk factors (e.g., 10-year CVD risk >7.5% and metabolic syndrome)

## Data Sources and Searches

We designed this review as an extension of two of our prior systematic reviews on behavioral counseling for the primary prevention of CVD. The first was our review of adults not at high risk of CVD and was published in 2017 (encompassing literature through May 2016).^2,^ ^3^ The second review focused on studies among high-risk adults and was published in 2020 (encompassing literature through September 2019).^4,^ ^5^ Our search strategies were identical for both reviews and were designed to encompass all adults regardless of risk level. During the search process for the 2020 review, we purposefully coded studies that did not include a high-risk population but that might otherwise be included for evaluation in our updated review. As such, we re-evaluated all of those records as well as the 88 studies included in the 2017 review for potential inclusion. We then searched for new primary published literature from May 2016 through February 3, 2021. We searched the following databases: MEDLINE, PsycINFO, and the Cochrane Central Register of Controlled Trials. We worked with a research librarian to develop our search strategy, which was peer reviewed by a second research librarian (Appendix A). All searches were limited to articles published in the English language. Collectively, the literature searches encompassed literature published from 1966 through February 3, 2021

We also examined the reference lists of previously published reviews, meta-analyses, and primary studies to identify any potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-content alerts, such as those produced by the USPSTF Scientific Resource Center LitWatch activity.^34^ We conducted active surveillance of the literature for relevant studies through February 9, 2022. In addition to these database searches, we searched ClinicalTrials.gov for ongoing trials through January 2021. We managed the literature search results using version X9 of EndNote® (Thomson Reuters, New York, NY), a bibliographic management software database.

## Study Selection

We developed specific inclusion criteria to guide our study selection (Appendix A Table 1). For all KQs, we included randomized, clinical trials (RCTs), including cluster randomized trials, that evaluated the effectiveness of primary care–relevant interventions focused on improving dietary habits, increasing physical activity, and/or reducing sedentary time with the primary aim of CVD primary prevention. We excluded studies with a primary aim of weight loss or weight management as this evidence is covered by a separate systematic review conducted for the USPSTF.^35^ Similarly, we excluded studies primarily aimed at falls prevention or improving cognitive function rather than CVD prevention. Studies had to report a behavioral outcome (i.e., diet, physical activity, sedentary time), intermediate outcome (e.g., blood pressure, lipid levels, weight), or health outcome (i.e., morbidity, mortality, health-related quality of life [QOL]) or report adverse events related to the intervention.

We included studies if they were among adults age 18 years or older without known CVD, diabetes, or CVD risk factors. The evidence on CVD prevention among adults with known cardiovascular risk factors is covered by a separate systematic review.^4,^ ^5^ As such, we excluded studies that 1) targeted persons with known CVD, hypertension or elevated blood pressure (high blood pressure stage 1 [systolic 130 mm Hg or diastolic 80-89 mm Hg]),^36^ dyslipidemia, diabetes, impaired fasting glucose or glucose tolerance, or a combination of these factors; 2) targeted persons categorized as high risk based on a cardiovascular risk assessment tool; or 3) generically stated that participants must have one or more CVD risk factors to be included. We included studies with persons that may be at elevated risk for CVD based on factors such as age, race/ethnicity, family history of CVD, overweight or obesity, or history of gestational diabetes.

We also included studies among unselected samples (e.g., a general population, recruited on the basis of age or sex only) or samples that were selected because of suboptimal behavior (e.g., did not meet national physical activity guidelines). We excluded studies of persons with other known chronic diseases, such as cancer (including studies targeting cancer survivors) or severe mental illness, as well as pregnant persons.

We included interventions that were conducted in or recruited from primary care or a health care system or that we judged could feasibly be implemented in or referred from primary care. For example, we included studies relying on virtual-, computer-, or telephone-based programs or those that exclusively used print or mailed materials, as we judged these all to be potentially feasible for a primary care office or a large health system to implement. We excluded studies that took place exclusively in or in conjunction with worksites, churches, or other settings that are not generalizable to primary care given pre-existing social ties that are not easily reproducible in primary care. Behavioral counseling was broadly defined to include interventions such as counseling or education that included but was not limited to assessment with feedback, motivational interviewing, advice, collaborative goal-setting, and exercise prescriptions.

Interventions could be delivered in various modes, including in person, with print materials, or by telephone or computer, and could be delivered by a number of potential interventionists, such as physicians, nurses, exercise specialists, dietitians, nutritionists, or behavioral health specialists. We excluded interventions focused on supervised exercise or controlled diets as well as those that focused on stress management techniques, such as meditation or yoga. We included only studies that included the following controls: no intervention (including wait list or usual care), minimal intervention (e.g., usual care limited to approximately 15 minutes or less of contact or generic brochures), or attention controls (e.g., similar format and intensity but different content). We excluded studies that evaluated the comparative effectiveness of two active interventions without the addition of a true control group. Additionally, we excluded trials in which the control group was specifically asked not to change their diet or physical activity behaviors. For the greatest applicability to U.S. primary care practice, we included only studies conducted in developed countries, as defined by “very high” development according to the 2018 United Nations Human Development Index.^37^ Finally, due to resource constraints, we included only studies that published their results in English.

Two reviewers independently reviewed titles and abstracts for potential inclusion, and two reviewers reviewed the full-text articles. Discrepancies were resolved by discussion and third party consultation as needed. Title and abstract and full-text review were conducted in DistillerSR (Evidence Partners, Ottawa, Canada). We kept detailed records of all included and excluded studies (and the reason for their exclusion) during full-text review.

## Quality Assessment and Data Abstraction

For the new literature, at least two reviewers applied USPSTF design-specific criteria (Appendix A Table 2) to assess the methodological quality of all eligible studies.^34^ We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were reviewed and discussed; a third reviewer adjudicated as needed. Good-quality studies were those that met nearly all of the specified quality criteria (e.g., comparable groups were assembled initially and maintained throughout the study and followup was ≥80%), whereas fair-quality studies did not meet these criteria but did not have serious threats to their internal validity related to the design, execution, or reporting of the study. Studies rated as poor-quality had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%); differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; or issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting, inappropriate exclusion of participants from analyses, and questionable validity of randomization and allocation concealment procedures). Studies rated as poor-quality were excluded from the review. As the quality assessment was an update of our own work, we did not repeat critical appraisal of the original studies through full dual-quality rating.

For all of the included studies, one reviewer extracted key elements into standardized abstraction forms in Microsoft Access® 2016 (Microsoft, Redmond, WA). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics of the study (e.g., author, year, study design), clinical and demographic characteristics of the sample and setting (e.g., age, race/ethnicity, baseline clinical characteristics, setting, country), analytic methods, and results.

For intervention characteristics, we abstracted detailed information about specific components: duration, number, and length of sessions; group or one-on-one delivery; mode of delivery (i.e., in person, telephone, electronic, or print); providers and provider training; and setting. We used methods consistent with the previous reviews on this topic to estimate and categorize the intensity (or “contact time”) of each intervention.

To calculate the total intensity of an intervention, we multiplied the number of sessions by the length of the respective sessions and estimated the total number of minutes. For example, a 12-month intervention consisting of eight 1-hour group sessions would have been calculated as 8 × 60 = 480 minutes. We categorized an intervention as low intensity if the number of minutes was estimated to be 30 or fewer, medium intensity if the number of minutes was 31 to 360, and high intensity if the number of minutes was greater than 360. Interventions that consisted of only print materials were categorized as low intensity. We abstracted the number of sessions and length of sessions according to what was planned (and not necessarily implemented). When reported, we abstracted actual adherence or implementation of the intervention and documented that as well. If a study did not report the length of sessions, we estimated the following: individual counseling session as 30 minutes, group counseling session as 60 minutes, telephone sessions as 15 minutes, computer-based sessions as 15-30 minutes, e-mails as 1-2 minutes, and text messages as 1 minute or less.

We noted the theoretical basis of the intervention where reported and used the description of the intervention to judge the specific behavior change techniques that were used (e.g., goals and planning, feedback and monitoring, self-belief) according to the taxonomy of Michie et al.^38^ for behavior change techniques.

## Data Synthesis and Analysis

We synthesized data separately for each KQ. The data on health outcomes (KQ 1) and adverse events (KQ 4) did not allow for quantitative pooling due to the limited number of contributing studies and the variability in outcomes measured, so we summarized those data in tables and narratively. For intermediate health outcomes (KQ 2) and behavioral outcomes (KQ 3), random-effects meta-analyses were performed to account for the variability of the studies.^39^ Due to either high statistical heterogeneity (commonly I^2^>50) or small number of trials to be pooled, restricted maximum likelihood method with the Knapp-Hartung correction was applied in meta-analyses.^40,^ ^41^ Crude effect estimates were calculated if between-group results were not reported and, we favored adjusted over unadjusted effect estimates. Within each study, we chose followup time point closest to 12 months. If there were multiple followup assessments, we favored 6 months over 18 months. We presented the results of other time points in tabular format. If a trial had more than one active intervention arm, we plotted the most intensive arm or the arm that was the most similar with other interventions included in the analysis (all denoted as intervention group 1 [IG1]). Among trials that reported both intermediate and behavioral outcomes, we examined the concordance and discordance in the size and precision of effects to examine consistency within each study.

Because we included different measures in the pooled analyses for continuous measures of physical activity, saturated fat, fiber, and sedentary, we pooled standardized mean differences in change between groups. We also conducted analyses limited to only studies that reported similar measures (e.g., minutes per week of physical activity, percent of energy from saturated fat) and found that the standardized pooled effects were very similar to analyses that included trials reporting other measures, indicating that confounding by measurement is minimal or absent.

We generated funnel plots to evaluate small-study effects (a possible indication of publication bias) and performed the Egger’s (for continuous data) or Peters’ test (for binary data) to assess the statistical significance of imbalance in study size as well as findings that suggest a pattern by study size.^42,^ ^43^ We also performed sensitivity analyses to examine whether the overall findings for each outcome were robust to influential age groups (i.e., removing studies limited to older adults), imputed standard deviations, and adjusting for clustering within cluster randomized trials. None of the results were sensitive to these modifications and are not discussed further.

We used visual displays and tables grouped and sorted by potentially important characteristics to investigate whether variability among the results was associated with any prespecified study, population, or intervention characteristics. Specifically, we examined study quality (good vs. fair), link to primary care (conducted in or recruited from primary care vs. not), conducted in USA or not, based on population selection/unselected for a demographic factor versus suboptimal behavior (e.g., sedentary, poor diet) versus other (e.g., obesity, family history), intervention focus (healthy diet only, physical activity only, healthy diet and physical activity), intervention intensity (as continuous in minutes; high vs. medium vs. low intensity), intervention duration (as continuous in weeks), number of intervention sessions, total in person contacts, and setting (e.g., remote only or print materials only). We used meta-regression and subgroup analyses to examine whether there were study, population, or intervention characteristics that were associated with effect size for systolic and diastolic blood pressure, LDL-C, fasting glucose, BMI, weight and physical activity.

We used Stata 16.1 (StataCorp LLC, College Station, TX). All significance testing was 2-sided, and results were considered statistically significant if the p-value was 0.05 or less.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center approach,^44^ which is based on a system developed by the Grading of Recommendations Assessment, Development, and Evaluation Working Group.^45^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., whether the evidence links the interventions directly to a health outcome). We supplemented the four domains with the additional domain of dose-response association, given our a priori hypothesis that larger effects may be seen with greater intensity (or exposure) of interventions. Evidence of a dose-response association either across or within studies may warrant increasing the overall strength of evidence.

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). The body of evidence limitations field highlights important restrictions in answering the overall KQ (e.g., suspected reporting bias, lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, low, or insufficient.^44^ “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. We developed our overall strength of evidence grade based on consensus discussion involving at least two reviewers.

## Expert Review and Public Comment

A draft research plan was posted on the USPSTF website for public comment from February 20, 2020 to March 18, 2020. The USPSTF received comments from 14 unique respondents which included voices from two federal partners (CDC and NIH), seven unique professional societies or advocacy organizations (American Geriatrics Society, American Heart Association, American Medical Association, American Psychological Association, National Center for Health Research, Physical Activity Alliance, and WW [formerly Weight Watchers]), and individual clinicians and citizens. No substantive changes were made to the research plan. Minor changes were made and clarifying text was added as appropriate. A final research plan was posted on the USPSTF website on June 4, 2020.

The draft version of this report was reviewed by four invited experts and seven individuals at three USPSTF Federal Partner agencies. Experts were selected based on their expertise with fundamental methodologic and content aspects of the review (i.e., nutrition, physical activity, epidemiology) and were selected to obtain diverse informed perspectives. All expert comments were considered, and selected comments from experts were used to clarify and extend the synthesis of evidence to ensure accuracy and address scientifically relevant concerns. All comments were shared with members of the USPSTF and the Agency for Healthcare Research and Quality. Finally, a draft report was posted for public comment on the AHRQ website from January 18 to February 15, 2022. Additional minor modifications were made in response to comments received, including some added detail, minor clarifications, and mention of additional evidence limitations.

## USPSTF Involvement

We worked with four USPSTF members at key points throughout this review, particularly when determining the scope and methods for this review and developing the Analytic Framework and KQs. After revisions reflecting the public comment period, the USPSTF members approved the final analytic framework, KQs, and inclusion and exclusion criteria. The Agency for Healthcare Research and Quality funded this review under a contract to support the work of the USPSTF. An Agency Medical Officer provided project oversight, reviewed the draft report, and assisted in the external review of the report.