# Chapter 1 Introduction

## Purpose

In 2017, the United States Preventive Services Task Force (USPSTF) recommended that primary care professionals individualize the decision to offer or refer adults without obesity who do not have CVD risk factors to behavioral counseling to promote a healthful diet and physical activity (C Grade).^1^ The current review is an update of the 2017 review^2,^ ^3^ that supported that recommendation and will be used by the USPSTF to update this recommendation. The objective of this report is to synthesize the evidence on the benefits and harms of behavioral counseling on healthy diet and physical activity among adults without CVD risk factors.

For the purposes of this review, adults not at high risk for CVD were defined as those without known hypertension or elevated blood pressure, dyslipidemia or elevated lipids, impaired fasting glucose/impaired glucose tolerance, diabetes, metabolic syndrome, or at high risk according to risk equations. This review, therefore, represents studies among adults: 1) with unknown risk (i.e., unselected adults) or 2) those explicitly without these risk factors. Studies among adults who are overweight or have obesity (without other known CVD risk factors) are included within this review.

A separate USPSTF review^4,^ ^5^ and recommendation^6^ address behavioral counseling interventions in adults with known risk factors. Additionally, the USPSTF maintains several other reviews and recommendations associated with preventing CVD including interventions related to tobacco cessation,^7^ weight loss,^8^ aspirin use,^9^ statin use,^10^ and screening for and treatment of high or abnormal levels of blood pressure,^11^ and glucose.^12^ The recommendations related to behavioral counseling in adults with risk factors, those with abnormal blood glucose levels or diabetes, and those with obesity are particularly inter-related and are shown in Table 1.

Table 1 Related USPSTF Behavioral Counseling Interventions

Risk Factors | Normal Weight (BMI 18.5 to <25)^*^ | Overweight (BMI 25 to <30)^*^ | Obese (BMI ≥30)^*^
No hypertension, dyslipidemia, or abnormal blood glucose levels | Individualize the decision to provide or refer to behavioral counseling^†^,^214^ | Individualize the decision to provide or refer to behavioral counseling^†^,^214^ | Provide or refer to intensive, multicomponent behavioral counseling^215^
Hypertension, dyslipidemia, or both | Provide or refer to intensive behavioral counseling^6^ | Provide or refer to intensive behavioral counseling^6^ | Provide or refer to intensive, multicomponent behavioral counseling^215^
Prediabetes or diabetes | Provide or refer to effective behavioral counseling^§^,^216^ | Provide or refer to effective behavioral counseling^216^ | Provide or refer to effective behavioral counseling^216^

* BMI calculated as weight in kilograms divided by the square of height in meters.

† The evidence review that supports this recommendation statement did include studies that enrolled persons with overweight or obesity. A separate recommendation statement addresses individuals with a BMI of 30 or greater.

§ The USPSTF recommends screening for prediabetes and diabetes as part of cardiovascular risk assessment in adults aged 35 to 70 years who have overweight or obesity. Clinicians should consider screening at an earlier age in persons from groups with disproportionately high incidence and prevalence of diabetes (American Indian/Alaska Native, Asian American, Black, Hispanic/Latino, or Native Hawaiian/Pacific Islander persons) or in persons who have a family history of diabetes, a history of gestational diabetes, or a history of polycystic ovarian syndrome, and at a lower BMI in Asian American persons.

Abbreviations: BMI=body mass index; USPSTF=U.S. Preventive Services Task Force.

## Condition Definition

### Healthy Diet

A healthy eating pattern accounts for all foods and beverages within an appropriate calorie level, including consuming a variety of vegetables (from all of the subgroups including dark green, red and orange, starchy, and other), fruits (especially whole fruits), grains (at least half of which are whole grains), fat-free or low-fat dairy, a variety of protein foods, and oils and limiting saturated fats and trans fats, added sugar, and sodium.^13^

### Physical Activity

Physical activity is any bodily activity that enhances or maintains overall health and physical fitness. The 2018 U.S. physical activity guidelines emphasize that adults should move more and sit less throughout the day and that some physical activity is better than none.^14^ For substantial health benefits, the guideline suggests that adults do at least 150 minutes to 300 minutes a week of moderate-intensity, or 75 minutes to 150 minutes a week of vigorous-intensity aerobic physical activity, or an equivalent combination of moderate- and vigorous-intensity aerobic activity. Adults should also do muscle-strengthening activities of moderate or greater intensity and that involve all major muscle groups on 2 or more days a week and older adults are also encouraged to incorporate balance training as well as aerobic and muscle-strengthening activities.

### Sedentary Behavior

Sedentary behavior refers to any waking behavior characterized by a low level of energy expenditure (less than 1.5 metabolic equivalents of task [METs]) while sitting, reclining, or lying such as watching television, using a computer, and sitting in a car.^14^ The 2018 U.S. physical activity guidelines advisory committee found a strong relationship between time in sedentary behavior and the risk of all-cause mortality and CVD mortality in adults.^15^ However, there is no specific target for adults for how many times during the day sedentary time should be interrupted or a healthy target for total sedentary time.

## Burden and Prevalence of CVD and Risk Factors

CVD, including heart, ischemic heart disease, and stroke, is the leading cause of death in the United States for both men and women, and for most races and ethnicities including Hispanic, Black, and white adults.^16,^ ^17^ In 2016, CVD was the underlying cause of 840,678—or 1 in 3—deaths among US adults.^18^ Of these deaths, approximately 43 percent were due to coronary heart disease and 17 percent were the result of stroke.^16^ This pattern is expected to continue with an estimated 23.3 million deaths from CVDs worldwide (primarily from heart disease and stroke) projected by 2030.^19^ The American Heart Association estimates that by 2035, approximately 45 percent of adults in the US will have some form of CVD.^16^

Risk factors for CVD are well-established, multicomponent, and common in adults. While many of the CVD risk factors are nonmodifiable (age, sex, family history, and race and ethnicity) many are modifiable and can be changed or treated. Modifiable risk factors include: dyslipidemia or hyperlipidemia (referred to as dyslipidemia in this report), hypertension, high fasting plasma glucose level, overweight and obesity, smoking, lack of physical activity, sedentary behavior, and unhealthy diet.^18,^ ^20,^ ^21^ The CDC estimates that nearly half (47%) of all US adults age 20 years or older have at least one of the following CVD risk factors: uncontrolled hypertension, uncontrolled elevated low-density lipoprotein (LDL) cholesterol level, or current smoking.^21^ Prevalence of risk factors as defined by the American Heart Association’s (AHA) “Life’s Simple 7” are presented by age group in Table 2.

Table 2 Prevalence Estimates of Ideal Cardiovascular Health for Each of the Seven Metrics of Cardiovascular Health in the AHA 2020 Goals Among U.S. Adults

Measure | Definition of Ideal Cardiovascular Health | Adults 20-49 Years, % | Adults ≥50 Years, %
Current Smoking | Never or quit >12 months | 76.6 | 81.6
BMI | <25 kg/m^2^ | 32.0 | 24.4
Physical Activity | ≥150 min/wk MPA or ≥75 min/wk VPA | 49.2 | 30.3
Healthy Diet Score | AHA Diet Score 4-5^*^ | 0.1 | 0.5
Total Cholesterol | <200 mg/dL | 64.6 | 27.2
Blood Pressure | <120 mm Hg/<80 mm Hg | 55.1 | 19.9
Fasting Plasma Glucose | <100 mg/dL | 72.8 | 36.7

* Meeting 4 to 5 of the following dietary targets: ≥4.5 cups/day fruits and vegetables, 2 or more 3.5-oz servings/week fish and shellfish, ≤1500 mg/day sodium, ≤36 oz/week sugar sweetened beverages, 3 or more 1-oz servings/day whole grains.

Abbreviations: AHA=American Heart Association; BMI=body mass index; dL=deciliter; m=meter(s); mg=milligram(s); min=minute(s); mmHg=millimeters of mercury; MPA=moderate-intensity physical activity; oz=ounce; wk=week; VPA=vigorous-intensity physical activity.

Adapted from Virani et al., 2020^16,^ ^217^

There is a marked disparity in diet and physical activity behaviors by important subpopulations. People of lower socioeconomic status or those with lower educational attainment tend to be less active, eat fewer fruits and vegetables, and eat fewer foods rich in dietary fiber when compared with people in a higher socioeconomic position or with higher educational attainment.^22–26^ Non-white adults tend to exercise less than White adults,^22,^ ^23^ and Black adults consume fewer servings of fruits and vegetables than white adults.^24–26^ Physical activity rates are lower in older vs. younger people and women vs. men.^22,^ ^23^ Structural and environmental barriers such as the nonavailability of healthy eating establishments or grocery stores, parks, sidewalks, bicycle trails, or safe and pleasant walking paths close to home or the workplace; traffic; the availability of public transportation; crime; and pollution may affect individuals’ perceived or real ability to be more active and adopt healthful eating behaviors and contribute to these differences in healthful behaviors.

## Behavioral Counseling Interventions for CVD Primary Prevention

Behavioral interventions to improve diet, physical activity, and sedentary behavior encompass a wide range of strategies that may be available within, feasible for, or referable from primary care.^3^ These interventions can take different formats, including brief counseling by a primary care provider, with or without accompanying materials or followup counseling; mailed, print-based interventions with tailored feedback; individual or group counseling; telephone counseling with no in-person contact; or computer-based interventions, including web-based sessions, email, or mobile technology. Behavioral counseling interventions can be delivered by a primary care provider, health educator, behavioral health specialist, nutritionist or dietitian, exercise specialist, peers, or health coaches. Behavior change techniques employed in these interventions can include a broad range of activities, including goal-setting and planning, monitoring and feedback through food and activity logs or pedometers, increasing efficacy and motivation for behavioral change (including using motivational interviewing), addressing barriers to change, social support, and general education and advice regarding the benefits of healthy eating, physical activity, or reduced sedentary time. Many interventions focused on lifestyle changes also encourage weight loss among patients with excess weight.^3,^ ^5^

## Recommendations From Other Groups on Healthy Diet and Physical Activity Counseling

The 2017 USPSTF recommendation that healthcare providers should individualize the decision to offer or refer adults to behavioral counseling to promote a healthful diet and physical activity is referred to and affirmed by the American Academy of Family Physicians (AAFP).^27^ Similarly, the National Institute for Health and Care Excellence (NICE) recommends that the decision to assess patients’ physical activity levels and offer behavioral counseling should be based on the professional judgment of the healthcare provider.^28^ However, numerous other organizations, including the American College of Sports Medicine (ACSM), American Heart Association (AHA), U.S. Department of Health and Human Services (HHS), and Department of Veterans Affairs (VA),^29^ recommend that healthcare providers provide behavioral counseling on diet and physical activity to all of their adult patients, irrespective of chronic conditions or risk factors. The 2018 “Exercise is Medicine” initiative, developed by the ACSM and American Medical Association and endorsed by the AHA, calls for healthcare providers to review and assess every patient’s physical activity level (e.g., physical activity as a vital sign), with office visits concluding with an exercise prescription or referral to a qualified health and fitness professional for further counseling.^30^

## Current Clinical Practice in the United States

In the United States, 62 percent of adults report consulting a primary care provider in the past year, with an average of 3.2 visits per year,^31^ and fewer than half report receiving counseling related to healthy diet, nutrition, or physical activity.^32^ According to 2011–2016 data from the National Health and Nutrition Examination Survey (NHANES), lifestyle counseling provided by health care providers is generally low among all adults, but is more common for adults with higher body mass index and chronic conditions (e.g., elevated blood pressure, elevated cholesterol, type 2 diabetes mellitus).^32,^ ^33^ Among adults without chronic conditions, 20 percent report receiving counseling on exercise and 11 percent report counseling on diet.^32^ In a separate analysis of data among patients with diabetes, from 2005 to 2015, Hispanic patients with diabetes had a higher likelihood of receiving diet or exercise counseling, compared with white patients with diabetes.^33^ Those aged 30–49 years were more likely to receive diet or exercise counseling, compared with those aged >75 years. Compared with rural areas and other providers, visits in a metropolitan area or with an advanced practice provider had higher likelihood of any diet or exercise counseling delivery. Data on rates of counseling by sociodemographic characteristics were not available for patients without diabetes.^33^

## Previous USPSTF Recommendations

In 2017, the United States Preventive Services Task Force (USPSTF) concluded that primary care professionals individualize the decision to offer or refer adults without obesity who do not have hypertension, dyslipidemia, abnormal blood glucose levels, or diabetes to behavioral counseling to promote a healthful diet and physical activity (Grade: C recommendation).^1^ The recommendation went on to say that “Existing evidence indicates a positive but small benefit of behavioral counseling for the prevention of cardiovascular disease (CVD) in this population. Persons who are interested and ready to make behavioral changes may be most likely to benefit from behavioral counseling.”