# Appendices

Appendix A Detailed Methods

Appendix A Figure 1 Literature Flow Diagram

Appendix A Table 1 Inclusion and Exclusion Criteria

Appendix B Included Studies

Appendix C Excluded Studies

Appendix D Table 1 Study and Population Characteristics for All Studies, by Author

Appendix E Table 1 Intervention Characteristics for All Studies, by Author

Appendix E Table 2 Intervention Details for All Studies, by Author

Appendix E Table 3 Intervention Behavioral Targets and Techniques for All Studies, by Author

Appendix F Table 1 Mortality and Cardiovascular Disease Health Outcomes (Key Question 1)

Appendix F Table 2 Quality of Life/Subjective Well-Being Outcomes (Key Question 1)

Appendix G Table 1 Blood Pressure Outcomes (Key Question 2)

Appendix G Table 2 Lipid Outcomes (Key Question 2)

Appendix G Table 3 Glucose Outcomes (Key Question 2)

Appendix G Table 4 Adiposity Outcomes (Key Question 2)

Appendix H Table 1 Dietary Outcomes (Key Question 3)

Appendix H Table 2 Physical Activity Outcomes (Key Question 3)

Appendix H Table 3 Sedentary Behavior Outcomes (Key Question 3)

Appendix I Table 1 Ongoing Studies