# References

1 American Diabetes Association. Classification and diagnosis of diabetes: standards of medical care in diabetes-2020. Diabetes Care. 2020 Jan;43(Suppl 1):S14–S31. doi: 10.2337/dc20-S002. PMID: 31862745.31862745
2 American Diabetes Association. Diagnosis and classification of diabetes mellitus. Diabetes Care. 2013 Jan;36 Suppl 1:S67–74. doi: 10.2337/dc13-S067. PMID: 23264425.23264425
3 Elder DA, Hornung LN, Khoury JC, . Beta-cell function over time in adolescents with new type 2 diabetes and obese adolescents without diabetes. J Adolesc Health. 2017 Dec;61(6):703–8. doi: 10.1016/j.jadohealth.2017.06.007. PMID: 28935388.28935388
4 Weiss R, Caprio S, Trombetta M, . Beta-cell function across the spectrum of glucose tolerance in obese youth. Diabetes. 2005 Jun;54(6):1735–43. doi: 10.2337/diabetes.54.6.1735. PMID: 15919795.15919795
5 Elder DA, Hornung LN, Herbers PM, . Rapid deterioration of insulin secretion in obese adolescents preceding the onset of type 2 diabetes. J Pediatr. 2015 Mar;166(3):672–8. doi: 10.1016/j.jpeds.2014.11.029. PMID: 25557969.25557969
6 Dabelea D, Hamman RF, Knowler WC. Chapter 15. Diabetes in youth. In: Cowie CC, Casagrande SS, Menke A, Cissell MA, Eberhardt MS, Meigs JB, ., eds. Diabetes in America. 3rd ed. Bethesda, MD: National Institutes of Health; 2018.
7 Weiss R, Taksali SE, Tamborlane WV, . Predictors of changes in glucose tolerance status in obese youth. Diabetes Care. 2005 Apr;28(4):902–9. doi: 10.2337/diacare.28.4.902. PMID: 15793193.15793193
8 Wolfsdorf JI, Glaser N, Agus M, . ISPAD clinical practice consensus guidelines 2018: diabetic ketoacidosis and the hyperglycemic hyperosmolar state. Pediatr Diabetes. 2018 Oct;19 Suppl 27:155–77. doi: 10.1111/pedi.12701. PMID: 29900641.29900641
9 Klingensmith GJ, Connor CG, Ruedy KJ, . Presentation of youth with type 2 diabetes in the Pediatric Diabetes Consortium. Pediatr Diabetes. 2016 Jun;17(4):266–73. doi: 10.1111/pedi.12281. PMID: 25951940.25951940
10 Dabelea D, Rewers A, Stafford JM, . Trends in the prevalence of ketoacidosis at diabetes diagnosis: the SEARCH for diabetes in youth study. Pediatrics. 2014 Apr;133(4):e938–45. doi: 10.1542/peds.2013-2795. PMID: 24685959.24685959
11 Rewers A, Klingensmith G, Davis C, . Presence of diabetic ketoacidosis at diagnosis of diabetes mellitus in youth: the Search for Diabetes in Youth Study. Pediatrics. 2008 May;121(5):e1258–66. doi: 10.1542/peds.2007-1105. PMID: 18450868.18450868
12 Canarie MF, Bogue CW, Banasiak KJ, . Decompensated hyperglycemic hyperosmolarity without significant ketoacidosis in the adolescent and young adult population. J Pediatr Endocrinol Metab. 2007 Oct;20(10):1115–24. doi: 10.1515/jpem.2007.20.10.1115. PMID: 18051930.18051930
13 Rosenbloom AL. Hyperglycemic hyperosmolar state: an emerging pediatric problem. J Pediatr. 2010 Feb;156(2):180–4. doi: 10.1016/j.jpeds.2009.11.057. PMID: 20105637.20105637
14 Pavkov ME, Bennett PH, Knowler WC, . Effect of youth-onset type 2 diabetes mellitus on incidence of end-stage renal disease and mortality in young and middle-aged Pima Indians. JAMA. 2006 Jul 26;296(4):421–6. doi: 10.1001/jama.296.4.421. PMID: 16868300.16868300
15 Awa WL, Fach E, Krakow D, . Type 2 diabetes from pediatric to geriatric age: analysis of gender and obesity among 120,183 patients from the German/Austrian DPV database. Eur J Endocrinol. 2012 Aug;167(2):245–54. doi: 10.1530/EJE-12-0143. PMID: 22645200.22645200
16 Liu LL, Lawrence JM, Davis C, . Prevalence of overweight and obesity in youth with diabetes in USA: the SEARCH for Diabetes in Youth study. Pediatr Diabetes. 2010 Feb;11(1):4–11. doi: 10.1111/j.1399-5448.2009.00519.x. PMID: 19473302.19473302
17 Arslanian S, Bacha F, Grey M, . Evaluation and management of youth-onset type 2 diabetes: a position statement by the American Diabetes Association. Diabetes Care. 2018 Dec;41(12):2648–68. doi: 10.2337/dci18-0052. PMID: 30425094.30425094
18 Copeland KC, Zeitler P, Geffner M, . Characteristics of adolescents and youth with recent-onset type 2 diabetes: the TODAY cohort at baseline. J Clin Endocrinol Metab. 2011 Jan;96(1):159–67. doi: 10.1210/jc.2010-1642. PMID: 20962021.20962021
19 Fagot-Campagna A, Pettitt DJ, Engelgau MM, . Type 2 diabetes among North American children and adolescents: an epidemiologic review and a public health perspective. J Pediatr. 2000 May;136(5):664–72. doi: 10.1067/mpd.2000.105141. PMID: 10802501.10802501
20 Pinhas-Hamiel O, Zeitler P. The global spread of type 2 diabetes mellitus in children and adolescents. J Pediatr. 2005 May;146(5):693–700. doi: 10.1016/j.jpeds.2004.12.042. PMID: 15870677.15870677
21 Meigs JB, Cupples LA, Wilson PW. Parental transmission of type 2 diabetes: the Framingham Offspring Study. Diabetes. 2000 Dec;49(12):2201–7. doi: 10.2337/diabetes.49.12.2201. PMID: 11118026.11118026
22 American Diabetes Association. Type 2 diabetes in children and adolescents. Diabetes Care. 2000 Mar;23(3):381–9. doi: 10.2337/diacare.23.3.381. PMID: 10868870.10868870
23 Writing Group for the Search for Diabetes in Youth Study Group, Dabelea D, Bell RA, . Incidence of diabetes in youth in the United States. JAMA. 2007 Jun 27;297(24):2716–24. doi: 10.1001/jama.297.24.2716. PMID: 17595272.17595272
24 Ball GD, Huang TT, Gower BA, . Longitudinal changes in insulin sensitivity, insulin secretion, and beta-cell function during puberty. J Pediatr. 2006 Jan;148(1):16–22. doi: 10.1016/j.jpeds.2005.08.059. PMID: 16423592.16423592
25 Amiel SA, Sherwin RS, Simonson DC, . Impaired insulin action in puberty. A contributing factor to poor glycemic control in adolescents with diabetes. N Engl J Med. 1986 Jul 24;315(4):215–9. doi: 10.1056/NEJM198607243150402. PMID: 3523245.3523245
26 Dabelea D, Mayer-Davis EJ, Saydah S, . Prevalence of type 1 and type 2 diabetes among children and adolescents from 2001 to 2009. JAMA. 2014 May 7;311(17):1778–86. doi: 10.1001/jama.2014.3201. PMID: 24794371.24794371
27 Pinhas-Hamiel O, Dolan LM, Daniels SR, . Increased incidence of non-insulin-dependent diabetes mellitus among adolescents. J Pediatr. 1996 May;128(5 Pt 1):608–15. doi: 10.1016/s0022-3476(96)80124-7. PMID: 8627431.8627431
28 Golden SH, Yajnik C, Phatak S, . Racial/ethnic differences in the burden of type 2 diabetes over the life course: a focus on the USA and India. Diabetologia. 2019 Oct;62(10):1751–60. doi: 10.1007/s00125-019-4968-0. PMID: 31451876.31451876
29 Bailey ZD, Krieger N, Agenor M, . Structural racism and health inequities in the USA: evidence and interventions. Lancet. 2017 Apr 8;389(10077):1453–63. doi: 10.1016/S0140-6736(17)30569-X. PMID: 28402827.28402827
30 Trent M, Dooley DG, Douge J, . The impact of racism on child and adolescent health. Pediatrics. 2019 Aug;144(2)doi: 10.1542/peds.2019-1765. PMID: 31358665.31358665
31 Odoms-Young A, Bruce MA. Examining the impact of structural racism on food insecurity: implications for addressing racial/ethnic disparities. Fam Community Health. 2018 Apr/Jun;41 (Suppl 2 Suppl, Food Insecurity and Obesity):S3–S6. doi: 10.1097/FCH.0000000000000183. PMID: 29461310.29461310
32 Centers for Disease Control and Prevention. National diabetes statistics report, 2020. Centers for Disease Control and Prevention. Atlanta, GA: U.S. Department of Health and Human Services; 2020. https://www.cdc.gov/diabetes/data/statistics/statistics-report.html?CDC_AA_refVal=https%3A%2F%2Fwww.cdc.gov%2Fdiabetes%2Fdata%2Fstatistics-report%2Fdiagnosed.html
33 Pettitt DJ, Talton J, Dabelea D, . Prevalence of diabetes in U.S. youth in 2009: the SEARCH for diabetes in youth study. Diabetes Care. 2014 Feb;37(2):402–8. doi: 10.2337/dc13-1838. PMID: 24041677.24041677
34 Divers J, Mayer-Davis EJ, Lawrence JM, . Trends in incidence of type 1 and type 2 diabetes among youths - selected counties and indian reservations, United States, 2002-2015. MMWR Morb Mortal Wkly Rep. 2020 Feb 14;69(6):161–5. doi: 10.15585/mmwr.mm6906a3. PMID: 32053581.32053581
35 Allen PJ, Vessey JA. Primary care of the child with a chronic condition. 4th ed. St. Louis: Mosby-Yearbook; 2004.
36 Heron M. Deaths: leading causes for 2015. Natl Vital Stat Rep. 2017 Nov;66(5):1–76. PMID: 29235984.29235984
37 Dabelea D, Stafford JM, Mayer-Davis EJ, . Association of type 1 diabetes vs type 2 diabetes diagnosed during childhood and adolescence with complications during teenage years and young adulthood. JAMA. 2017 Feb 28;317(8):825–35. doi: 10.1001/jama.2017.0686. PMID: 28245334.28245334
38 Centers for Disease Control and Prevention. National diabetes fact sheet: national estimates and general information on diabetes and prediabetes in the United States, 2011. Atlanta, GA: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention; 2011.
39 U.S. Burden of Disease Collaborators, Mokdad AH, Ballestros K, . The state of US health, 1990-2016: burden of diseases, injuries, and risk factors among US states. JAMA. 2018 Apr 10;319(14):1444–72. doi: 10.1001/jama.2018.0158. PMID: 29634829.29634829
40 American Diabetes Association. 3. Prevention or delay of type 2 diabetes: standards of medical care in diabetes-2020. Diabetes Care. 2020 Jan;43(Suppl 1):S32–S6. doi: 10.2337/dc20-S003. PMID: 31862746.31862746
41 American Diabetes Association. 8. Obesity management for the treatment of type 2 diabetes: standards of medical care in diabetes-2020. Diabetes Care. 2020 Jan;43(Suppl 1):S89–S97. doi: 10.2337/dc20-S008. PMID: 31862751.31862751
42 American Diabetes Association. 9. Pharmacologic approaches to glycemic treatment: standards of medical care in diabetes-2020. Diabetes Care. 2020 Jan;43(Suppl 1):S98–S110. doi: 10.2337/dc20-S009. PMID: 31862752.31862752
43 Copeland KC, Silverstein J, Moore KR, . Management of newly diagnosed type 2 Diabetes Mellitus (T2DM) in children and adolescents. Pediatrics. 2013 Feb;131(2):364–82. doi: 10.1542/peds.2012-3494. PMID: 23359574.23359574
44 Springer SC, Silverstein J, Copeland K, . Management of type 2 diabetes mellitus in children and adolescents. Pediatrics. 2013 Feb;131(2):e648–64. doi: 10.1542/peds.2012-3496. PMID: 23359584.23359584
45 Lee JM, Gebremariam A, Wu EL, . Evaluation of nonfasting tests to screen for childhood and adolescent dysglycemia. Diabetes Care. 2011 Dec;34(12):2597–602. doi: 10.2337/dc11-0827. PMID: 21953800.21953800
46 Ehehalt S, Wiegand S, Korner A, . Diabetes screening in overweight and obese children and adolescents: choosing the right test. Eur J Pediatr. 2017 Jan;176(1):89–97. doi: 10.1007/s00431-016-2807-6. PMID: 27888412.27888412
47 American Diabetes Association. 13. Children and adolescents: standards of medical care in diabetes-2020. Diabetes Care. 2020 Jan;43(Suppl 1):S163–S82. doi: 10.2337/dc20-S013. PMID: 31862756.31862756
48 Diabetes Canada Clinical Practice Guidelines Expert Committee, Prebtani APH, Bajaj HS, . Reducing the risk of developing diabetes. Can J Diabetes. 2018 Apr;42 Suppl 1:S20–S6. doi: 10.1016/j.jcjd.2017.10.033. PMID: 29650097.29650097
49 American Diabetes Association. 5. Prevention or delay of type 2 diabetes: standards of medical care in diabetes-2018. Diabetes Care. 2018 Jan;41(Suppl 1):S51–S4. doi: 10.2337/dc18-S005. PMID: 29222376.29222376
50 Khokhar A, Umpaichitra V, Chin VL, . Metformin use in children and adolescents with prediabetes. Pediatr Clin North Am. 2017 Dec;64(6):1341–53. doi: 10.1016/j.pcl.2017.08.010. PMID: 29173789.29173789
51 Centers for Disease Control and Prevention. Prevent type 2 diabetes in kids. 2017. https://www.cdc.gov/diabetes/prevent-type-2/type-2-kids.html.
52 National Collaborating Centre for Women’s and Children’s Health (UK). Diabetes (type 1 and type 2) in children and young people: diagnosis and management. National Institute for Health and Care Excellence (UK). London: 2015. https://www.ncbi.nlm.nih.gov/books/NBK315806/
53 Zeitler P, Hirst K, Pyle L, . A clinical trial to maintain glycemic control in youth with type 2 diabetes. N Engl J Med. 2012 Jun 14;366(24):2247–56. doi: 10.1056/NEJMoa1109333. PMID: 22540912.22540912
54 American Diabetes Association. 13. Children and adolescents: standards of medical care in diabetes-2019. Diabetes Care. 2019 Jan;42(Suppl 1):S148–S64. doi: 10.2337/dc19-S013. PMID: 30559239.30559239
55 Miles JM, Leiter L, Hollander P, . Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002 Jul;25(7):1123–8. doi: 10.2337/diacare.25.7.1123. PMID: 12087008.12087008
56 U.S. Preventive Services Task Force. Procedure manual. Rockville, MD: U.S. Preventive Services Task Force,; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
57 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
58 TODAY Study Group. Safety and tolerability of the treatment of youth-onset type 2 diabetes: the TODAY experience. Diabetes Care. 2013 Jun;36(6):1765–71. doi: 10.2337/dc12-2390. PMID: 23704676.23704676
59 TODAY Study Group. Design of a family-based lifestyle intervention for youth with type 2 diabetes: the TODAY study. Int J Obes (Lond). 2010 Feb;34(2):217–26. doi: 10.1038/ijo.2009.195. PMID: 19823189.19823189
60 Levitt Katz L, Gidding SS, Bacha F, . Alterations in left ventricular, left atrial, and right ventricular structure and function to cardiovascular risk factors in adolescents with type 2 diabetes participating in the TODAY clinical trial. Pediatr Diabetes. 2015 Feb;16(1):39–47. doi: 10.1111/pedi.12119. PMID: 24450390.24450390
61 Zeitler P, Epstein L, Grey M, . Treatment options for type 2 diabetes in adolescents and youth: a study of the comparative efficacy of metformin alone or in combination with rosiglitazone or lifestyle intervention in adolescents with type 2 diabetes. Pediatr Diabetes. 2007 Apr;8(2):74–87. doi: 10.1111/j.1399-5448.2007.00237.x. PMID: 17448130.17448130
62 Kelsey MM, Geffner ME, Guandalini C, . Presentation and effectiveness of early treatment of type 2 diabetes in youth: lessons from the TODAY study. Pediatr Diabetes. 2016 May;17(3):212–21. doi: 10.1111/pedi.12264. PMID: 25690268.25690268
63 Jones KL, Arslanian S, Peterokova VA, . Effect of metformin in pediatric patients with type 2 diabetes: a randomized controlled trial. Diabetes Care. 2002 Jan;25(1):89–94. doi: 10.2337/diacare.25.1.89. PMID: 11772907.11772907
64 Savoye M, Caprio S, Dziura J, . Reversal of early abnormalities in glucose metabolism in obese youth: results of an intensive lifestyle randomized controlled trial. Diabetes Care. 2014 Feb;37(2):317–24. doi: 10.2337/dc13-1571. PMID: 24062325.24062325
65 TODAY Study Group. Treatment effects on measures of body composition in the TODAY clinical trial. Diabetes Care. 2013 Jun;36(6):1742–8. doi: 10.2337/dc12-2534. PMID: 23704673.23704673
66 Marcus MD, Wilfley DE, El Ghormli L, . Weight change in the management of youth-onset type 2 diabetes: the TODAY clinical trial experience. Pediatr Obes. 2017 Aug;12(4):337–45. doi: 10.1111/ijpo.12148. PMID: 27161901.27161901
67 Jonas DE, Crotty K, Yun JDY, . Screening for prediabetes and type 2 diabetes: updated evidence report and systematic review for the U.S. Preventive Services Task Force. JAMA. 2021 Aug 24;326(8):744–60. doi: 10.1001/jama.2021.10403. PMID: 34427595.34427595
68 Vajravelu ME, Lee JM, Shah R, . Association between prediabetes diagnosis and body mass index trajectory of overweight and obese adolescents. Pediatr Diabetes. 2020 Aug;21(5):743–6. doi: 10.1111/pedi.13028. PMID: 32314478.32314478
69 Diabetes Canada Clinical Practice Guidelines Expert Committee, Panagiotopoulos C, Hadjiyannakis S, . Type 2 diabetes in children and adolescents. Can J Diabetes. 2018 Apr;42 Suppl 1:S247–S54. doi: 10.1016/j.jcjd.2017.10.037. PMID: 29650104.29650104
70 Zeitler P, Fu J, Tandon N, . ISPAD clinical practice consensus guidelines 2014. Type 2 diabetes in the child and adolescent. Pediatr Diabetes. 2014 Sep;15 Suppl 20:26–46. doi: 10.1111/pedi.12179. PMID: 25182306.25182306
71 Kapadia C, Zeitler P, Drugs, . Hemoglobin A1c measurement for the diagnosis of Type 2 diabetes in children. Int J Pediatr Endocrinol. 2012 Dec 20;2012(1):31. doi: 10.1186/1687-9856-2012-31. PMID: 23256825.23256825
72 Buse JB, Kaufman FR, Linder B, . Diabetes screening with hemoglobin A(1c) versus fasting plasma glucose in a multiethnic middle-school cohort. Diabetes Care. 2013 Feb;36(2):429–35. doi: 10.2337/dc12-0295. PMID: 23193207.23193207
73 Galderisi A, Giannini C, Weiss R, . Trajectories of changes in glucose tolerance in a multiethnic cohort of obese youths: an observational prospective analysis. Lancet Child Adolesc Health. 2018 Oct;2(10):726–35. doi: 10.1016/s2352-4642(18)30235-9. PMID: 30236381.30236381
74 Vijayakumar P, Nelson RG, Hanson RL, . HbA1c and prediction of the type 2 diabetes in children and adults. Diabetes Care. 2017 Jan;40(1):16–21. doi: 10.2337/dc16-1358. PMID: 27810987.27810987
75 Tamborlane WV, Barrientos-Pérez M, Fainberg U, . Liraglutide in children and adolescents with type 2 diabetes. N Engl J Med. 2019 Aug 15;381(7):637–46. doi: 10.1056/NEJMoa1903822. PMID: 31034184.31034184
76 TODAY Study Group. Postintervention effects of varying treatment arms on glycemic failure and β-cell function in the TODAY Trial. Diabetes Care. 2021 Jan;44(1):75–80. doi: 10.2337/dc20-0622. PMID: 33290248.33290248
77 TODAY Study Group. Rapid rise in hypertension and nephropathy in youth with type 2 diabetes: the TODAY clinical trial. Diabetes Care. 2013 Jun;36(6):1735–41. doi: 10.2337/dc12-2420. PMID: 23704672.23704672
78 Today Study Group. Retinopathy in youth with type 2 diabetes participating in the TODAY clinical trial. Diabetes Care. 2013 Jun;36(6):1772–4. doi: 10.2337/dc12-2387. PMID: 23704677.23704677
79 Cali AM, Pierpont BM, Taksali SE, . Rosiglitazone improves glucose metabolism in obese adolescents with impaired glucose tolerance: a pilot study. Obesity (Silver Spring). 2011 Jan;19(1):94–9. doi: 10.1038/oby.2010.109. PMID: 20467418.20467418
80 Kaar JL, Schmiege SJ, Drews K, . Evaluation of the longitudinal change in health behavior profiles across treatment groups in the TODAY clinical trial. Pediatr Diabetes. 2020;21(2):224–32. doi: 10.1111/pedi.12976. PMID: CN-02233381.31886931
81 Hitt JM, Velasquez-Mieyer P, Neira C, . Factors affecting hemoglobin A1C in the diagnosis of diabetes and prediabetes in youth. J Pediatr Nurs. 2016 Sep–Oct;31(5):511–8. doi: 10.1016/j.pedn.2016.03.020. PMID: 27132801.27132801
82 Tester J, Sharma S, Jasik CB, . Gender differences in prediabetes and insulin resistance among 1356 obese children in Northern California. Diabetes Metab Syndr. 2013 Jul–Sep;7(3):161–5. doi: 10.1016/j.dsx.2013.06.002. PMID: 23953182.23953182
83 Kim MS, Jo DS, Lee DY. Comparison of HbA1c and OGTT for the diagnosis of type 2 diabetes in children at risk of diabetes. Pediatr Neonatol. 2019 Aug;60(4):428–34. doi: 10.1016/j.pedneo.2018.11.002. PMID: 30497969.30497969
84 Yoon JS, So CH, Lee HS, . Glycated hemoglobin A1c as a screening test for detecting type 2 diabetes mellitus in obese children and adolescents. J Pediatr Endocrinol Metab. 2018 Apr 25;31(5):503–6. doi: 10.1515/jpem-2017-0463. PMID: 29652667.29652667
85 Chan CL, Pyle L, Kelsey M, . Screening for type 2 diabetes and prediabetes in obese youth: evaluating alternate markers of glycemia - 1,5-anhydroglucitol, fructosamine, and glycated albumin. Pediatr Diabetes. 2016 May;17(3):206–11. doi: 10.1111/pedi.12258. PMID: 25652226.25652226
86 Galhardo J, Shield J. The role of haemoglobin A1c in screening obese children and adolescents for glucose intolerance and type 2 diabetes. Acta Med Port. 2015 May–Jun;28(3):307–15. PMID: 26421782.26421782
87 Brar PC, Mengwall L, Franklin BH, . Screening obese children and adolescents for prediabetes and/or type 2 diabetes in pediatric practices: a validation study. Clin Pediatr (Phila). 2014 Jul;53(8):771–6. doi: 10.1177/0009922814528571. PMID: 24671874.24671874
88 Barry E, Roberts S, Oke J, . Efficacy and effectiveness of screen and treat policies in prevention of type 2 diabetes: systematic review and meta-analysis of screening tests and interventions. BMJ. 2017 Jan 4;356:i6538. doi: 10.1136/bmj.i6538. PMID: 28052845.28052845
89 Hannon TS, Dugan TM, Saha CK, . Effectiveness of computer automation for the diagnosis and management of childhood type 2 diabetes: a randomized clinical trial. JAMA Pediatr. 2017 Apr 1;171(4):327–34. doi: 10.1001/jamapediatrics.2016.4207. PMID: 28192551.28192551
90 Biondich PG, Downs SM, Anand V, . Automating the recognition and prioritization of needed preventive services: early results from the CHICA system. AMIA Annu Symp Proc. 2005:51–5. PMID: 16779000.16779000
91 Anand V, Biondich PG, Liu G, . Child Health Improvement through Computer Automation: the CHICA system. Stud Health Technol Inform. 2004;107(Pt 1):187–91. PMID: 15360800.15360800
92 Downs SM, Biondich PG, Anand V, . Using Arden Syntax and adaptive turnaround documents to evaluate clinical guidelines. AMIA Annu Symp Proc. 2006:214–8. PMID: 17238334.17238334
93 Carroll AE, Biondich PG, Anand V, . Targeted screening for pediatric conditions with the CHICA system. J Am Med Inform Assoc. 2011 Jul–Aug;18(4):485–90. doi: 10.1136/amiajnl-2011-000088. PMID: 21672910.21672910
94 Anand V, Carroll AE, Biondich PG, . Pediatric decision support using adapted Arden Syntax. Artif Intell Med. 2018 Nov;92:15–23. doi: 10.1016/j.artmed.2015.09.006. PMID: 26547523.26547523
95 DuBose KD, Cummings DM, Imai S, . Development and validation of a tool for assessing glucose impairment in adolescents. Prev Chronic Dis. 2012;9:E104. doi: 10.5888/pcd911_0213. PMID: 22632741.22632741
96 Koopman RJ, Mainous AG, 3rd, Everett CJ, . Tool to assess likelihood of fasting glucose impairment (TAG-IT). Ann Fam Med. 2008 Nov–Dec;6(6):555–61. doi: 10.1370/afm.913. PMID: 19001309.19001309
97 Charlson ME, Pompei P, Ales KL, . A new method of classifying prognostic comorbidity in longitudinal studies: development and validation. J Chronic Dis. 1987;40(5):373–83. doi: 10.1016/0021-9681(87)90171-8. PMID: 3558716.3558716
98 Gray LJ, Brady EM, Albaina O, . Evaluation and refinement of the PRESTARt tool for identifying 12-14 year olds at high lifetime risk of developing type 2 diabetes compared to a clinicians assessment of risk: a cross-sectional study. BMC Endocr Disord. 2019 Jul 25;19(1):79. doi: 10.1186/s12902-019-0410-3. PMID: 31345191.31345191