# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; current and former members of the U.S. Preventive Services Task Force; expert reviewers Callie L. Brown, MD, MPH, Wake Forest University School of Medicine; Sheela N. Magge, MD, MSCE, Johns Hopkins University School of Medicine; Hanna Xu, MD, Cook County Health, Illinois; Federal partners from the Centers for Disease Control and Prevention, Eunice Kennedy Shriver National Institute of Child Health and Human Development, and National Institute of Diabetes and Digestive and Kidney Diseases; Sharon Barrell, MA, editor; Loraine Monroe, publications specialist; and Carol Woodell, BSPH, EPC Program Manager.