# Chapter 4 Discussion

## Summary of Evidence

Table 6 provides a summary of the main findings in this evidence review organized by KQ along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability. Overall, limited data were eligible for this review, and the strength of evidence was graded as insufficient or low for all KQs.

Table 6 Summary of Evidence on Screening for Prediabetes and Type 2 Diabetes in Children and Adolescents

Key Question and Topic | No. of Studies (k), No. of Participants (n) | Summary of Findings | Consistency and Precision | Study Quality | Limitations (Including Reporting Bias) | Overall Strength of Evidence | Applicability
KQ 1. Benefits of screening | 0, 0 | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 2. Harms of screening | 0, 0 | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 3. Benefits of interventions for screen-detected or recently diagnosed type 2 diabetes and prediabetes | 2 RCTs (7 publications), 781 participants | The TODAY study (n=699) reported no significant difference between groups for renal impairment in youths treated with metformin only vs. metformin plus rosiglitazone vs. metformin plus a lifestyle intervention (0 vs. 1 vs. 1, p=1.00) and no difference for DKA (5 vs. 3 vs. 3, p=0.70, respectively). One smaller trial (n=82) reported that one adolescent with diabetes in the placebo group developed DKA compared with zero in the metformin group. No eligible studies reported other health outcomes. | Consistency unknown (no 2 studies assessed the same comparisons); imprecise | Good: 1; Fair: 1 | Mean followup 3.8 years in TODAY (range 2–6.5 y) likely insufficient to assess health outcomes; followup of 16 weeks in the smaller trial; reporting bias not detected | Insufficient | The TODAY trial enrolled adolescents who were obese (age 10–17 y) with previous or newly diagnosed type 2 diabetes; predominantly nonwhite participants from U.S.; during run-in and prior to randomization, participants had to achieve glycemic control (HbA1c <8%), achieve mastery of diabetes education material, and confirm adherence.
KQ 4. Harms of interventions for type 2 diabetes | 2 RCTs (7 publications), 781 participants | Hypoglycemic events: More youths treated with metformin plus rosiglitazone had repeated mild hypoglycemia than those treated with metformin or metformin plus lifestyle (8.2% vs. 4.3% vs. 3.4%), p=0.05.; Gastrointestinal adverse events: Higher rates with metformin alone and metformin plus lifestyle intervention than with metformin plus rosiglitazone (55.6% vs. 58.1% vs. 42.9%, p=0.002). Higher rates of abdominal pain (25% vs. 12%, P NR) and nausea or vomiting (17% vs. 10%, P NR) for youths treated with metformin for 16 weeks than with placebo.; Infection: Lower rates with metformin plus rosiglitazone than with metformin alone or metformin plus a lifestyle intervention (p=0.005).; Muscle aches or pains: Lower rates with metformin plus rosiglitazone than with metformin alone or metformin plus a lifestyle intervention (p=0.05).; Heart failure: One participant treated with metformin plus rosiglitazone developed heart failure. | Consistency unknown (no 2 studies used similar measures at similar time points for the same comparison); imprecise | Good: 1; Fair: 1 | Included studies assessed different comparisons; reporting bias not detected | Low | Youths who were obese (ages 10–17 y) with previous or newly diagnosed type 2 diabetes; predominantly nonwhite participants from the U.S.
KQ 4. Harms of interventions for prediabetes | 0, 0 | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 5. Interventions for prediabetes to delay or prevent progression to type 2 diabetes | 1 RCT, 75 participants | No participants in the high-contact healthy lifestyle intervention group or the control group developed diabetes over 6 months. | Consistency unknown (single study); imprecise | Fair | Followup duration of 6 months; high attrition; some participants were withdrawn for being started on metformin (n=5); reporting bias not detected | Insufficient | Children ages 10–16 years with BMI >95th percentile and prediabetes (elevated OGTT, 2-h 130–199 mg/dL) seen in a pediatric obesity clinic; high-contact lifestyle intervention with both diet/nutrition and physical activity/exercise components.
KQ 6. Change in health outcomes that results from reduction in diabetes after interventions for prediabetes | 0, 0 | No eligible studies | NA | NA | NA | Insufficient | NA

Abbreviations: BMI=body mass index; DKA=diabetic ketoacidosis; KQ=key question; NA=not applicable; NR=not reported; OGTT=oral glucose tolerance test; RCT=randomized, controlled trial; TODAY=Treatment Options for Type 2 Diabetes in Adolescents and Youth.

### Evidence for Benefit and Harms of Screening

This review found no eligible studies that directly addressed the overarching question (i.e., no studies evaluated screening for prediabetes or type 2 diabetes among asymptomatic youths compared with no screening or alternative screening strategies). Therefore, the strength of evidence was graded as insufficient for KQs 1 and 2.

### Benefits of Interventions for Screen-Detected or Recently Diagnosed Diabetes

For screen-detected diabetes, this review found no eligible studies. For recently diagnosed diabetes, two eligible trials were identified. Evidence from one RCT (TODAY) designed to evaluate intermediate outcomes reported very few health outcomes, finding no difference between groups for renal impairment in adolescents who were obese treated with metformin only versus metformin plus rosiglitazone versus metformin plus a lifestyle intervention, and finding no difference for DKA. The other trial reported that one adolescent with diabetes in the placebo group developed DKA compared with zero in the metformin group. The strength of evidence was graded as insufficient because of unknown consistency, substantial imprecision, and a duration of followup likely insufficient to assess health outcomes.

CQs 2 and 3 (Appendix A) address whether interventions for children and adolescents with screen-detected or recently diagnosed type 2 diabetes or prediabetes change intermediate outcomes. In summary, CQ 2 found that, among those recently diagnosed with type 2 diabetes, lifestyle and pharmacological interventions (metformin, rosiglitazone, liraglutide) improved glycemia, but data were limited or lacking about the impact of pharmacological interventions on other intermediate outcomes (microalbuminuria, subclinical retinopathy, subclinical neuropathy). CQ 3 found that, for those with diabetes, metformin alone and metformin plus a lifestyle intervention were associated with decreases in BMI and weight when compared with metformin plus rosiglitazone in TODAY,^18,^ ^53,^ ^65,^ ^66^ but another study reported that metformin was not associated with significant changes when compared with control.^63^

### Benefits of Interventions for Prediabetes

This review found one eligible trial that assessed whether lifestyle interventions for prediabetes can help prevent progression to type 2 diabetes. However, the strength of evidence was graded as insufficient because followup was only 6 months, results were imprecise (with zero events in either group), consistency is unknown (single study), and the study had high attrition. Among adults who were obese and overweight, recent meta-analyses for the USPSTF found high strength of evidence that lifestyle interventions were associated with reduction in the incidence of diabetes in trials with followup ranging from less than 1 year to 30 years (pooled relative risk, 0.78 [95% confidence interval {CI}, 0.69 to 0.88], 23 trials, 12,915 participants).^67^

CQs 2 and 3 (Appendix A) address whether interventions for children and adolescents with screen-detected or recently diagnosed type 2 diabetes or prediabetes change intermediate outcomes. In summary, CQ 2 found that, among those with prediabetes, lifestyle interventions improved 2-h glucose (after OGTT), but not fasting glucose or A1c in one trial, and data on rosiglitazone were inconclusive because of early trial discontinuation. CQ 3 found that lifestyle interventions for children and adolescents with prediabetes improved weight and BMI compared with controls in one study^64^ and that prediabetes identification was associated with decreases in BMI in adolescents who were obese and overweight, although evidence was from a retrospective cohort study with many limitations and a medium to high risk of bias.^68^

### Harms of Interventions for Prediabetes or Type 2 Diabetes

Low strength of evidence from the two included trials indicates that minor hypoglycemic events were more common among youths treated with metformin plus rosiglitazone than among those treated with metformin or metformin plus lifestyle; GI adverse effects were commonly associated with metformin; and GI adverse events, infections, and muscle aches and pains were more common among youths treated with metformin and metformin plus a lifestyle intervention than with metformin plus rosiglitazone. The strength of evidence was downgraded to low because of imprecision, unknown consistency (studies assessed different comparisons), and one study was rated as medium risk of bias.

## Limitations

This review has limitations. The limitations of the included studies are discussed above in Results and Discussion. Here we focus on limitations of this review. We excluded non-English-language articles. This review was limited to asymptomatic children and focused on the overarching question of screening for prediabetes or type 2 diabetes. This review did not evaluate diagnostic testing of symptomatic children or those with signs of insulin resistance, diagnostic testing of children with conditions associated with insulin resistance, or screening for type 1 diabetes. This review excluded studies limited to or predominately comprising adults or pregnant women and children and adolescents with symptomatic diabetes (e.g., weight loss, polyuria, blurred vision, headache). For studies of recently diagnosed diabetes, this review excluded studies of children and adolescents who had diabetes for more than 1 year or with more advanced diabetes, aiming to identify the studies with good applicability to a screen-detected population.

## Future Research Needs

Screening trials of sufficient duration and sample size that focus on health outcomes are needed, as are eligible studies evaluating interventions for prediabetes and screen-detected type 2 diabetes among children and adolescents.

## Conclusion

No eligible studies directly evaluated the benefits or harms of screening for prediabetes and type 2 diabetes in children and adolescents. For youths with prediabetes or recently diagnosed (not screen-detected) diabetes, the only eligible trials reported few health outcomes and found no difference between groups, although evidence was limited by substantial imprecision and a duration of followup likely insufficient to assess health outcomes. Limited data showed that the combination of rosiglitazone plus metformin was associated with hypoglycemic events (compared with metformin alone or metformin plus lifestyle) and that metformin was associated with gastrointestinal adverse events, consistent with studies conducted in adults.