# Chapter 3 Results

## Literature Search

We identified 4,335 unique records and assessed 524 full-text articles for eligibility (Figure 2). We excluded 516 articles for various reasons, detailed in Appendix C, and included eight articles representing three studies. Details of quality assessments of included studies are in Appendix D Tables 1 through 2.

Figure 2 Summary of Evidence Search and Selection

Note: The sum of the number of studies per KQ exceeds the total number of studies because some studies were applicable to multiple KQs.

Abbreviations: KQ=key question.

Figure 2 is a flow diagram that documents the search and selection of evidence. There were 4,322 unique records identified by searching PubMed (n=2,632), Cochrane Library (n=1,223), and ClinicalTrials.gov (n=467). In addition, 13 records were identified through handsearching. In total, 4,335 titles and abstracts were screened for potential inclusion. Of these, 524 were deemed appropriate for full-text review to determine eligibility. After full-text review, 516 were excluded: 6 for non-English; 236 for ineligible population; 6 for ineligible screening; 32 for ineligible treatment; 61 for ineligible comparison; 76 for ineligible outcome; 2 for ineligible setting; 91 for ineligible study design; 2 for ineligible country; and 4 for being abstracts only. Eight articles representing 3 studies met inclusion criteria. No article was included for Key Question 1 or Key Question 2. Seven articles representing 2 studies were included for Key Question 3 and Key Question 4. One article was included for Key Question 5. No article was included for Key Question 6.

## Results by Key Question

### KQ 1 Is There Direct Evidence That Screening for Type 2 Diabetes and Prediabetes in Asymptomatic Children and Adolescents Improves Health Outcomes?

We found no eligible studies that addressed this question.

### KQ 2 What Are the Harms of Screening for Type 2 Diabetes and Prediabetes in Asymptomatic Children and Adolescents?

We found no eligible studies that addressed this question.

### KQ 3a Do Interventions for Screen-Detected Type 2 Diabetes and Prediabetes Provide an Incremental Benefit in Health Outcomes When Delivered at the Time of Detection Compared With Initiating Interventions Later, After Clinical Diagnosis?

We found no eligible studies that addressed this question.

### KQ 3b Do Interventions for Screen-Detected Type 2 Diabetes and Prediabetes Improve Health Outcomes Compared With No Intervention, Usual Care, or Interventions With Different Treatment Targets?

We found no eligible studies that addressed this question.

### KQ 3c Do Interventions for Recently Diagnosed Type 2 Diabetes Improve Health Outcomes Compared With No Intervention, Usual Care, or Interventions With Different Treatment Targets?

In summary, one included RCT (699 participants) that focused on intermediate outcomes reported that two youths with type 2 diabetes developed renal impairment and 11 developed DKA, finding no significant difference between treatments (metformin, metformin rosiglitazone, and metformin plus a lifestyle intervention). One smaller trial reported that one person in the placebo control group developed DKA. No eligible studies reported on other health outcomes.

#### Characteristics of Included Studies

We included two RCTs (described in 7 articles) (Table 3).^53,^ ^58–63^ One was rated as good quality and one was rated as fair quality. The one good-quality RCT (described in 6 articles) enrolled 699 participants and evaluated interventions for recently diagnosed type 2 diabetes.^53,^ ^58–62^ The Treatment Options for Type 2 Diabetes in Adolescents and Youth (TODAY) study was a 15-site multicenter trial conducted in the United States. The trial randomized adolescents who were obese (BMI ≥85th percentile for age and sex) with recently diagnosed type 2 diabetes to metformin monotherapy, metformin plus rosiglitazone, or metformin plus a lifestyle intervention. Prior to randomization, all participants completed a run-in of 2 to 6 months that involved weaning from nonstudy diabetes medications, initiating metformin at a dose of up to 1,000 mg twice daily, attaining glycemic control with metformin alone (A1c<8.0%), providing standard diabetes education and ensuring the participants’ mastery of the material, and confirming adherence. The mean age of participants was 14; mean BMI was 35 kg/m^2^; mean baseline A1c values were 7.0 to 7.3 percent across the three study groups; 65 percent were female; 79 percent were nonwhite, 32.5 percent were non-Hispanic black, 39.7 percent were Hispanic, and 20.3 percent were non-Hispanic white. The duration of followup ranged from 2 to 6.5 years (mean 3.8 years). The lifestyle intervention focused on diet/nutrition, physical activity, and family support. The program included three phases of in-person contacts: once weekly for the first 6 to 8 months, twice-weekly for months 6 to 8 through months 12 to 16, and then once-monthly until the end of the study. The primary outcome of the trial was loss of glycemic control, defined as HbA1c level of at least 8 percent for 6 months or sustained metabolic decompensation requiring insulin (described in CQ 2), and the study focused largely on intermediate outcomes (e.g., glycemic control, BMI) rather than on health outcomes.

Table 3 Characteristics of Included Randomized Trials of Children and Adolescents With Prediabetes or Type 2 Diabetes (KQs 3, 4, and 5)

First Author, Year | Participants | Groups, No. | Duration of Followup | Duration of Diabetes, Mean (Range or SD), Months | Age, Mean (Range or SD), y | No. (%) F | No. (%) Nonwhite | HbA1C Mean (%)(SD) | BMI, Mean (SD) (kg/m^2^) | Quality
Jones, 2002^63^ | Children (10–16 y) with previous or new diagnosis of type 2 diabetes, BMI >50th percentile for age; 44 sites in multiple countries^*^ | G1: Metformin (titrated up to maximum 2,000 mg/day^†^), 42; G2: Placebo, 40 | 16 weeks | NR | G1: 13.9 (1.8); G2: 13.6 (1.8) | G1: 30 (71.4); G2: 27 (67.5) | G1: 25 (59.5); G2: 27 (67.5) | G1: 8.3 (1.3); G2: 9.0 (1.4) | G1: 34.2 (10.6); G2: 33.9 (12.7) | Fair
TODAY Study Group, 2007, 2010, 2012, 2013, 2015, 2016^53,^ ^58–62^ | Adolescents who were obese (10–17 y) with type 2 diabetes for <2 years, BMI ≥85th percentile for age and sex at 15 clinical centers in the United States | After a run-in of 2 to 6 months^ǂ^; G1: Metformin, 232; G2: Metformin + rosiglitazone 4 mg twice daily, 233; G3: Metformin + lifestyle program, 234 | Mean, 3.8 y (range, 2–6.5 y) | G1: 7.8 (6.0); G2: 8.0 (5.7); G3: 7.6 (5.8) | G1: 14.1 (1.9); G2: 14.1 (2.1); G3: 13.8 (2.0) | G1: NR (63.1); G2: NR (65.7); G3: NR (66.0) | G1: 183 (78.9); G2: 186 (79.8); G3: 188 (80.3) | G1: 7.3 (2.2); G2: 7.0 (2.3); G3: 7.1 (2.2) | G1: 35.8 (8.1); G2: 35.0 (7.7); G3: 34.1 (7.1) | Good
Savoye, 2014^64^ | Adolescents who were obese (10–16 y) with BMI >95th percentile and prediabetes (elevated OGTT, 2-h 130–199 mg/dL) from the Yale Pediatric Obesity Clinic | G1: Bright Bodies Healthy Lifestyle Program,^§^ 38; G2: standard care, 37 | 6 months | NA | G1: 12.7 (1.9); G2: 13.2 (1.8) | G1: 26 (68.4); G2: 23 (62.2) | G1: 11 (29.0); G2: 12 (32.4) | G1: 5.7 (0.4); G2: 5.6 (0.4) | G1: 32.1 (5.2); G2: 34.6 (6.8) | Fair

* Subjects were from the United States (25 sites [n=62]), Russia (6 sites [n=13]), Ukraine (1 site [n=4]), Belarus (1 site [n=2]), and Poland (1 site [n=1]).

† Mean final dose of metformin was 1,798 mg/day.

ǂ The run-in involved weaning from nonstudy diabetes medications, initiating metformin at a dose of up to 1,000 mg twice daily, attaining glycemic control with metformin alone (A1c <8.0%), providing standard diabetes education and ensuring the participants’ mastery of the material, and confirming adherence.

§ The program consisted of two 50-minute exercise sessions per week, one weekly weigh-in, and a 40-minute nutrition/behavior modification class. Participants were encouraged to exercise 3 additional days per week and record the duration and type of exercise. The study used raffle tickets for gift cards to motivate participants; tickets could be earned if weight stayed the same or decreased and, in some cases, for returning their weekly exercise log.

Abbreviations: BMI=body mass index; G=group; HbA1c=glycated hemoglobin; KQ=key question; NA=not applicable; NR=not reported; OGTT=oral glucose tolerance test; SD=standard deviation; TODAY=Treatment Options for Type 2 Diabetes in Adolescents and Youth.

The second trial^63^ compared metformin and placebo in 82 treatment-naïve adolescents ages 10 to 16 years with previous or newly diagnosed type 2 diabetes.^63^ It was a 16-week double-blind placebo-controlled trial of 82 adolescents recruited from 44 sites in multiple countries, including the United States, Russia, Belarus, Ukraine, and Poland. Most participants were from the U.S. sites. The intervention group received up to 2,000 mg daily of metformin for 16 weeks. The mean age of participants was 14; mean BMI was 34 kg/m^2^; mean baseline A1c values were 8.3 to 9.0 percent across the study groups; 69 percent were female; and 63 percent were nonwhite. The primary outcome was change in fasting PG from baseline (described in CQ 2).

#### Renal Impairment

The TODAY study reported two cases of renal impairment (Table 4). One case was in the metformin plus rosiglitazone group, and one was in the metformin plus lifestyle intervention group (p=1.00). Renal impairment was defined as an estimated creatinine clearance of less than 70 ml per minute or a serum creatinine of more than 1.5 mg/dl.

Table 4 Results of Trials of Children and Adolescents With Prediabetes or Type 2 Diabetes Reporting Health Outcomes (KQ 3) or Progression From Prediabetes to Type 2 Diabetes (KQ 5)

First Author, Year | G1 (N); G2 (N) | Progression to Diabetes | Mortality G1 vs. G2; HR (95% CI) | CVD Events G1 vs. G2; HR (95% CI) | Diabetic Ketoacidosis | Chronic Kidney Disease; G1 N (%); G2 N (%); HR (95% CI) | Amputations; G1 N (%); G2 N (%); HR (95% CI) | Skin Ulcers; G1 N (%); G2 N (%); HR (95% CI) | Visual Impairment; G1 N (%); G2 N (%); HR (95% CI) | Neuropathy; G1 N (%); G2 N (%); HR (95% CI)
Jones, 2002^63^ | G1: 42; G2: 40 | NA | NR | NR | G1: 0; G2: 1 (2.5%) | NR | NR | NR | NR | NR
TODAY Study Group, 2007, 2010, 2012, 2013, 2015, 2016^53,^ ^58–62^ | G1: 232; G2: 233; G3: 234 | NA | G1: 0; G2: 0; G3: 0 | NR | G1: 5 (2.1); G2: 3 (1.3); G3: 3 (1.3); p=0.70 | Renal impairment:; G1: 0; G2: 1 (0.4); G3: 1 (0.4); p=1.00 | NR | NR | NR | NR
Savoye, 2014^64^ | G1: 38; G2: 37 | G1: 0; G2: 0 | NR | NR | NR | NR | NR | NR | NR | NR

Abbreviations: CI=confidence interval; CVD=cardiovascular disease; G=group; HR=hazard ratio; N=number; NA=not applicable; NR=not reported; TODAY=Treatment Options for Type 2 Diabetes in Adolescents and Youth; vs.=versus.

#### Diabetic Ketoacidosis

The TODAY study reported that 11 participants developed DKA. There was no statistically significant difference across treatment groups (5 [2.1%] vs. 3 [1.3%] vs. 3 [1.3%], p=0.70, for metformin monotherapy vs. metformin plus rosiglitazone vs. metformin plus lifestyle, respectively). The smaller trial reported that zero participants in the metformin group developed DKA and that one person in the control group developed DKA.

#### Other Health Outcomes

No eligible studies reported other health outcomes, including mortality, cardiovascular morbidity (including myocardial infarction, stroke, congestive heart failure), amputation, skin ulcers, visual impairment (including blindness), neuropathy, and quality of life.

### KQ 4 What Are the Harms of Interventions for Prediabetes, Screen-Detected Type 2 Diabetes, or Recently Diagnosed Type 2 Diabetes?

Overall, two RCTs that enrolled youths with recently diagnosed type 2 diabetes were eligible. The two trials assessed different comparisons. Major hypoglycemic events were reported by less than 1 percent of participants. Minor hypoglycemic events were more common among youths treated with metformin plus rosiglitazone than among those treated with metformin or metformin plus lifestyle. In one study, gastrointestinal (GI) adverse events were more commonly reported by those taking metformin than by those taking placebo. GI adverse events, infections, and muscle aches and pains were less common among youths treated with metformin plus rosiglitazone than with metformin alone or metformin plus a lifestyle intervention. No eligible studies assessed harms for youths with screen-detected diabetes or prediabetes, and no eligible studies reported on harms of lifestyle interventions provided without pharmacotherapy.

#### Harms of Interventions for Recently Diagnosed Type 2 Diabetes

Two RCTs (described in 7 articles) reported on harms of interventions for recently diagnosed type 2 diabetes (Table 3).^53,^ ^58–63^ The TODAY trial is described above in KQ 3; it compared metformin monotherapy, metformin plus rosiglitazone, or metformin plus a lifestyle intervention. The second trial^63^ was also described in KQ 3; it reported on harms related to metformin (up to 2,000 mg daily) compared with placebo in treatment-naïve adolescents ages 10 to 16 years with previous or newly diagnosed type 2 diabetes.^63^ The duration of followup ranged from 16 weeks^63^ to a mean of 3.8 years (TODAY). Both studies reported on withdrawals, hypoglycemic events requiring medical attention, gastrointestinal adverse events, and lactic acidosis (Table 5). The TODAY study reported on other adverse events, including rash, infection, sprain or fracture, muscle ache or pain, anemia, and edema. The TODAY study reported zero deaths during the trial.

Table 5 Results of Included Trials of Children and Adolescents With Type 2 Diabetes Reporting Harms/Adverse Events Due to Treatment (KQ 4)

First Author, Year | CV Adverse Events; G1 N (%); G2 N (%); HR (95% CI) | Hypoglycemic Events; G1 N (%); G2 N (%); HR (95% CI) | All-Cause Withdrawals; G1 N (%); G2 N (%); HR (95% CI) | Gastrointestinal Adverse Events; G1 N (%); G2 N (%); HR (95% CI) | Lactic Acidosis; G1 N (%); G2 N (%); HR (95% CI) | Other Adverse Events; G1 N (%); G2 N (%); HR (95% CI)
Jones, 2002^63^ | NR | Hypoglycemic events requiring medical attention:; G1: 0; G2: 0 | G1: 6 (14.3); G2: 4 (10.0) | Abdominal pain; G1: NR (25); G2: NR (12); Nausea/vomiting; G1: NR (17); G2: NR (10) | G1: 0; G2: 0 | Other adverse events, as reported by the authors (all deemed unrelated to the study drug); G1: 2 (4.7%) (one person became seropositive for hepatitis B and one had severe abdominal pain and diarrhea due to a viral infection); G2: 2 (5.4%) (one had hyperglycemia and one experienced problems associated with diabetes and increased liver function enzymes; a third participant had diabetic ketoacidosis) (covered in Table 4)
TODAY Study Group, 2007, 2010, 2012, 2013, 2015, 2016^53,^ ^58–62^ | Heart failure; Before primary outcome; G1: 0; G2: 0; G3: 0; After primary outcome (out of 319 participants who had the primary outcome of treatment failure); G1: 0; G2: 1 (1.1); G3: 0 | Severe hypoglycemia:; G1: 1 (0.4); G2: 1 (0.4); G3: 2 (0.8); p=1.00; Mild hypoglycemia:; G1: 10 (4.3); G2: 19 (8.2); G3: 8 (3.4); p=0.05; Repeated mild hypoglycemia; Before primary outcome (out of all 699 participants); G1: 5 (2.1); G2: 16 (6.9); G3: 6 (2.6); p=0.094; After primary outcome (out of 319 participants); G1: 4 (3.3); G2: 3 (3.3); G3: 1 (0.9); p=0.029 | G1: 15 (6.4); G2: 20 (8.6); G3: 15 (6.4) | GI symptoms; Full sample:; G1: 129 (55.6); G2: 100 (42.9); G3: 136 (58.1); p=0.002 | G1: 1 (0.4); G2: 0; G3: 0; p=0.33 | Rash; G1: 108 (46.5); G2: 101 (43.3); G3: 95 (40.6); p=0.43; Infection; G1: 149 (64.2); G2: 120 (51.5); G3: 151 (64.5); p=0.005; Sprain or fracture; G1: 66 (28.4); G2: 53 (22.7); G3: 64 (27.4); p=0.33 | Muscle ache or pain; G1: 68 (29.3); G2: 53 (22.7); G3: 77 (32.9); p=0.05; Anemia; G1: 71 (30.6); G2: 58 (24.8); G3: 52 (22.2); p=0.11; Edema; G1: 17 (7.3); G2: 17 (7.3); G3: 17 (7.3); p=1.00

Abbreviations: CI=confidence interval; CV=cardiovascular; G=group; HR=hazard ratio; KQ=key question; N=number; NR=not reported; TODAY=Treatment Options for Type 2 Diabetes in Adolescents and Youth.

#### Hypoglycemic Events

Serious hypoglycemic events requiring medical attention were reported in both trials and were rare (Table 5). The TODAY study reported that four youths had severe hypoglycemia (1 [0.4%] vs. 1 [0.4%] vs. 2 [0.8%] for metformin monotherapy vs. metformin plus rosiglitazone vs. metformin plus lifestyle, respectively, p=1.00). It also reported that more youths had repeated mild hypoglycemia in the group that received metformin plus rosiglitazone (10 [4.3%] vs. 19 [8.2%] vs. 8 [3.4%] for metformin monotherapy vs. metformin plus rosiglitazone vs. metformin plus lifestyle, respectively, p=0.05). The 16-week trial^63^ comparing metformin monotherapy with placebo reported zero hypoglycemic events requiring medical attention in either study group.

#### Gastrointestinal Adverse Events

GI adverse events were common in both studies. The TODAY study reported lower rates of GI symptoms in the metformin plus rosiglitazone group than in the metformin monotherapy or metformin plus lifestyle intervention groups (129 [55.6%] vs. 100 [42.9%] vs. 136 [58.1%], for metformin monotherapy vs. metformin plus rosiglitazone vs. metformin plus lifestyle, respectively, p=0.002). The 16-week trial^63^ reported that more youths treated with metformin than with placebo had abdominal pain (25% vs. 12%, p not reported) and nausea or vomiting (17% vs. 10%, p not reported).

#### Other Adverse Events

Both studies reported other adverse events; types of events reported (and definitions) varied and most found no difference between groups or reported that no adverse events were attributed to study interventions (Table 5). The TODAY study found higher rates of infection (p=0.005) and muscle ache or pain (p=0.05) in the metformin monotherapy and metformin plus lifestyle intervention groups than in the metformin plus rosiglitazone group. The TODAY study reported on rash, sprain or fracture, anemia, and edema, but found no statistically significant difference between groups. The TODAY study reported that one participant in the metformin plus rosiglitazone group developed heart failure and one participant in the metformin monotherapy group developed lactic acidosis. The 16-week trial^63^ reported that few participants had serious adverse events, all deemed unrelated to the study drug.

### KQ 5 Do Interventions for Prediabetes Delay or Prevent Progression to Type 2 Diabetes?

In summary, the one included study reported no evidence that lifestyle interventions were associated with a reduction in the incidence of diabetes, although followup was only 6 months and the study had zero participants progress to type 2 diabetes in either group. No eligible studies that evaluated pharmacologic interventions were identified.

#### Study Characteristics

We included one fair-quality RCT (75 participants) that compared the Bright Bodies Healthy Lifestyle Program with standard care for adolescents who were obese (BMI>95^th^ percentile) ages 10 to 16 years with prediabetes (Table 3).^64^ The trial was conducted in the United States in a pediatric obesity clinic starting in September 2009. Regarding prediabetes ascertainment, the trial focused on IGT for participant eligibility, defined as an elevated 2-h OGTT (after a glucose load of 1.75 g/kg, maximum 75 g) result between 130 and 199 mg/dL (using a range that was slightly wider than the current prediabetes criteria of 140 to 199 mg/dL). The mean age of participants was 13, mean BMI was 33 kg/m^2^, mean baseline A1c was 5.6 to 5.7 across the groups, 64 percent were female, and 31 percent were nonwhite. The duration of followup was 6 months. The lifestyle program focused on both diet/nutrition and physical activity. The high-contact program included twice-weekly 50-minute exercise classes, a once-weekly weigh-in, and a one-time 40-minute nutrition/behavior modification class (all administered in group settings). Participants were encouraged to exercise 3 additional days per week and record the duration and type of exercise. The study used raffle tickets for gift cards to motivate participants; tickets could be earned if weight stayed the same or decreased and, in some cases, for returning their weekly exercise log. The trial was rated as fair quality mainly because of the overall attrition (of 23%) and having some participants withdrawn because of starting metformin (Appendix D).

The primary outcome of the trial was the 6-month change in PG 2 hours after OGTT (intermediate outcomes are described in CQs 2 and 3). The trial reported that zero participants developed diabetes during the trial (Table 4).

### KQ 6 After Interventions for Prediabetes Are Provided, What Is the Magnitude of Change in Health Outcomes That Results From the Reduction in Type 2 Diabetes Incidence?

We found no eligible studies that addressed this question.