# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Six KQs were developed for this review:

1. Is there direct evidence that screening for type 2 diabetes and prediabetes in asymptomatic children and adolescents improves health outcomes?
2. What are the harms of screening for type 2 diabetes and prediabetes in asymptomatic children and adolescents?
3. a. Do interventions for screen-detected type 2 diabetes and prediabetes provide an incremental benefit in health outcomes when delivered at the time of detection compared with initiating interventions later, after clinical diagnosis?
  b. Do interventions for screen-detected type 2 diabetes and prediabetes improve health outcomes compared with no intervention, usual care, or interventions with different treatment targets?
  c. Do interventions for recently diagnosed type 2 diabetes improve health outcomes compared with no intervention, usual care, or interventions with different treatment targets?
4. What are the harms of interventions for prediabetes, screen-detected type 2 diabetes, or recently diagnosed type 2 diabetes?
5. Do interventions for prediabetes delay or prevent progression to type 2 diabetes?
6. After interventions for prediabetes are provided, what is the magnitude of change in health outcomes that results from the reduction in type 2 diabetes incidence?

Figure 1 Analytic Framework

* Eligible interventions include pharmacotherapy and primary care–relevant counseling focused on healthy diet and nutrition, physical activity, or both.

Figure 1 depicts the key questions within the context of the eligible populations, screenings, interventions, comparisons, outcomes, and settings. On the left, the population of interest is asymptomatic children and adolescents. Moving from left to right, the figure illustrates the overarching question: Is there direct evidence that screening for type 2 diabetes and prediabetes in asymptomatic children and adolescents improves health outcomes (Key Question 1)? Screening may result in harms (Key Question 2). After diagnosis of type 2 diabetes or prediabetes, the figure illustrates the following questions: Do interventions provide an incremental benefit in health outcomes when delivered at the time of detection compared with initiating interventions later, after clinical diagnosis (Key Question 3a); and do interventions improve health outcomes compared with no intervention, usual care, or interventions with different treatment targets (Key Question 3b)? For recently diagnosed type 2 diabetes, the figure illustrates the question: Do interventions improve health outcomes compared with no intervention, usual care, or interventions with different treatment targets (Key Question 3c)? Interventions may result in harms (Key Question 4). For prediabetes, the figure depicts the questions: Do interventions delay or prevent progression to type 2 diabetes (Key Question 5); and after intervention, what is the magnitude of change in health outcomes that results from the reduction in type 2 diabetes incidence (Key Question 6)?

In addition to addressing the KQs, this review also looked for evidence related to five CQs that focused on progression from prediabetes to diabetes, whether screening or interventions change intermediate outcomes, agreement among screening tests, and risk assessment tools. These CQs were not a part of this systematic review. They are intended to provide additional background information. Literature addressing the CQs is summarized in Appendix A.

## Data Sources and Searches

PubMed/MEDLINE and the Cochrane Library were searched for English-language articles published through May 3, 2021. Medical Subject Headings were used as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are listed in Appendix B. Targeted searches for unpublished literature were conducted by searching ClinicalTrials.gov. To supplement electronic searches, the reference lists of pertinent review articles and studies that met the inclusion criteria were reviewed. Studies suggested by peer reviewers or public comment respondents were reviewed and, if appropriate, incorporated into the final review. Since May 3, 2021, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on July 22, 2022, and did not identify any additional studies that would affect the conclusions. All literature search results were managed using EndNote™ version 9.2 (Thomson Reuters, New York, NY).

## Study Selection

Inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs were developed with input from the USPSTF (Appendix B). English-language studies of asymptomatic, nonpregnant people younger than age 18 conducted in countries categorized as very high on the 2019 Human Development Index were included. For all KQs, controlled clinical trials were eligible. Controlled prospective cohort studies were also eligible for KQs on harms (KQs 2 and 4) and the change in health outcomes after reduction in type 2 diabetes incidence (KQ 6); case-control studies were eligible for KQs on harms (KQs 2 and 4). For KQs 1 and 2 (direct evidence of benefits and harms of screening), studies that compared screening with A1c, fasting glucose, or OGTT with no screening or alternative screening strategies were eligible. For KQs 3 through 6 (benefits and harms of interventions), studies were eligible that evaluated primary care–relevant behavioral counseling interventions or pharmacologic interventions for glycemic control for prediabetes or type 2 diabetes.

Titles and abstracts were independently reviewed by two investigators; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

We assessed the quality of studies as good, fair, or poor, using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B). Two independent investigators assigned quality ratings for each study. Disagreements were resolved by discussion. Only studies rated as having good or fair quality were included.

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. All data extractions were checked by a second investigator for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were summarized in tabular and narrative format. The overall strength of the evidence for each KQ was assessed as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence, using methods developed for the USPSTF (and the EPC program).^56^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

To determine whether meta-analyses were appropriate, the clinical and methodological heterogeneity of the studies was assessed according to established guidance.^57^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. Because of the limited number of similar studies for each KQ, meta-analyses were not conducted.

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from July 30, 2020 to August 26, 2020. In response to comments, the USPSTF changed the title to include prediabetes, added socioeconomic status to the list of prespecified specific populations, clarified the eligibility of school-based health centers and community settings, and added more intermediate outcomes to the CQs. The final version of the research plan was posted on the USPSTF website on November 12, 2020. A draft evidence review was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and addressed in revisions of this evidence review when appropriate. Revisions included clarifications to the introduction and edits to use person-first language. The draft evidence review was posted for public comment from December 14, 2021, through January 18, 2022; one article was added to CQ 1 based on public comments.

## USPSTF and AHRQ Involvement

AHRQ staff and members of the USPSTF participated in developing the scope of work (including the analytic framework and KQs) and reviewed draft reports, but the authors are solely responsible for the content. AHRQ staff provided oversight for the project and assisted in an external review of the draft evidence synthesis.