# Appendix D Quality Assessments

Appendix D Table 1 Quality Assessment of Randomized, Controlled Clinical Trials (All KQs)

First author, Year; Trial name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | What was the reported adherence to the intervention? | Did the study have cross-overs or contamination raising concern for bias? | What was the overall attrition? Enter values for both loss to f/u (missing data) and noncompleters | What was the differential attrition? | Did the study have high differential attrition (>10% but think about how it might bias) or overall high attrition (depends on duration and outcome; generally 20%) raising concern for bias? | Were outcome measurements equal, valid, and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | What was the method used to handle missing data? | Did the study use an ITT analysis (i.e., analyze people in the groups they were randomized to)? | Quality rating (for benefits) | Comments
Kelsey, 2016^62^; Zeitler, 2012^53^; TODAY Study Group^58^; TODAY Study Group^59^; Levitt Katz, 2015^60^; Zeitler, 2007^61^; Treatment Options for type 2 Diabetes in Adolescents and Youth (TODAY) Study | Yes | Yes | Yes | Adherence to the medication regimen before the primary outcome was reached or the study was completed ranged from 84% at month 8 to 57% at month 60 but did not differ significantly across treatments. The rate of attendance at lifestyle program visits during the first 24 months was 75.2%; 53.6% of participants met the preplanned target of attending 75% or more of visits over these 2 years. | No | Combining withdrawing consent and data censored: 6.4% (15/232) vs. 8.6% (20/233) vs. 6.4% (15/234) | 2.2% | No | Yes | Yes | Yes | Yes | Yes | Censored; all randomized participants were included in the time-to-event analysis. | Yes (all participants included in time-to-event analysis) | Good | None
Jones, 2002^63^ | Unclear | Unclear | No, placebo had higher FPG and higher A1c and TG. Metformin group had higher C-peptide. | 7.5% of placebo (3/40) and 45.2% (19/42) completed metformin | Yes | At 16 weeks: 10/82=12.2% overall | At 16 weeks: Metformin group 6/42=14.3%; At 16 weeks: Placebo group 4/40=10%; Between-group difference of 4.3% | No | Yes | Yes | Unclear | Unclear | Yes | NR | No | Fair | None
Savoye, 2014^64^ | Yes | Yes | Yes | 2/38 in the intervention group never attended the intervention visits, and 5 others did not finish the study intervention. | No | 23% (6-month followup assessments were missing for 17/75 participants) | 8.6% (18.4% [7/38] vs. 27.0% [10/37]) | Yes | Yes | No | No | Yes | Unclear | Multiple imputation | Yes | Fair | None

Abbreviations: FPG=fasting plasma glucose; ITT=intention to treat; KQ=key question; NR=not reported; TG=triglycerides; TODAY=Treatment Options for Type 2 Diabetes in Adolescents and Youth.

Appendix D Table 2 Quality Assessment of Randomized, Controlled Clinical Trials: Additional Questions for Studies Reporting Harms (KQ 2 and KQ 4 only)

First author, Year; Trial name | Were harms prespecified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Quality rating (for harms) | Comments
Kelsey, 2016^62^; Zeitler, 2012^53^; TODAY Study Group^58^; TODAY Study Group^59^; Levitt Katz, 2015^60^; Zeitler, 2007^61^; Treatment Options for type 2 Diabetes in Adolescents and Youth (TODAY) Study | Yes | Yes | Yes | Yes | Good
Jones, 2002^63^ | Unclear | No | Unclear | Yes | Fair | Unsure how harms data was measured.

For RCTs and cohorts, definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Abbreviations: RCT=randomized, controlled trial; TODAY=Treatment Options for Type 2 Diabetes in Adolescents and Youth.