# Appendix C Excluded Articles

- X1: Non-English
- X2: Ineligible Population
- X3: Ineligible Screening
- X4: Ineligible Treatment
- X5: Ineligible Comparison
- X6: Ineligible Outcome
- X7: Ineligible Setting
- X8: Ineligible Study Design
- X9: Ineligible Country
- X10: Abstract Only

1 Metformin: new indication. Useful for some children with type 2 diabetes. Prescrire Int. 2007 Apr;16(88):50–2. PMID: 17458042. Exclusion Code: X8.17458042
2 Effects of metformin, metformin plus rosiglitazone, and metformin plus lifestyle on insulin sensitivity and β-cell function in TODAY. Diabetes Care. 2013 Jun;36(6):1749–57. doi: 10.2337/dc12-2393. PMID: 23704674. Exclusion Code: X6.23704674
3 Lipid and inflammatory cardiovascular risk worsens over 3 years in youth with type 2 diabetes: the TODAY clinical trial. Diabetes Care. 2013 Jun;36(6):1758–64. doi: 10.2337/dc12-2388. PMID: 23704675. Exclusion Code: X6.23704675
4 Restoring Insulin Secretion (RISE): design of studies of β-cell preservation in prediabetes and early type 2 diabetes across the life span. Diabetes Care. 2014;37(3):780–8. doi: 10.2337/dc13-1879. PMID: 24194506. Exclusion Code: X6.24194506
5 Effects of a community-based diabetes prevention program for obese latino youth. Diabetes. 2017;Conference: 77th Scientific Sessions of the American Diabetes Association, ADA 2017. United States. 66(pp A369)PMID: CN-01471124. Exclusion Code: X2.
6 Impact of insulin and metformin versus metformin alone on β-cell function in youth with impaired glucose tolerance or recently diagnosed type 2 diabetes. Diabetes Care. 2018 Aug;41(8):1717–25. doi: 10.2337/dc18-0787. PMID: 29941500. Exclusion Code: X5.29941500
7 Effects of treatment of impaired glucose tolerance or recently diagnosed type 2 diabetes with metformin alone or in combination with insulin glargine on β-cell function: comparison of responses in youth and adults. Diabetes. 2019 Aug;68(8):1670–80. doi: 10.2337/db19-0299. PMID: 31178433. Exclusion Code: X6.31178433
8 DIABRISK-SL trial: further consideration of age and impact of imputations. BMC Med. 2019;17(1)doi: 10.1186/s12916-019-1361-2. PMID: CN-02002832. Exclusion Code: X8.
9 Reducing the incidence of predictors of cardio-metabolic disease and dysglycaemia with lifestyle modification in at-risk persons-results of further analyses of DIABRISK-SL in those below 18 years of age. BMC Med. 2019;17(1)doi: 10.1186/s12916-019-1398-2. PMID: CN-02092627. Exclusion Code: X2.
10 Effects of treatment of impaired glucose tolerance or recently diagnosed type 2 diabetes with metformin alone or in combination with insulin glargine on Î²-cell function: comparison of responses in youth and adults: the RISE consortium. Diabetes. 2019;68(8):1670–80. doi: 10.2337/db19-0299. PMID: CN-02011190. Exclusion Code: X5.31178433
11 Abdella K, McReelis KD, Strungaru MH. Diabetic retinopathy screening in a Canadian community pediatric diabetes clinic. Can J Ophthalmol. 2019 Feb;54(1):27–32. doi: 10.1016/j.jcjo.2018.03.012. PMID: 30851771. Exclusion Code: X2.30851771
12 Abdella NA, Mojiminiyi OA. Clinical applications of adiponectin measurements in type 2 diabetes mellitus: screening, diagnosis, and marker of diabetes control. Dis Markers. 2018;2018:5187940. doi: 10.1155/2018/5187940. PMID: 30069271. Exclusion Code: X2.30069271
13 Abegg MR, Nandagopal R, Brown RJ, . Partners for better health in adolescents with type 2 diabetes (“Buddy study”)-an update. Diabetes. 2012;61:A615–A6. doi: 10.2337/db12-2323-2568. PMID: CN-01032289. Exclusion Code: X10.
14 Abrams P, Levitt Katz LE, Moore RH, . Threshold for improvement in insulin sensitivity with adolescent weight loss. J Pediatr. 2013 Sep;163(3):785–90. doi: 10.1016/j.jpeds.2013.04.003. PMID: 23706362. Exclusion Code: X2.23706362
15 Addy C, Tatosian D, Hou XS, . Effects of age, gender and obesity on the single dose pharmacokinetics (PK) of omarigliptin, a novel once-weekly dipeptidyl peptidase- 4 (DPP-4) inhibitor. Diabetes. 2013;62:A301. doi: 10.2337/db13-859-1394. PMID: CN-01065264. Exclusion Code: X2.
16 Aguilar C, Reza A, García JE, . Biguanide related lactic acidosis: incidence and risk factors. Arch Med Res. 1992 Spring;23(1):19–24. PMID: 1308787. Exclusion Code: X2.1308787
17 Ahrens MJ, Thompson DL. Effect of emulin on blood glucose in type 2 diabetics. J Med Food. 2013;16(3):211–5. doi: 10.1089/jmf.2012.0069. PMID: CN-00877198. Exclusion Code: X2.23444965
18 Al Amiri E, Abdullatif M, Abdulle A, . The prevalence, risk factors, and screening measure for prediabetes and diabetes among Emirati overweight/obese children and adolescents. BMC Public Health. 2015 Dec 24;15:1298. doi: 10.1186/s12889-015-2649-6. PMID: 26704130. Exclusion Code: X8.26704130
19 Al Khalifah R, Thabane L, Tarnopolsky MA, . The prognosis for glycemic status among children and youth with obesity 2 years after entering a weight management program. Pediatr Diabetes. 2018 Aug;19(5):874–81. doi: 10.1111/pedi.12675. PMID: 29577539. Exclusion Code: X5.29577539
20 Al-Rubeaan K, Al-Manaa H, Khoja T, . The Saudi Abnormal Glucose Metabolism and Diabetes Impact Study (SAUDI-DM). Ann Saudi Med. 2014 Nov–Dec;34(6):465–75. doi: 10.5144/0256-4947.2014.465. PMID: 25971818. Exclusion Code: X8.25971818
21 Amed S, Islam N, Sutherland J, . Incidence and prevalence trends of youth-onset type 2 diabetes in a cohort of Canadian youth: 2002-2013. Pediatr Diabetes. 2018 Jun;19(4):630–6. doi: 10.1111/pedi.12631. PMID: 29280255. Exclusion Code: X8.29280255
22 Apovian CM, Bergenstal RM, Cuddihy RM, . Effects of exenatide combined with lifestyle modification in patients with type 2 diabetes. Am J Med. 2010 May;123(5):468.e9–17. doi: 10.1016/j.amjmed.2009.11.019. PMID: 20399326. Exclusion Code: X2.20399326
23 Arky RA, Abramson EA. Insulin response to glucose in the presence of oral hypoglycemics. Ann N Y Acad Sci. 1968 Mar 26;148(3):768–77. doi: 10.1111/j.1749-6632.1968.tb27749.x. PMID: 5241475. Exclusion Code: X2.5241475
24 Arslanian S, El Ghormli L, Bacha F, . Adiponectin, insulin sensitivity, β-cell function, and racial/ethnic disparity in treatment failure rates in TODAY. Diabetes Care. 2017 Jan;40(1):85–93. doi: 10.2337/dc16-0455. PMID: 27803118. Exclusion Code: X6.27803118
25 Arslanian S, El Ghormli L, Haymond MH, . Beta cell function and insulin sensitivity in obese youth with maturity onset diabetes of youth mutations vs type 2 diabetes in TODAY: Longitudinal observations and glycemic failure. Pediatr Diabetes. 2020 Jun;21(4):575–85. doi: 10.1111/pedi.12998. PMID: 32064729. Exclusion Code: X5.32064729
26 Aschner P, Kipnes MS, Lunceford JK, . Effect of the dipeptidyl peptidase-4 inhibitor sitagliptin as monotherapy on glycemic control in patients with type 2 diabetes. Diabetes Care. 2006 Dec;29(12):2632–7. doi: 10.2337/dc06-0703. PMID: 17130196. Exclusion Code: X2.17130196
27 Atabek ME, Pirgon O. Use of metformin in obese adolescents with hyperinsulinemia: a 6-month, randomized, double-blind, placebo-controlled clinical trial. J Pediatr Endocrinol Metab. 2008 Apr;21(4):339–48. doi: 10.1515/jpem.2008.21.4.339. PMID: 18556965. Exclusion Code: X6.18556965
28 Babamoto KS, Sey KA, Camilleri AJ, . Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Educ Behav. 2009 Feb;36(1):113–26. doi: 10.1177/1090198108325911. PMID: 19188371. Exclusion Code: X2.19188371
29 Bacha F, El Ghormli L, Arslanian S, . Predictors of response to insulin therapy in youth with poorly-controlled type 2 diabetes in the TODAY trial. Pediatr Diabetes. 2019 Nov;20(7):871–9. doi: 10.1111/pedi.12906. PMID: 31418516. Exclusion Code: X2.31418516
30 Bacha F, Gungor N, Lee S, . Indices of insulin secretion during a liquid mixed-meal test in obese youth with diabetes. J Pediatr. 2013 May;162(5):924–9. doi: 10.1016/j.jpeds.2012.11.037. PMID: 23290511. Exclusion Code: X5.23290511
31 Bacha F, Pyle L, Nadeau K, . Determinants of glycemic control in youth with type 2 diabetes at randomization in the TODAY study. Pediatr Diabetes. 2012 Aug;13(5):376–83. doi: 10.1111/j.1399-5448.2011.00841.x. PMID: 22332798. Exclusion Code: X8.22332798
32 Bahíllo-Curieses MP, Hermoso-López F, Martínez-Sopena MJ, . Prevalence of insulin resistance and impaired glucose tolerance in a sample of obese Spanish children and adolescents. Endocrine. 2012 Apr;41(2):289–95. doi: 10.1007/s12020-011-9540-8. PMID: 21964644. Exclusion Code: X8.21964644
33 Bantle JP, Laine DC, Thomas JW. Metabolic effects of dietary fructose and sucrose in types I and II diabetic subjects. JAMA. 1986;256(23):3241–6. PMID: CN-00045554. Exclusion Code: X2.3783868
34 Barnes NS, White PC, Hutchison MR. Time to failure of oral therapy in children with type 2 diabetes: a single center retrospective chart review. Pediatr Diabetes. 2012 Nov;13(7):578–82. doi: 10.1111/j.1399-5448.2012.00873.x. PMID: 22646303. Exclusion Code: X5.22646303
35 Barnett AH, Charbonnel B, Li J, . Saxagliptin add-on therapy to insulin with or without metformin for type 2 diabetes mellitus: 52-week safety and efficacy. Clin Drug Investig. 2013 Oct;33(10):707–17. doi: 10.1007/s40261-013-0107-8. PMID: 23949898. Exclusion Code: X2.23949898
36 Barnett AH, Patel S, Harper R, . Linagliptin monotherapy in type 2 diabetes patients for whom metformin is inappropriate: an 18-week randomized, double-blind, placebo-controlled phase III trial with a 34-week active-controlled extension. Diabetes Obes Metab. 2012 Dec;14(12):1145–54. doi: 10.1111/dom.12011. PMID: 22974280. Exclusion Code: X2.22974280
37 Barreiro-Ribeiro F, Vasques AC, da Silva CC, . Hypertriglyceridemic waist phenotype indicates insulin resistance in adolescents according to the clamp technique in the BRAMS Study. Child Obes. 2016 Dec;12(6):446–54. doi: 10.1089/chi.2016.0180. PMID: 27627113. Exclusion Code: X6.27627113
38 Bashier AMK, Hussain AKB, Alawadi F, . Impact of optimum diabetes care on the safety of fasting in Ramadan in adult patients with type 2 diabetes mellitus on insulin therapy. Diabetes Res Clin Pract. 2019 Apr;150:301–7. doi: 10.1016/j.diabres.2019.01.037. PMID: 30768940. Exclusion Code: X2.30768940
39 Bays HE, Goldberg RB, Truitt KE, . Colesevelam hydrochloride therapy in patients with type 2 diabetes mellitus treated with metformin: glucose and lipid effects. Arch Intern Med. 2008 Oct 13;168(18):1975–83. doi: 10.1001/archinte.168.18.1975. PMID: 18852398. Exclusion Code: X2.18852398
40 Bazelier MT, de Vries F, Vestergaard P, . Use of thiazolidinediones and risk of bladder cancer: disease or drugs? Curr Drug Saf. 2013 Nov;8(5):364–70. doi: 10.2174/15748863113086660069. PMID: 24215315. Exclusion Code: X2.24215315
41 Benavides S, Striet J, Germak J, . Efficacy and safety of hypoglycemic drugs in children with type 2 diabetes mellitus. Pharmacotherapy. 2005 Jun;25(6):803–9. doi: 10.1592/phco.2005.25.6.803. PMID: 15927898. Exclusion Code: X8.15927898
42 Bergman A, Tan B, Somayaji VR, . A 4-week study assessing the pharmacokinetics, pharmacodynamics, safety, and tolerability of the glucagon receptor antagonist PF-06291874 administered as monotherapy in subjects with type 2 diabetes mellitus. Diabetes Res Clin Pract. 2017 Apr;126:95–104. doi: 10.1016/j.diabres.2017.01.019. PMID: 28237861. Exclusion Code: X2.28237861
43 Berkowitz RI, Marcus MD, Anderson BJ, . Adherence to a lifestyle program for youth with type 2 diabetes and its association with treatment outcome in the TODAY clinical trial. Pediatr Diabetes. 2018 Mar;19(2):191–8. doi: 10.1111/pedi.12555. PMID: 28664624. Exclusion Code: X8.28664624
44 Bernardita Prado A, Veronica Gaete P, Francisca Corona H, . Metabolic effect of metformin in obese adolescents at risk of diabetes mellitus type 2. Rev Chil Pediatr. 2012;83(1):48–57. doi: 10.4067/S0370-41062012000100006. PMID: CN-01017731. Exclusion Code: X1.
45 Berry DC, Gonzales C, Montano NP, . Rationale, design, and methodology for the healthy mothers-healthy children study: a randomized controlled trial. BMC Nutr. 2019;5:58. doi: 10.1186/s40795-019-0322-7. PMID: 32153971. Exclusion Code: X2.32153971
46 Bhagyanathan M, Dhayanithy D, Parambath VA, . Acanthosis nigricans: a screening test for insulin resistance - an important risk factor for diabetes mellitus type-2. J Family Med Prim Care. 2017 Jan–Mar;6(1):43–6. doi: 10.4103/2249-4863.214961. PMID: 29026747. Exclusion Code: X8.29026747
47 Bhisitkul DM, Vinik AI, Morrow AL, . Prediabetic markers in children with stress hyperglycemia. Arch Pediatr Adolesc Med. 1996 Sep;150(9):936–41. doi: 10.1001/archpedi.1996.02170340050010. PMID: 8790124. Exclusion Code: X3.8790124
48 Bizino MB, Jazet IM, Westenberg JJM, . Effect of liraglutide on cardiac function in patients with type 2 diabetes mellitus: randomized placebo-controlled trial. Cardiovasc Diabetol. 2019 Apr 30;18(1):55. doi: 10.1186/s12933-019-0857-6. PMID: 31039778. Exclusion Code: X2.31039778
49 Bjornstad P, Nehus E, El Ghormli L, . Insulin sensitivity and diabetic kidney disease in children and adolescents with type 2 diabetes: an observational analysis of data from the TODAY clinical trial. Am J Kidney Dis. 2018 Jan;71(1):65–74. doi: 10.1053/j.ajkd.2017.07.015. PMID: 29157731. Exclusion Code: X6.29157731
50 Blackett PR, Taylor T, Russell D, . Lipoprotein changes in relation to body mass index in Native American adolescents. Pediatr Res. 1996;40(1):77–81. doi: 10.1203/00006450-199607000-00014. PMID: CN-00129817. Exclusion Code: X4.8798250
51 Bouchard C. Individual differences in the response to regular exercise. Int J Obes Relat Metab Disord. 1995 Oct;19 Suppl 4:S5–8. PMID: 8581095. Exclusion Code: X8.8581095
52 Boucher AB, Adesanya EA, Owei I, . Dietary habits and leisure-time physical activity in relation to adiposity, dyslipidemia, and incident dysglycemia in the pathobiology of prediabetes in a biracial cohort study. Metabolism. 2015 Sep;64(9):1060–7. doi: 10.1016/j.metabol.2015.05.015. PMID: 26116207. Exclusion Code: X2.26116207
53 Bourn DM, Mann JI, McSkimming BJ, . Impaired glucose tolerance and NIDDM: does a lifestyle intervention program have an effect? Diabetes Care. 1994 Nov;17(11):1311–9. doi: 10.2337/diacare.17.11.1311. PMID: 7821173. Exclusion Code: X2.7821173
54 Bradshaw B. The role of the family in managing therapy in minority children with type 2 diabetes mellitus. J Pediatr Endocrinol Metab. 2002 Apr;15 Suppl 1:547–51. PMID: 12017230. Exclusion Code: X6.12017230
55 Brar PC, Mengwall L, Franklin BH, . Screening obese children and adolescents for prediabetes and/or type 2 diabetes in pediatric practices: a validation study. Clin Pediatr (Phila). 2014 Jul;53(8):771–6. doi: 10.1177/0009922814528571. PMID: 24671874. Exclusion Code: X8.24671874
56 Broadney MM, Belcher B, Berrigan D, . Effects of interrupting sedentary behavior with short bouts of moderate physical activity on glucose tolerance in overweight children: a randomized, crossover trial. Diabetes. 2017;66:A365-. PMID: CN-01756063. Exclusion Code: X6.
57 Broadney MM, Belcher BR, Berrigan DA, . Effects of interrupting sedentary behavior with short bouts of moderate physical activity on glucose tolerance in children with overweight and obesity: a randomized crossover trial. Diabetes Care. 2018 Oct;41(10):2220–8. doi: 10.2337/dc18-0774. PMID: 30082324. Exclusion Code: X4.30082324
58 Brown B, Noonan C, Harris KJ, . Developing and piloting the Journey to Native Youth Health program in Northern Plains Indian communities. Diabetes Educ. 2013 Jan–Feb;39(1):109–18. doi: 10.1177/0145721712465343. PMID: 23150531. Exclusion Code: X6.23150531
59 Brufani C, Fintini D, Ciampalini P, . Pre-diabetes in Italian obese children and youngsters. J Endocrinol Invest. 2011 Oct;34(9):e275–80. doi: 10.3275/7798. PMID: 21666412. Exclusion Code: X4.21666412
60 Bryrup T, Thomsen CW, Kern T, . Metformin-induced changes of the gut microbiota in healthy young men: results of a non-blinded, one-armed intervention study. Diabetologia. 2019 Jun;62(6):1024–35. doi: 10.1007/s00125-019-4848-7. PMID: 30904939. Exclusion Code: X2.30904939
61 Burgert TS, Duran EJ, Goldberg-Gell R, . Short-term metabolic and cardiovascular effects of metformin in markedly obese adolescents with normal glucose tolerance. Pediatr Diabetes. 2008 Dec;9(6):567–76. doi: 10.1111/j.1399-5448.2008.00434.x. PMID: 18761646. Exclusion Code: X2.18761646
62 Burkeholder JN, Pickens JM, Womack WN. Oral glucose tolerance test in siblings of children with diabetes mellitus. Diabetes. 1967 Mar;16(3):156–60. doi: 10.2337/diab.16.3.156. PMID: 6019594. Exclusion Code: X8.6019594
63 Buse JB, DeFronzo RA, Rosenstock J, . The primary glucose-lowering effect of metformin resides in the gut, not the circulation: results from short-term pharmacokinetic and 12-week dose-ranging studies. Diabetes Care. 2016 Feb;39(2):198–205. doi: 10.2337/dc15-0488. PMID: 26285584. Exclusion Code: X2.26285584
64 Buse JB, Kaufman FR, Linder B, . Diabetes screening with hemoglobin A(1c) versus fasting plasma glucose in a multiethnic middle-school cohort. Diabetes Care. 2013 Feb;36(2):429–35. doi: 10.2337/dc12-0295. PMID: 23193207. Exclusion Code: X8.23193207
65 Cali AM, Pierpont BM, Taksali SE, . Rosiglitazone improves glucose metabolism in obese adolescents with impaired glucose tolerance: a pilot study. Obesity (Silver Spring). 2011 Jan;19(1):94–9. doi: 10.1038/oby.2010.109. PMID: 20467418. Exclusion Code: X6.20467418
66 Campbell EM, Redman S, Moffitt PS, . The relative effectiveness of educational and behavioral instruction programs for patients with NIDDM: a randomized trial. Diabetes Educ. 1996 Jul–Aug;22(4):379–86. doi: 10.1177/014572179602200412. PMID: 8846745. Exclusion Code: X2.8846745
67 Candler TP, Mahmoud O, Lynn RM, . Treatment adherence and BMI reduction are key predictors of HbA1c 1 year after diagnosis of childhood type 2 diabetes in the United Kingdom. Pediatr Diabetes. 2018 Dec;19(8):1393–9. doi: 10.1111/pedi.12761. PMID: 30175430. Exclusion Code: X8.30175430
68 Caprio S. Treatment of impaired glucose tolerance in childhood. Nature Clinical Practice Endocrinology and Metabolism. 2008;4(6):320–1. doi: 10.1038/ncpendmet0815. PMID: CN-01757313. Exclusion Code: X8.
69 Carrel AL. Randomised trial of exercise dose in children reduces diabetes risk (as measured by insulin resistance) in both 20-min and 40-min doses. Evid Based Med. 2013;18(4):147–8. doi: 10.1136/eb-2012-101092. PMID: CN-00917731. Exclusion Code: X2.23213116
70 Castells S. Management of hyperglycemia in minority children with type 2 diabetes mellitus. J Pediatr Endocrinol Metab. 2002 Apr;15 Suppl 1:531–40. PMID: 12017228. Exclusion Code: X5.12017228
71 Cha E, Paul S, Braxter BJ, . Dietary behaviors and glucose metabolism in young adults at risk for type 2 diabetes. Diabetes Educ. 2018 Apr;44(2):158–67. doi: 10.1177/0145721718756057. PMID: 29495910. Exclusion Code: X2.29495910
72 Chadwick JQ, Van Buren DJ, Morales E, . Structure to utilize interventionists’ implementation experiences of a family-based behavioral weight management program to enhance the dissemination of the standardized intervention: The TODAY study. Clin Trials. 2017 Aug;14(4):406–12. doi: 10.1177/1740774517707727. PMID: 28486851. Exclusion Code: X6.28486851
73 Chambers RA, Rosenstock S, Neault N, . A home-visiting diabetes prevention and management program for American Indian Youth: The Together on Diabetes Trial. Diabetes Educ. 2015 Dec;41(6):729–47. doi: 10.1177/0145721715608953. PMID: 26450222. Exclusion Code: X5.26450222
74 Chan CL, McFann K, Newnes L, . Hemoglobin A1c assay variations and implications for diabetes screening in obese youth. Pediatr Diabetes. 2014 Dec;15(8):557–63. doi: 10.1111/pedi.12132. PMID: 24636682. Exclusion Code: X8.24636682
75 Chan CL, Pyle L, Kelsey M, . Screening for type 2 diabetes and prediabetes in obese youth: evaluating alternate markers of glycemia - 1,5-anhydroglucitol, fructosamine, and glycated albumin. Pediatr Diabetes. 2016 May;17(3):206–11. doi: 10.1111/pedi.12258. PMID: 25652226. Exclusion Code: X3.25652226
76 Chan CL, Pyle L, Newnes L, . Continuous glucose monitoring and its relationship to hemoglobin A1c and oral glucose tolerance testing in obese and prediabetic youth. J Clin Endocrinol Metab. 2015 Mar;100(3):902–10. doi: 10.1210/jc.2014-3612. PMID: 25532041. Exclusion Code: X8.25532041
77 Charbonnel B, Karasik A, Liu J, . Efficacy and safety of the dipeptidyl peptidase-4 inhibitor sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes inadequately controlled with metformin alone. Diabetes Care. 2006 Dec;29(12):2638–43. doi: 10.2337/dc06-0706. PMID: 17130197. Exclusion Code: X2.17130197
78 Chaudhari P, Vallarino C, Law EH, . Evaluation of patients with type 2 diabetes mellitus receiving treatment during the pre-diabetes period: Is early treatment associated with improved outcomes? Diabetes Res Clin Pract. 2016 Dec;122:162–9. doi: 10.1016/j.diabres.2016.10.020. PMID: 27865163. Exclusion Code: X2.27865163
79 Chen J, Guo H, Yuan S, . Efficacy of urinary glucose for diabetes screening: a reconsideration. Acta Diabetol. 2019 Jan;56(1):45–53. doi: 10.1007/s00592-018-1212-1. PMID: 30159749. Exclusion Code: X8.30159749
80 Cheskin LJ, Mitchell AM, Jhaveri AD, . Efficacy of meal replacements versus a standard food-based diet for weight loss in type 2 diabetes: a controlled clinical trial. Diabetes Educ. 2008 Jan–Feb;34(1):118–27. doi: 10.1177/0145721707312463. PMID: 18267998. Exclusion Code: X2.18267998
81 Chitnis SD, Han Y, Yamaguchi M, . Population pharmacokinetic modeling and noncompartmental analysis demonstrated bioequivalence between metformin component of metformin/vildagliptin fixed-dose combination products and metformin immediate-release tablet sourced from various countries. Clin Pharmacol Drug Dev. 2016 Jan;5(1):40–51. doi: 10.1002/cpdd.191. PMID: 27119577. Exclusion Code: X2.27119577
82 Choi SH, Lim S, Hong ES, . PROPIT: A PROspective comparative clinical study evaluating the efficacy and safety of PITavastatin in patients with metabolic syndrome. Clin Endocrinol (Oxf). 2015 May;82(5):670–7. doi: 10.1111/cen.12580. PMID: 25109606. Exclusion Code: X2.25109606
83 Choi YS, Klaric JS, Beltran TH. Prediction of insulin resistance with anthropometric and clinical laboratory measures in nondiabetic teenagers. Metab Syndr Relat Disord. 2019 Feb;17(1):37–45. doi: 10.1089/met.2018.0072. PMID: 30394863. Exclusion Code: X3.30394863
84 Chou HS, Palmer JP, Jones AR, . Initial treatment with fixed-dose combination rosiglitazone/glimepiride in patients with previously untreated type 2 diabetes. Diabetes Obes Metab. 2008 Aug;10(8):626–37. doi: 10.1111/j.1463-1326.2007.00753.x. PMID: 17645558. Exclusion Code: X2.17645558
85 Christensen ML, Meibohm B, Capparelli EV, . Single- and multiple-dose pharmacokinetics of pioglitazone in adolescents with type 2 diabetes. J Clin Pharmacol. 2005 Oct;45(10):1137–44. doi: 10.1177/0091270005279578. PMID: 16172178. Exclusion Code: X5.16172178
86 Clarson CL, Brown HK, De Jesus S, . Effects of a comprehensive, intensive lifestyle intervention combined with metformin extended release in obese adolescents. Int Sch Res Notices. 2014;2014:659410. doi: 10.1155/2014/659410. PMID: 27433488. Exclusion Code: X6.27433488
87 Clarson CL, Mahmud FH, Baker JE, . Metformin in combination with structured lifestyle intervention improved body mass index in obese adolescents, but did not improve insulin resistance. Endocrine. 2009 Aug;36(1):141–6. doi: 10.1007/s12020-009-9196-9. PMID: 19387874. Exclusion Code: X2.19387874
88 Conwell LS, Batch JA. Oral glucose tolerance test in children and adolescents: positives and pitfalls. J Paediatr Child Health. 2004 Nov;40(11):620–6. doi: 10.1111/j.1440-1754.2004.00487.x. PMID: 15469531. Exclusion Code: X8.15469531
89 Copeland KC, Zeitler P, Geffner M, . Characteristics of adolescents and youth with recent-onset type 2 diabetes: the TODAY cohort at baseline. J Clin Endocrinol Metab. 2011 Jan;96(1):159–67. doi: 10.1210/jc.2010-1642. PMID: 20962021. Exclusion Code: X6.20962021
90 Craft S, Tripputi M, Edelstein S, . Associations between β-cell function and cognitive measures following treatment in youth with impaired glucose tolerance (IGT) or recently diagnosed type 2 diabetes (T2d). Diabetes. 2020;69doi: 10.2337/db20-1268-P. PMID: CN-02203727. Exclusion Code: X5.
91 Czech M, Rdzanek E, Pawęska J, . Drug-related risk of severe hypoglycaemia in observational studies: a systematic review and meta-analysis. BMC Endocr Disord. 2015 Oct 12;15:57. doi: 10.1186/s12902-015-0052-z. PMID: 26458540. Exclusion Code: X8.26458540
92 Daaboul JJ, Siverstein JH. The management of type 2 diabetes in children and adolescents. Minerva Pediatr. 2004 Jun;56(3):255–64. PMID: 15252375. Exclusion Code: X8.15252375
93 Dangardt F, Chen Y, Gronowitz E, . High physiological omega-3 Fatty Acid supplementation affects muscle Fatty Acid composition and glucose and insulin homeostasis in obese adolescents. J Nutr Metab. 2012;2012:395757. doi: 10.1155/2012/395757. PMID: 22523671. Exclusion Code: X2.22523671
94 d’Annunzio G, Vanelli M, Pistorio A, . Insulin resistance and secretion indexes in healthy Italian children and adolescents: a multicentre study. Acta Biomed. 2009 Apr;80(1):21–8. PMID: 19705616. Exclusion Code: X2.19705616
95 Davies MJ, Bain SC, Atkin SL, . Efficacy and safety of liraglutide versus placebo as add-on to glucose-lowering therapy in patients with type 2 diabetes and moderate renal impairment (LIRA-RENAL): a randomized clinical trial. Diabetes Care. 2016 Feb;39(2):222–30. doi: 10.2337/dc14-2883. PMID: 26681713. Exclusion Code: X2.26681713
96 Davis CL, Pollock NK, Waller JL, . Exercise dose and diabetes risk in overweight and obese children: a randomized controlled trial. JAMA. 2012 Sep 19;308(11):1103–12. doi: 10.1001/2012.jama.10762. PMID: 22990269. Exclusion Code: X2.22990269
97 Davis JN, Gyllenhammer LE, Vanni AA, . Startup circuit training program reduces metabolic risk in Latino adolescents. Med Sci Sports Exerc. 2011 Nov;43(11):2195–203. doi: 10.1249/MSS.0b013e31821f5d4e. PMID: 21502883. Exclusion Code: X2.21502883
98 Davis JN, Kelly LA, Lane CJ, . Randomized control trial to improve adiposity and insulin resistance in overweight Latino adolescents. Obesity (Silver Spring, MD.). 2009;17(8):1542–8. doi: 10.1038/oby.2009.19. PMID: CN-00720224. Exclusion Code: X2.
99 Davis JN, Tung A, Chak SS, . Aerobic and strength training reduces adiposity in overweight Latina adolescents. Med Sci Sports Exerc. 2009 Jul;41(7):1494–503. doi: 10.1249/MSS.0b013e31819b6aea. PMID: 19516150. Exclusion Code: X2.19516150
100 Davis JN, Ventura EE, Tung A, . Effects of a randomized maintenance intervention on adiposity and metabolic risk factors in overweight minority adolescents. Pediatr Obes. 2012 Feb;7(1):16–27. doi: 10.1111/j.2047-6310.2011.00002.x. PMID: 22434736. Exclusion Code: X2.22434736
101 de Moraes MM, Mediano MFF, de Souza RAG, . Discouraging soft drink consumption reduces blood glucose and cholesterol of Brazilian elementary students: Secondary analysis of a randomized controlled trial. Prev Med. 2017 Jul;100:223–8. doi: 10.1016/j.ypmed.2017.04.035. PMID: 28457714. Exclusion Code: X4.28457714
102 DeBar LL, Schneider M, Ford EG, . Social marketing-based communications to integrate and support the HEALTHY study intervention. Int J Obes (Lond). 2009 Aug;33 Suppl 4(Suppl 4):S52–9. doi: 10.1038/ijo.2009.117. PMID: 19623190. Exclusion Code: X6.19623190
103 DeBoer MD, Gurka MJ. Low sensitivity of the metabolic syndrome to identify adolescents with impaired glucose tolerance: an analysis of NHANES 1999-2010. Cardiovasc Diabetol. 2014 Apr 23;13:83. doi: 10.1186/1475-2840-13-83. PMID: 24755002. Exclusion Code: X6.24755002
104 DeBoer MD, Gurka MJ, Morrison JA, . Inter-relationships between the severity of metabolic syndrome, insulin and adiponectin and their relationship to future type 2 diabetes and cardiovascular disease. Int J Obes (Lond). 2016 Sep;40(9):1353–9. doi: 10.1038/ijo.2016.81. PMID: 27133621. Exclusion Code: X2.27133621
105 Deehan EC, Colin-Ramirez E, Triador L, . Efficacy of metformin and fermentable fiber combination therapy in adolescents with severe obesity and insulin resistance: study protocol for a double-blind randomized controlled trial. Trials. 2021 Feb 17;22(1):148. doi: 10.1186/s13063-021-05060-8. PMID: 33596993. Exclusion Code: X5.33596993
106 DeFronzo RA, Hissa MN, Garber AJ, . The efficacy and safety of saxagliptin when added to metformin therapy in patients with inadequately controlled type 2 diabetes with metformin alone. Diabetes Care. 2009 Sep;32(9):1649–55. doi: 10.2337/dc08-1984. PMID: 19478198. Exclusion Code: X2.19478198
107 Del Prato S, Barnett AH, Huisman H, . Effect of linagliptin monotherapy on glycaemic control and markers of β-cell function in patients with inadequately controlled type 2 diabetes: a randomized controlled trial. Diabetes Obes Metab. 2011 Mar;13(3):258–67. doi: 10.1111/j.1463-1326.2010.01350.x. PMID: 21205122. Exclusion Code: X2.21205122
108 Delahanty L, Kriska A, Edelstein S, . Self-reported dietary intake of youth with recent onset of type 2 diabetes: results from the TODAY study. J Acad Nutr Diet. 2013 Mar;113(3):431–9. doi: 10.1016/j.jand.2012.11.015. PMID: 23438494. Exclusion Code: X6.23438494
109 Deschamps I, Heptner W, Desjeux JF, . Effects of diet on insulin and gastric inhibitory polypeptide levels in obese children. Pediatr Res. 1980 Apr;14(4 Pt 1):300–3. doi: 10.1203/00006450-198004000-00008. PMID: 6990366. Exclusion Code: X8.6990366
110 Dhaliwal R, Shepherd JA, El Ghormli L, . Changes in visceral and subcutaneous fat in youth with type 2 diabetes in the TODAY Study. Diabetes Care. 2019 Aug;42(8):1549–59. doi: 10.2337/dc18-1935. PMID: 31167889. Exclusion Code: X6.31167889
111 Di Bonito P, Pacifico L, Chiesa C, . Impaired fasting glucose and impaired glucose tolerance in children and adolescents with overweight/obesity. J Endocrinol Invest. 2017 Apr;40(4):409–16. doi: 10.1007/s40618-016-0576-8. PMID: 27854028. Exclusion Code: X4.27854028
112 Diaz-Zavala RG, Esparza-Romero J, Moya-Camarena SY, . Improvement of insulin sensitivity after an intensive lifestyle program for youth’s weight management in the primary care. Arch Latinoam Nutr. 2012;62(3):258–66. PMID: CN-01048157. Exclusion Code: X1.24617028
113 Dobson R, Whittaker R, Jiang Y, . Effectiveness of text message based, diabetes self management support programme (SMS4BG): two arm, parallel randomised controlled trial. BMJ. 2018 May 17;361:k1959. doi: 10.1136/bmj.k1959. PMID: 29773539. Exclusion Code: X2.29773539
114 Dolan LM, Bean J, D’Alessio D, . Frequency of abnormal carbohydrate metabolism and diabetes in a population-based screening of adolescents. J Pediatr. 2005 Jun;146(6):751–8. doi: 10.1016/j.jpeds.2005.01.045. PMID: 15973311. Exclusion Code: X8.15973311
115 Dore DD, Bloomgren GL, Wenten M, . A cohort study of acute pancreatitis in relation to exenatide use. Diabetes Obes Metab. 2011 Jun;13(6):559–66. doi: 10.1111/j.1463-1326.2011.01376.x. PMID: 21320263. Exclusion Code: X2.21320263
116 Dorenbos E, Drummen M, Adam T, . Effect of a high protein/low glycaemic index diet on insulin resistance in adolescents with overweight/obesity—A PREVIEW randomized clinical trial. Pediatr Obes. 2020doi: 10.1111/ijpo.12702. PMID: CN-02139974. Exclusion Code: X5.
117 Dorenbos E, Drummen M, Rijks J, . PREVIEW (Prevention of Diabetes Through Lifestyle Intervention and Population Studies in Europe and Around the World) study in children aged 10 to 17 years: Design, methods and baseline results. Diabetes Obes Metab. 2018 May;20(5):1096–101. doi: 10.1111/dom.13216. PMID: 29322617. Exclusion Code: X5.29322617
118 Dreyfus JG, Lutsey PL, Huxley R, . Age at menarche and risk of type 2 diabetes among African-American and white women in the Atherosclerosis Risk in Communities (ARIC) study. Diabetologia. 2012 Sep;55(9):2371–80. doi: 10.1007/s00125-012-2616-z. PMID: 22760786. Exclusion Code: X5.22760786
119 Duncan S, Stewart T, McPhee J, . Efficacy of a compulsory homework programme for increasing physical activity and improving nutrition in children: a cluster randomised controlled trial. Int J Behav Nutr Phys Act. 2019;16(1):N.PAG. doi: 10.1186/s12966-019-0840-3. PMID: CN-02117475. Exclusion Code: X7.
120 Edwards NM, Daniels SR, Claytor RP, . Physical activity is independently associated with multiple measures of arterial stiffness in adolescents and young adults. Metabolism. 2012 Jun;61(6):869–72. doi: 10.1016/j.metabol.2011.10.016. PMID: 22153839. Exclusion Code: X8.22153839
121 Ehrlich RM, Martin JM. Early diabetes mellitus in children. Metabolism. 1973 Feb;22(2):391–2. doi: 10.1016/0026-0495(73)90197-2. PMID: 4687967. Exclusion Code: X5.4687967
122 Eisenmann JC, DuBose KD, Donnelly JE. Fatness, fitness, and insulin sensitivity among 7- to 9-year-old children. Obesity (Silver Spring). 2007 Aug;15(8):2135–44. doi: 10.1038/oby.2007.254. PMID: 17712133. Exclusion Code: X4.17712133
123 Elder DA, Hornung LN, Herbers PM, . Rapid deterioration of insulin secretion in obese adolescents preceding the onset of type 2 diabetes. J Pediatr. 2015 Mar;166(3):672–8. doi: 10.1016/j.jpeds.2014.11.029. PMID: 25557969. Exclusion Code: X4.25557969
124 Elks CE, Ong KK, Scott RA, . Age at menarche and type 2 diabetes risk: the EPIC-InterAct study. Diabetes Care. 2013 Nov;36(11):3526–34. doi: 10.2337/dc13-0446. PMID: 24159179. Exclusion Code: X4.24159179
125 Emerson P, Van Haeften TW, Pimenta W, . Different pathophysiology of impaired glucose tolerance in first-degree relatives of individuals with type 2 diabetes mellitus. Metabolism. 2009 May;58(5):602–7. doi: 10.1016/j.metabol.2008.12.004. PMID: 19375581. Exclusion Code: X2.19375581
126 Eppens MC, Craig ME, Cusumano J, . Prevalence of diabetes complications in adolescents with type 2 compared with type 1 diabetes. Diabetes Care. 2006 Jun;29(6):1300–6. doi: 10.2337/dc05-2470. PMID: 16732012. Exclusion Code: X8.16732012
127 Escudero-Carretero MJ, Prieto-Rodríguez M, Fernández-Fernández I, . Expectations held by type 1 and 2 diabetes mellitus patients and their relatives: the importance of facilitating the health-care process. Health Expect. 2007 Dec;10(4):337–49. doi: 10.1111/j.1369-7625.2007.00452.x. PMID: 17986070. Exclusion Code: X8.17986070
128 Esposito K, Chiodini P, Bellastella G, . Proportion of patients at HbA1c target <7% with eight classes of antidiabetic drugs in type 2 diabetes: systematic review of 218 randomized controlled trials with 78 945 patients. Diabetes Obes Metab. 2012 Mar;14(3):228–33. doi: 10.1111/j.1463-1326.2011.01512.x. PMID: 21958121. Exclusion Code: X8.21958121
129 Fajans SS, Herman WH, Oral EA. Insufficient sensitivity of hemoglobin A(₁C) determination in diagnosis or screening of early diabetic states. Metabolism. 2011 Jan;60(1):86–91. doi: 10.1016/j.metabol.2010.06.017. PMID: 20723948. Exclusion Code: X2.20723948
130 Farabi SS, Carley DW, Smith D, . Impact of exercise on diurnal and nocturnal markers of glycaemic variability and oxidative stress in obese individuals with type 2 diabetes or impaired glucose tolerance. Diab Vasc Dis Res. 2015;12(5):381–5. doi: 10.1177/1479164115579003. PMID: CN-01258209. Exclusion Code: X2.25994591
131 Farahmand M, Tehrani FR, Dovom MR, . Menarcheal age and risk of type 2 diabetes: a community-based cohort study. J Clin Res Pediatr Endocrinol. 2017 Jun 1;9(2):156–62. doi: 10.4274/jcrpe.3370. PMID: 27840328. Exclusion Code: X5.27840328
132 Faulkner MS, Michaliszyn SF. Exercise Adherence in Hispanic Adolescents with Obesity or Type 2 Diabetes. J Pediatr Nurs. 2021 Jan–Feb;56:7–12. doi: 10.1016/j.pedn.2020.09.012. PMID: 33181374. Exclusion Code: X5.33181374
133 Feigerlová E, Pruhová S, Dittertová L, . Aetiological heterogeneity of asymptomatic hyperglycaemia in children and adolescents. Eur J Pediatr. 2006 Jul;165(7):446–52. doi: 10.1007/s00431-006-0106-3. PMID: 16602010. Exclusion Code: X5.16602010
134 Fernandes RA, Zanesco A. Early physical activity promotes lower prevalence of chronic diseases in adulthood. Hypertens Res. 2010 Sep;33(9):926–31. doi: 10.1038/hr.2010.106. PMID: 20574424. Exclusion Code: X8.20574424
135 Fernandez RS, Frost S. Congruence between the Indian Diabetes Risk Score and Australian Type 2 Diabetes Risk Assessment tool screening in Asian-Indians. Nurse Res. 2013 Nov;21(2):36–9. doi: 10.7748/nr2013.11.21.2.36.e215. PMID: 24171636. Exclusion Code: X2.24171636
136 Ferrannini E, Berk A, Hantel S, . Long-term safety and efficacy of empagliflozin, sitagliptin, and metformin: an active-controlled, parallel-group, randomized, 78-week open-label extension study in patients with type 2 diabetes. Diabetes Care. 2013 Dec;36(12):4015–21. doi: 10.2337/dc13-0663. PMID: 24186878. Exclusion Code: X2.24186878
137 Filozof C, Gautier JF. A comparison of efficacy and safety of vildagliptin and gliclazide in combination with metformin in patients with Type 2 diabetes inadequately controlled with metformin alone: a 52-week, randomized study. Diabet Med. 2010 Mar;27(3):318–26. doi: 10.1111/j.1464-5491.2010.02938.x. PMID: 20536495. Exclusion Code: X2.20536495
138 Fiorentino TV, Pedace E, Succurro E, . Individuals with prediabetes display different age-related pathophysiological characteristics. J Clin Endocrinol Metab. 2019 Jul 1;104(7):2911–24. doi: 10.1210/jc.2018-02610. PMID: 30848793. Exclusion Code: X2.30848793
139 Fogelholm M, Larsen TM, Westerterp-Plantenga M, . PREVIEW-Design, methods and baseline participant description of an international intervention to prevent type-2 diabetes. Ann Nutr Metab. 2015;67:414. doi: 10.1159/000440895. PMID: CN-01160326. Exclusion Code: X2.
140 Fonseca V, Staels B, Morgan JD, 2nd, . Efficacy and safety of sitagliptin added to ongoing metformin and pioglitazone combination therapy in a randomized, placebo-controlled, 26-week trial in patients with type 2 diabetes. J Diabetes Complications. 2013 Mar–Apr;27(2):177–83. doi: 10.1016/j.jdiacomp.2012.09.007. PMID: 23116881. Exclusion Code: X2.23116881
141 Forjuoh SN, Bolin JN, Huber JC, Jr., . Behavioral and technological interventions targeting glycemic control in a racially/ethnically diverse population: a randomized controlled trial. BMC Public Health. 2014 Jan 23;14:71. doi: 10.1186/1471-2458-14-71. PMID: 24450992. Exclusion Code: X2.24450992
142 Forslund A, Weghuber D, Paulmichl K, . Exenatide once weekly reduces weight, liver fat and 2-hour postprandial glucose in obese adolescents. Acta Paediatrica, International Journal of Paediatrics. 2017;106:14–5. PMID: CN-01439712. Exclusion Code: X10.
143 Foster GD, Linder B, Baranowski T, . A school-based intervention for diabetes risk reduction. N Engl J Med. 2010 Jul 29;363(5):443–53. doi: 10.1056/NEJMoa1001933. PMID: 20581420. Exclusion Code: X2.20581420
144 Fox LA, Fraser IP, Neufield N, . Metabolic effects and safety of single rising-dose sitagliptin in adolescents with type 2 diabetes. Diabetes. 2013;62:A341. doi: 10.2337/db13-859-1394. PMID: CN-01065245. Exclusion Code: X10.
145 Fraser IP, Neufeld ND, Fox LA, . A randomized clinical trial to evaluate the single-dose pharmacokinetics, pharmacodynamics, and safety of sitagliptin in pediatric patients with type 2 diabetes. Pediatr Diabetes. 2019 Feb;20(1):48–56. doi: 10.1111/pedi.12790. PMID: 30346099. Exclusion Code: X2.30346099
146 Freemark M, Bursey D. A therapeutic trial of metformin in obese adolescents predisposed to type 2 diabetes mellitus. Pediatr Res. 2000;47(4):128A. PMID: CN-00400965. Exclusion Code: X2.
147 Freemark M, Bursey D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Pediatrics. 2001 Apr;107(4):E55. doi: 10.1542/peds.107.4.e55. PMID: 11335776. Exclusion Code: X2.11335776
148 Galhardo J, Shield J. The role of haemoglobin A1c in screening obese children and adolescents for glucose intolerance and type 2 diabetes. Acta Med Port. 2015 May–Jun;28(3):307–15. PMID: 26421782. Exclusion Code: X8.26421782
149 Gallwitz B, Vaag A, Falahati A, . Adding liraglutide to oral antidiabetic drug therapy: onset of treatment effects over time. Int J Clin Pract. 2010 Jan;64(2):267–76. doi: 10.1111/j.1742-1241.2009.02265.x. PMID: 19925617. Exclusion Code: X2.19925617
150 Garnett SP, Baur LA, Noakes M, . Researching effective strategies to improve insulin sensitivity in children and teenagers - RESIST. A randomised control trial investigating the effects of two different diets on insulin sensitivity in young people with insulin resistance and/or pre-diabetes. BMC Public Health. 2010 Sep 25;10:575. doi: 10.1186/1471-2458-10-575. PMID: 20868506. Exclusion Code: X6.20868506
151 Garnett SP, Gow M, Ho M, . Improved insulin sensitivity and body composition, irrespective of macronutrient intake, after a 12 month intervention in adolescents with pre-diabetes; RESIST a randomised control trial. BMC Pediatr. 2014 Nov 25;14:289. doi: 10.1186/s12887-014-0289-0. PMID: 25422027. Exclusion Code: X5.25422027
152 Garnett SP, Srinivasan S, Birt SG, . Evaluation of glycaemic status in young people with clinical insulin resistance; fasting glucose, fasting insulin or an oral glucose tolerance test? Clin Endocrinol (Oxf). 2010 Apr;72(4):475–80. doi: 10.1111/j.1365-2265.2009.03677.x. PMID: 19656159. Exclusion Code: X8.19656159
153 Gastaldelli A, Nauck MA, Balena R. Eight weeks of treatment with long-acting GLP-1 analog taspoglutide improves postprandial insulin secretion and sensitivity in metformin-treated patients with type 2 diabetes. Metabolism. 2013 Sep;62(9):1330–9. doi: 10.1016/j.metabol.2013.05.001. PMID: 23831441. Exclusion Code: X2.23831441
154 Geloneck MM, Forbes BJ, Shaffer J, . Ocular complications in children with diabetes mellitus. Ophthalmology. 2015 Dec;122(12):2457–64. doi: 10.1016/j.ophtha.2015.07.010. PMID: 26341461. Exclusion Code: X4.26341461
155 Gidding SS, Bacha F, Bjornstad P, . Cardiac biomarkers in youth with type 2 diabetes mellitus: results from the TODAY Study. J Pediatr. 2018 Jan;192:86–92.e5. doi: 10.1016/j.jpeds.2017.09.012. PMID: 29246363. Exclusion Code: X6.29246363
156 Gillani SW. Determining effective diabetic care; a multicentre - longitudinal interventional study. Curr Pharm Des. 2016;22(42):6469–76. doi: 10.2174/1381612822666160813235704. PMID: 27526787. Exclusion Code: X2.27526787
157 Gillis B, Mobley C, Stadler DD, . Rationale, design and methods of the HEALTHY study nutrition intervention component. Int J Obes (Lond). 2009 Aug;33 Suppl 4(Suppl 4):S29–36. doi: 10.1038/ijo.2009.114. PMID: 19623185. Exclusion Code: X6.19623185
158 Glueck CJ, Mellies MJ, Srivastava L, . Insulin, obesity, and triglyceride interrelationships in sixteen children with familial hypertriglyceridemia. Pediatr Res. 1977 Jan;11(1 Pt 1):13–9. PMID: 318742. Exclusion Code: X6.318742
159 Gokcel A, Baltali M, Tarim E, . Detection of insulin resistance in Turkish adults: a hospital-based study. Diabetes Obes Metab. 2003 Mar;5(2):126–30. doi: 10.1046/j.1463-1326.2003.00253.x. PMID: 12630938. Exclusion Code: X2.12630938
160 Gómez-Díaz RA, Talavera JO, Pool EC, . Metformin decreases plasma resistin concentrations in pediatric patients with impaired glucose tolerance: a placebo-controlled randomized clinical trial. Metabolism. 2012 Sep;61(9):1247–55. doi: 10.1016/j.metabol.2012.02.003. PMID: 22424822. Exclusion Code: X9.22424822
161 Gomis R, Espadero RM, Jones R, . Efficacy and safety of initial combination therapy with linagliptin and pioglitazone in patients with inadequately controlled type 2 diabetes: a randomized, double-blind, placebo-controlled study. Diabetes Obes Metab. 2011 Jul;13(7):653–61. doi: 10.1111/j.1463-1326.2011.01391.x. PMID: 21410628. Exclusion Code: X2.21410628
162 Goodman M, Thurston H, Penman J. Efficacy and tolerability of vildagliptin in patients with type 2 diabetes inadequately controlled with metformin monotherapy. Horm Metab Res. 2009 May;41(5):368–73. doi: 10.1055/s-0028-1104604. PMID: 19221978. Exclusion Code: X2.19221978
163 Goran MI, Shaibi GQ, Weigensberg MJ, . Deterioration of insulin sensitivity and beta-cell function in overweight Hispanic children during pubertal transition: a longitudinal assessment. Int J Pediatr Obes. 2006;1(3):139–45. doi: 10.1080/17477160600780423. PMID: 17899631. Exclusion Code: X4.17899631
164 Gore MO, Eason SJ, Ayers CR, . Glycated hemoglobin in 14,850 adolescent blood donors: a pilot screening program. Diabetes Care. 2014;37(1):e3–4. doi: 10.2337/dc13-0908. PMID: 24356607. Exclusion Code: X3.24356607
165 Gore MO, Eason SJ, Ayers CR, . High prevalence of elevated haemoglobin A1C among adolescent blood donors: Results from a voluntary screening programme including 31,546 adolescents. Diab Vasc Dis Res. 2015 Jul;12(4):272–8. doi: 10.1177/1479164115579799. PMID: 25972340. Exclusion Code: X8.25972340
166 Gow ML, Baur LA, Johnson NA, . Reversal of type 2 diabetes in youth who adhere to a very-low-energy diet: a pilot study. Diabetologia. 2017 Mar;60(3):406–15. doi: 10.1007/s00125-016-4163-5. PMID: 27889809. Exclusion Code: X5.27889809
167 Grey M, Berry D, Davidson M, . Preliminary testing of a program to prevent type 2 diabetes among high-risk youth. J Sch Health. 2004 Jan;74(1):10–5. doi: 10.1111/j.1746-1561.2004.tb06595.x. PMID: 15022370. Exclusion Code: X2.15022370
168 Grillo Mde F, Neumann CR, Scain SF, . Diabetes education in primary care: a randomized clinical trial. Cad Saude Publica. 2016 May 31;32(5)doi: 10.1590/0102-311x00097115. PMID: 27253458. Exclusion Code: X2.27253458
169 Grønbæk H, Lange A, Birkebæk NH, . Effect of a 10-week weight loss camp on fatty liver disease and insulin sensitivity in obese Danish children. J Pediatr Gastroenterol Nutr. 2012 Feb;54(2):223–8. doi: 10.1097/MPG.0b013e31822cdedf. PMID: 21760546. Exclusion Code: X5.21760546
170 Groot CJ, Grond JV, Delgado Y, . High predictability of impaired glucose tolerance by combining cardiometabolic screening parameters in obese children. J Pediatr Endocrinol Metab. 2017 Feb 1;30(2):189–96. doi: 10.1515/jpem-2016-0289. PMID: 28076317. Exclusion Code: X8.28076317
171 Gumbiner B, Esteves B, Dell V, . Single and multiple ascending-dose study of glucagon-receptor antagonist RN909 in type 2 diabetes: a phase 1, randomized, double-blind, placebo-controlled trial. Endocrine. 2018 Nov;62(2):371–80. doi: 10.1007/s12020-018-1597-1. PMID: 30203123. Exclusion Code: X2.30203123
172 Gumus P, Gomez R, Vargas A, . The relationship of insulin secretion and GAD65 antibody levels at diagnosis on glycemic control in type 2 diabetes. J Pediatr Endocrinol Metab. 2010 Oct;23(10):1025–9. doi: 10.1515/jpem.2010.163. PMID: 21158213. Exclusion Code: X8.21158213
173 Gustavson SM, Chen D, Somayaji V, . Effects of a long-acting GLP-1 mimetic (PF-04603629) on pulse rate and diastolic blood pressure in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2011;13(11):1056–8. doi: 10.1111/j.1463-1326.2011.01479.x. PMID: CN-00810261. Exclusion Code: X2.21812891
174 Hagman E, Ek AE, Marcus C. Insulin function in obese children within the low and high ranges of impaired fasting glycemia. Pediatr Diabetes. 2019 Mar;20(2):160–5. doi: 10.1111/pedi.12804. PMID: 30537059. Exclusion Code: X2.30537059
175 Hannon TS, Dugan TM, Saha CK, . Effectiveness of computer automation for the diagnosis and management of childhood type 2 diabetes: a randomized clinical trial. JAMA Pediatr. 2017 Apr 1;171(4):327–34. doi: 10.1001/jamapediatrics.2016.4207. PMID: 28192551. Exclusion Code: X4.28192551
176 Hannon TS, Edelstein SL, Arslanian SA, . Withdrawal of medications leads to worsening of OGTT parameters in youth with impaired glucose tolerance or recently-diagnosed type 2 diabetes. Pediatr Diabetes. 2020 Dec;21(8):1437–46. doi: 10.1111/pedi.13129. PMID: 32985775. Exclusion Code: X5.32985775
177 Hansel B, Giral P, Gambotti L, . A fully automated web-based program improves lifestyle habits and HbAa1c in patients with type 2 diabetes and abdominal obesity: randomized trial of patient e-coaching nutritional support (The ANODE Study). J Med Internet Res. 2017 Nov 8;19(11):e360. doi: 10.2196/jmir.7947. PMID: 29117929. Exclusion Code: X2.29117929
178 Harder-Lauridsen NM, Birk NM, Ried-Larsen M, . A randomized controlled trial on a multicomponent intervention for overweight school-aged children - Copenhagen, Denmark. BMC Pediatr. 2014;14:273. doi: 10.1186/1471-2431-14-273. PMID: CN-01112964. Exclusion Code: X2.25330848
179 Harris MA, Freeman KA, Beers M. Family therapy for adolescents with poorly controlled diabetes: initial test of clinical significance. J Pediatr Psychol. 2009;34(10):1097–107. doi: 10.1093/jpepsy/jsp009. PMID: CN-00730018. Exclusion Code: X2.19264879
180 Hasson RE, Adam TC, Davis JN, . Randomized controlled trial to improve adiposity, inflammation, and insulin resistance in obese African-American and Latino youth. Obesity (Silver Spring). 2012 Apr;20(4):811–8. doi: 10.1038/oby.2010.343. PMID: 21293446. Exclusion Code: X2.21293446
181 Hauner H, Hanisch J, Bramlage P, . Prevalence of undiagnosed Type-2-diabetes mellitus and impaired fasting glucose in German primary care: data from the German Metabolic and Cardiovascular Risk Project (GEMCAS). Exp Clin Endocrinol Diabetes. 2008 Jan;116(1):18–25. doi: 10.1055/s-2007-985359. PMID: 17926235. Exclusion Code: X2.17926235
182 Hazreen MA, Su TT, Jalaludin MY, . An exploratory study on risk factors for chronic non-communicable diseases among adolescents in Malaysia: overview of the Malaysian Health and Adolescents Longitudinal Research Team study (The MyHeART study). BMC Public Health. 2014;14 Suppl 3(Suppl 3):S6. doi: 10.1186/1471-2458-14-s3-s6. PMID: 25437068. Exclusion Code: X5.25437068
183 Heath GW, Leonard BE, Wilson RH, . Community-based exercise intervention: Zuni Diabetes Project. Diabetes Care. 1987 Sep–Oct;10(5):579–83. doi: 10.2337/diacare.10.5.579. PMID: 3677975. Exclusion Code: X2.3677975
184 Henderson M, Benedetti A, Barnett TA, . Influence of adiposity, physical activity, fitness, and screen time on insulin dynamics over 2 years in children. JAMA Pediatr. 2016 Mar;170(3):227–35. doi: 10.1001/jamapediatrics.2015.3909. PMID: 26857733. Exclusion Code: X8.26857733
185 Henderson M, Benedetti A, Gray-Donald K. Dietary composition and its associations with insulin sensitivity and insulin secretion in youth. Br J Nutr. 2014 Feb;111(3):527–34. doi: 10.1017/s0007114513002572. PMID: 24047611. Exclusion Code: X8.24047611
186 Hennessey JV, Bustamante MA, Teter ML, . Bedtime dosing of glyburide and the treatment of type II diabetes mellitus. Am J Med Sci. 1994 Oct;308(4):234–8. doi: 10.1097/00000441-199430840-00004. PMID: 7942982. Exclusion Code: X2.7942982
187 Henry RR, Aroda VR, Mudaliar S, . Effects of colesevelam on glucose absorption and hepatic/peripheral insulin sensitivity in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2012 Jan;14(1):40–6. doi: 10.1111/j.1463-1326.2011.01486.x. PMID: 21831167. Exclusion Code: X2.21831167
188 Henry RR, Mudaliar S, Kanitra L, . Efficacy and safety of taspoglutide in patients with type 2 diabetes inadequately controlled with metformin plus pioglitazone over 24 weeks: T-Emerge 3 trial. J Clin Endocrinol Metab. 2012 Jul;97(7):2370–9. doi: 10.1210/jc.2011-3253. PMID: 22539590. Exclusion Code: X2.22539590
189 Henry RR, Murray AV, Marmolejo MH, . Dapagliflozin, metformin XR, or both: initial pharmacotherapy for type 2 diabetes, a randomised controlled trial. Int J Clin Pract. 2012 May;66(5):446–56. doi: 10.1111/j.1742-1241.2012.02911.x. PMID: 22413962. Exclusion Code: X2.22413962
190 Henry RR, Staels B, Fonseca VA, . Efficacy and safety of initial combination treatment with sitagliptin and pioglitazone--a factorial study. Diabetes Obes Metab. 2014 Mar;16(3):223–30. doi: 10.1111/dom.12194. PMID: 23909985. Exclusion Code: X2.23909985
191 Herbst A, Kapellen T, Schober E, . Impact of regular physical activity on blood glucose control and cardiovascular risk factors in adolescents with type 2 diabetes mellitus--a multicenter study of 578 patients from 225 centres. Pediatr Diabetes. 2015 May;16(3):204–10. doi: 10.1111/pedi.12144. PMID: 24888254. Exclusion Code: X8.24888254
192 Hermansen K, Kipnes M, Luo E, . Efficacy and safety of the dipeptidyl peptidase-4 inhibitor, sitagliptin, in patients with type 2 diabetes mellitus inadequately controlled on glimepiride alone or on glimepiride and metformin. Diabetes Obes Metab. 2007 Sep;9(5):733–45. doi: 10.1111/j.1463-1326.2007.00744.x. PMID: 17593236. Exclusion Code: X2.17593236
193 Hingle MD, Turner T, Going S, . Feasibility of a family-focused YMCA-based diabetes prevention program in youth: The E.P.I.C. Kids (Encourage, Practice, and Inspire Change) Study. Prev Med Rep. 2019 Jun;14:100840. doi: 10.1016/j.pmedr.2019.100840. PMID: 30911460. Exclusion Code: X2.30911460
194 Hitt JM, Velasquez-Mieyer P, Neira C, . Factors affecting hemoglobin A1C in the diagnosis of diabetes and prediabetes in youth. J Pediatr Nurs. 2016 Sep–Oct;31(5):511–8. doi: 10.1016/j.pedn.2016.03.020. PMID: 27132801. Exclusion Code: X8.27132801
195 Ho M, Gow M, Baur LA, . Effect of fat loss on arterial elasticity in obese adolescents with clinical insulin resistance: RESIST study. J Clin Endocrinol Metab. 2014 Oct;99(10):E1846–53. doi: 10.1210/jc.2014-1944. PMID: 24955610. Exclusion Code: X6.24955610
196 Ho M, Heath AM, Gow M, . Zinc intake, zinc bioavailability and plasma zinc in obese adolescents with clinical insulin resistance following low energy diets. Ann Nutr Metab. 2016;69(2):135–41. doi: 10.1159/000450728. PMID: CN-01286479. Exclusion Code: X8.27750250
197 Hogg J, Diaz A, Del Cid M, . An after-school dance and lifestyle education program reduces risk factors for heart disease and diabetes in elementary school children. J Pediatr Endocrinol Metab. 2012;25(5–6):509–16. doi: 10.1515/jpem-2012-0027. PMID: 22876547. Exclusion Code: X2.22876547
198 Hollander P, Lasko B, Barnett AH, . Effects of taspoglutide on glycemic control and body weight in obese patients with type 2 diabetes (T-emerge 7 study). Obesity (Silver Spring). 2013 Feb;21(2):238–47. doi: 10.1002/oby.20042. PMID: 23404788. Exclusion Code: X2.23404788
199 Hollander P, Li J, Allen E, . Saxagliptin added to a thiazolidinedione improves glycemic control in patients with type 2 diabetes and inadequate control on thiazolidinedione alone. J Clin Endocrinol Metab. 2009 Dec;94(12):4810–9. doi: 10.1210/jc.2009-0550. PMID: 19864452. Exclusion Code: X2.19864452
200 Hollander PA, Amod A, Litwak LE, . Effect of rimonabant on glycemic control in insulin-treated type 2 diabetes: the ARPEGGIO trial. Diabetes Care. 2010;33(3):605–7. doi: 10.2337/dc09-0455. PMID: CN-00748784. Exclusion Code: X2.20009090
201 Horowitz M, Flint A, Jones KL, . Effect of the once-daily human GLP-1 analogue liraglutide on appetite, energy intake, energy expenditure and gastric emptying in type 2 diabetes. Diabetes Res Clin Pract. 2012 Aug;97(2):258–66. doi: 10.1016/j.diabres.2012.02.016. PMID: 22446097. Exclusion Code: X2.22446097
202 Hsia SH. Insulin glargine compared to NPH among insulin-naïve, U.S. inner city, ethnic minority type 2 diabetic patients. Diabetes Res Clin Pract. 2011;91(3):293–9. doi: 10.1016/j.diabres.2010.11.028. PMID: CN-00785671. Exclusion Code: X5.21146881
203 Huang SH, Weng KP, Hsieh KS, . Effects of a classroom-based weight-control intervention on cardiovascular disease in elementary-school obese children. Acta Paediatr Taiwan. 2007 Jul–Aug;48(4):201–6. PMID: 18265541. Exclusion Code: X2.18265541
204 Huo X, Spatz ES, Ding Q, . Design and rationale of the Cardiovascular Health and Text Messaging (CHAT) Study and the CHAT-Diabetes Mellitus (CHAT-DM) Study: two randomised controlled trials of text messaging to improve secondary prevention for coronary heart disease and diabetes. BMJ Open. 2017 Dec 21;7(12):e018302. doi: 10.1136/bmjopen-2017-018302. PMID: 29273661. Exclusion Code: X2.29273661
205 Huus K, Åkerman L, Raustorp A, . Physical activity, blood glucose and c-peptide in healthy school-children, a longitudinal study. PLoS One. 2016;11(6):e0156401. doi: 10.1371/journal.pone.0156401. PMID: 27270732. Exclusion Code: X4.27270732
206 Huys N, Van Stappen V, Shadid S, . Effectiveness of a family-, school- and community-based intervention on physical activity and its correlates in Belgian families with an increased risk for type 2 diabetes mellitus: the Feel4Diabetes-study. BMC Public Health. 2020 Aug 12;20(1):1231. doi: 10.1186/s12889-020-09336-7. PMID: 32787943. Exclusion Code: X2.32787943
207 Inci F, Atmaca M, Ozturk M, . Pantoprazole may improve beta cell function and diabetes mellitus. J Endocrinol Invest. 2014 May;37(5):449–54. doi: 10.1007/s40618-013-0040-y. PMID: 24682913. Exclusion Code: X5.24682913
208 Inge TH, Laffel LM, Jenkins TM, . Comparison of surgical and medical therapy for type 2 diabetes in severely obese adolescents. JAMA Pediatr. 2018 May 1;172(5):452–60. doi: 10.1001/jamapediatrics.2017.5763. PMID: 29532078. Exclusion Code: X5.29532078
209 Islam N, Gepts T, Lief I, . Protocol for the CHORD project (community health outreach to reduce diabetes): a cluster-randomized community health worker trial to prevent diabetes. BMC Public Health. 2018 Apr 19;18(1):521. doi: 10.1186/s12889-018-5419-4. PMID: 29673333. Exclusion Code: X2.29673333
210 Jackman MM, Nabors LA, McPherson CL, . Feasibility, acceptability, and preliminary effectiveness of the OpenMind (OM) program for pre-school children. J Child Fam Stud. 2019;28(10):2910–21. doi: 10.1007/s10826-019-01506-5. PMID: CN-02117498. Exclusion Code: X2.
211 Jaiswal M, Divers J, Dabelea D, . Prevalence of and risk factors for diabetic peripheral neuropathy in youth with type 1 and type 2 diabetes: SEARCH for diabetes in youth study. Diabetes Care. 2017 Sep;40(9):1226–32. doi: 10.2337/dc17-0179. PMID: 28674076. Exclusion Code: X8.28674076
212 Jakicic JM. Exercise demonstrates a dose-response effect on insulin resistance, fatness, and visceral fat. J Pediatr. 2013;162(3):649–50. doi: 10.1016/j.jpeds.2012.12.059. PMID: CN-00908824. Exclusion Code: X8.
213 Jani RH, Pai V, Jha P, . A multicenter, prospective, randomized, double-blind study to evaluate the safety and efficacy of Saroglitazar 2 and 4 mg compared with placebo in type 2 diabetes mellitus patients having hypertriglyceridemia not controlled with atorvastatin therapy (PRESS VI). Diabetes Technol Ther. 2014 Feb;16(2):63–71. doi: 10.1089/dia.2013.0253. PMID: 24138536. Exclusion Code: X2.24138536
214 Janson A, Jarvholm K, Gronowitz E, . A randomized controlled trial comparing intensive non-surgical treatment with bariatric surgery in adolescents aged 13–16 years (AMOS2): rationale, study design, and patient recruitment. Contemp Clin Trials Commun. 2020;19doi: 10.1016/j.conctc.2020.100592. PMID: CN-02141054. Exclusion Code: X4.
215 Javed A, Vella A, Balagopal PP, . Effects of vitamin D supplementation on insulin sensitivity and beta cell function in obese adolescents. Endocrine Reviews. Conference: 96th annual meeting and expo of the Endocrine Society, ENDO 2014; 2014 June 21-June 24; Chicago, IL. 35. Exclusion Code: X5.
216 Jayaram S, Hariharan RS, Madhavan R, . A prospective, parallel group, open-labeled, comparative, multi-centric, active controlled study to evaluate the safety, tolerability and benefits of fixed dose combination of acarbose and metformin versus metformin alone in type 2 diabetes. J Assoc Physicians India. 2010 Nov;58:679–82, 87. PMID: 21510461. Exclusion Code: X2.21510461
217 Jefferies C, Carter P, Reed PW, . The incidence, clinical features, and treatment of type 2 diabetes in children <15 yr in a population-based cohort from Auckland, New Zealand, 1995–2007. Pediatr Diabetes. 2012 Jun;13(4):294–300. doi: 10.1111/j.1399-5448.2012.00851.x. PMID: 22646236. Exclusion Code: X6.22646236
218 Jeffery SC, Hosking J, Jeffery AN, . Insulin resistance is higher in prepubertal girls but switches to become higher in boys at age 16: a cohort study (EarlyBird 57). Pediatr Diabetes. 2018 Mar;19(2):223–30. doi: 10.1111/pedi.12571. PMID: 28851041. Exclusion Code: X8.28851041
219 Ji L, Sun N, Zhang Y, . Efficacy of metformin in preventing progression to diabetes in a Chinese population with impaired glucose regulation: Protocol for a multicentre, open-label, randomized controlled clinical study. Diabetes Obes Metab. 2020 Feb;22(2):158–66. doi: 10.1111/dom.13884. PMID: 31512365. Exclusion Code: X2.31512365
220 Johnson MS, Figueroa-Colon R, Huang TT, . Longitudinal changes in body fat in African American and Caucasian children: influence of fasting insulin and insulin sensitivity. J Clin Endocrinol Metab. 2001 Jul;86(7):3182–7. doi: 10.1210/jcem.86.7.7665. PMID: 11443186. Exclusion Code: X6.11443186
221 Johnson SR, Carter HE, Leo P, . Cost-effectiveness analysis of routine screening using massively parallel sequencing for maturity-onset diabetes of the young in a pediatric diabetes cohort: reduced health system costs and improved patient quality of life. Diabetes Care. 2019 Jan;42(1):69–76. doi: 10.2337/dc18-0261. PMID: 30523035. Exclusion Code: X2.30523035
222 Joslowski G, Halim J, Goletzke J, . Dietary glycemic load, insulin load, and weight loss in obese, insulin resistant adolescents: RESIST study. Clin Nutr. 2015 Feb;34(1):89–94. doi: 10.1016/j.clnu.2014.01.015. PMID: 24534012. Exclusion Code: X8.24534012
223 Kaar JL, Schmiege SJ, Drews K, . Evaluation of the longitudinal change in health behavior profiles across treatment groups in the TODAY clinical trial. Pediatr Diabetes. 2020;21(2):224–32. doi: 10.1111/pedi.12976. PMID: CN-02233381. Exclusion Code: X6.31886931
224 Kabaroğlu C, Ersoy B, Onur E, . Elevated glucose level at 30 minutes during an oral glucose tolerance test in obese adolescents: a new disorder of glucose tolerance. Endocr J. 2013;60(2):197–205. doi: 10.1507/endocrj.ej12-0079. PMID: 23095208. Exclusion Code: X2.23095208
225 Kasliwal R, Wilton LV, Shakir SA. Monitoring the safety of pioglitazone : results of a prescription-event monitoring study of 12,772 patients in England. Drug Saf. 2008;31(10):839–50. doi: 10.2165/00002018-200831100-00003. PMID: 18759508. Exclusion Code: X2.18759508
226 Katakura M, Aizawa T, Naka M, . Long-term prognosis of islet cell antibody-negative ketosis-onset diabetes with subsequent non-insulin dependency. Diabetes Care. 1999;22(9):1584–6. doi: 10.2337/diacare.22.9.1584a. PMID: CN-00167283. Exclusion Code: X8.
227 Katz LL, Anderson BJ, McKay SV, . Correlates of medication adherence in the TODAY cohort of youth with type 2 diabetes. Diabetes Care. 2016 Nov;39(11):1956–62. doi: 10.2337/dc15-2296. PMID: 27352955. Exclusion Code: X6.27352955
228 Kaufman FR, Hirst K, Linder B, . Risk factors for type 2 diabetes in a sixth- grade multiracial cohort: the HEALTHY study. Diabetes Care. 2009 May;32(5):953–5. doi: 10.2337/dc08-1774. PMID: 19196888. Exclusion Code: X4.19196888
229 Kawamori R, Kadowaki T, Onji M, . Hepatic safety profile and glycemic control of pioglitazone in more than 20,000 patients with type 2 diabetes mellitus: postmarketing surveillance study in Japan. Diabetes Res Clin Pract. 2007 May;76(2):229–35. doi: 10.1016/j.diabres.2006.08.017. PMID: 17109986. Exclusion Code: X2.17109986
230 Kay JP, Alemzadeh R, Langley G, . Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism. 2001 Dec;50(12):1457–61. doi: 10.1053/meta.2001.28078. PMID: 11735093. Exclusion Code: X2.11735093
231 Kelly AS, Auerbach P, Barrientos Perez M, . Liraglutide for weight management in pubertal adolescents with obesity: a randomized controlled trial. Obes Rev. 2020;21(SUPPL 1)doi: 10.1111/obr.13115. PMID: CN-02230039. Exclusion Code: X2.
232 Kelly AS, Auerbach P, Barrientos-Pérez M, . A randomized, controlled trial of liraglutide for adolescents with obesity. N Engl J Med. 2020 May 28;382(22):2117–28. doi: 10.1056/NEJMoa1916038. PMID: 32233338. Exclusion Code: X2.32233338
233 Kelly AS, Metzig AM, Rudser KD, . Exenatide as a weight-loss therapy in extreme pediatric obesity: a randomized, controlled pilot study. Obesity (Silver Spring). 2012 Feb;20(2):364–70. doi: 10.1038/oby.2011.337. PMID: 22076596. Exclusion Code: X2.22076596
234 Kelly AS, Wetzsteon RJ, Kaiser DR, . Inflammation, insulin, and endothelial function in overweight children and adolescents: the role of exercise. J Pediatr. 2004;145(6):731–6. doi: 10.1016/j.jpeds.2004.08.004. PMID: CN-00503886. Exclusion Code: X2.15580192
235 Kelly L, Holmberg PM, Schroeder ET, . Effect of home-based strength training program on IGF-I, IGFBP-1 and IGFBP-3 in obese Latino boys participating in a 16-week randomized controlled trial. J Pediatr Endocrinol Metab. 2019;32(10):1121–9. doi: 10.1515/jpem-2019-0073. PMID: CN-01997339. Exclusion Code: X2.31539362
236 Kelly LA, Loza A, Lin X, . The effect of a home-based strength training program on type 2 diabetes risk in obese Latino boys. J Pediatr Endocrinol Metab. 2015;28(3–4):315–22. doi: 10.1515/jpem-2014-0470. PMID: CN-01256726. Exclusion Code: X2.25781537
237 Kendall D, Vail A, Amin R, . Metformin in obese children and adolescents: the MOCA trial. J Clin Endocrinol Metab. 2013 Jan;98(1):322–9. doi: 10.1210/jc.2012-2710. PMID: 23175691. Exclusion Code: X6.23175691
238 Kim HS, Yoo YS, Shim HS. Effects of an Internet-based intervention on plasma glucose levels in patients with type 2 diabetes. J Nurs Care Qual. 2005 Oct–Dec;20(4):335–40. doi: 10.1097/00001786-200510000-00009. PMID: 16177585. Exclusion Code: X2.16177585
239 Kim JS, Lê KA, Mahurkar S, . Influence of elevated liver fat on circulating adipocytokines and insulin resistance in obese Hispanic adolescents. Pediatr Obes. 2012;7(2):158–64. doi: 10.1111/j.2047-6310.2011.00014.x. PMID: CN-00872236. Exclusion Code: X5.22434756
240 Kim JY, Bacha F, Tfayli H, . Adipose tissue insulin resistance in youth on the spectrum from normal weight to obese and from normal glucose tolerance to impaired glucose tolerance to type 2 diabetes. Diabetes Care. 2019 Feb;42(2):265–72. doi: 10.2337/dc18-1178. PMID: 30455334. Exclusion Code: X4.30455334
241 Kim MS, Jo DS, Lee DY. Comparison of HbA1c and OGTT for the diagnosis of type 2 diabetes in children at risk of diabetes. Pediatr Neonatol. 2019 Aug;60(4):428–34. doi: 10.1016/j.pedneo.2018.11.002. PMID: 30497969. Exclusion Code: X8.30497969
242 Klein DJ, Aronson Friedman L, Harlan WR, . Obesity and the development of insulin resistance and impaired fasting glucose in black and white adolescent girls: a longitudinal study. Diabetes Care. 2004 Feb;27(2):378–83. doi: 10.2337/diacare.27.2.378. PMID: 14747217. Exclusion Code: X3.14747217
243 Klein DJ, Battelino T, Chatterjee DJ, . Liraglutide’s safety, tolerability, pharmacokinetics, and pharmacodynamics in pediatric type 2 diabetes: a randomized, double-blind, placebo-controlled trial. Diabetes Technol Ther. 2014 Oct;16(10):679–87. doi: 10.1089/dia.2013.0366. PMID: 25036533. Exclusion Code: X2.25036533
244 Klein S, Ghosh A, Cremieux PY, . Economic impact of the clinical benefits of bariatric surgery in diabetes patients with BMI ≥35 kg/m². Obesity (Silver Spring). 2011 Mar;19(3):581–7. doi: 10.1038/oby.2010.199. PMID: 20829800. Exclusion Code: X2.20829800
245 Kloppenborg JT, Gamborg M, Fonvig CE, . The effect of impaired glucose metabolism on weight loss in multidisciplinary childhood obesity treatment. Pediatr Diabetes. 2018 May;19(3):366–74. doi: 10.1111/pedi.12605. PMID: 29159854. Exclusion Code: X5.29159854
246 Kobayashi K, Amemiya S, Higashida K, . Pathogenic factors of glucose intolerance in obese Japanese adolescents with type 2 diabetes. Metabolism. 2000 Feb;49(2):186–91. doi: 10.1016/s0026-0495(00)91221-6. PMID: 10690942. Exclusion Code: X4.10690942
247 Kolterman OG, Kim DD, Shen L, . Pharmacokinetics, pharmacodynamics, and safety of exenatide in patients with type 2 diabetes mellitus. Am J Health Syst Pharm. 2005 Jan 15;62(2):173–81. doi: 10.1093/ajhp/62.2.173. PMID: 15700891. Exclusion Code: X2.15700891
248 Komamine M, Kajiyama K, Ishiguro C, . Cardiovascular risks associated with dipeptidyl peptidase-4 inhibitors monotherapy compared with other antidiabetes drugs in the Japanese population: a nationwide cohort study. Pharmacoepidemiol Drug Saf. 2019 Sep;28(9):1166–74. doi: 10.1002/pds.4847. PMID: 31338935. Exclusion Code: X5.31338935
249 Koro CE, Sowell MO, Stender M, . The risk of myopathy associated with thiazolidinediones and statins in patients with type 2 diabetes: a nested case-control analysis. Clin Ther. 2008 Mar;30(3):535–42. doi: 10.1016/j.clinthera.2008.02.008. PMID: 18405791. Exclusion Code: X2.18405791
250 Kothny W, Foley J, Kozlovski P, . Improved glycaemic control with vildagliptin added to insulin, with or without metformin, in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2013 Mar;15(3):252–7. doi: 10.1111/dom.12020. PMID: 23039321. Exclusion Code: X2.23039321
251 Krall J, Gabbay R, Zickmund S, . Current perspectives on psychological insulin resistance: primary care provider and patient views. Diabetes Technol Ther. 2015 Apr;17(4):268–74. doi: 10.1089/dia.2014.0268. PMID: 25551737. Exclusion Code: X2.25551737
252 Kriska A, Delahanty L, Edelstein S, . Sedentary behavior and physical activity in youth with recent onset of type 2 diabetes. Pediatrics. 2013 Mar;131(3):e850–6. doi: 10.1542/peds.2012-0620. PMID: 23400602. Exclusion Code: X5.23400602
253 Kriska A, El Ghormli L, Copeland KC, . Impact of lifestyle behavior change on glycemic control in youth with type 2 diabetes. Pediatr Diabetes. 2018 Feb;19(1):36–44. doi: 10.1111/pedi.12526. PMID: 28378429. Exclusion Code: X6.28378429
254 Krysiak R, Okopien B. The effect of metformin on monocyte secretory function in simvastatin-treated patients with impaired fasting glucose. Metabolism. 2013 Jan;62(1):39–43. doi: 10.1016/j.metabol.2012.06.009. PMID: 22841520. Exclusion Code: X2.22841520
255 Kuk JL, Lee S. Assessing the utility of cardiorespiratory fitness, visceral fat and liver fat in predicting changes in insulin sensitivity beyond simple changes in body weight after exercise training in adolescents. Appl Physiol Nutr Metab. 2020 Jul 16doi: 10.1139/apnm-2020-0284. PMID: 32674604. Exclusion Code: X2.32674604
256 Kumar VS, Wentzell KJ, Mikkelsen T, . The DAILY (Daily Automated Intensive Log for Youth) trial: a wireless, portable system to improve adherence and glycemic control in youth with diabetes. Diabetes Technol Ther. 2004 Aug;6(4):445–53. doi: 10.1089/1520915041705893. PMID: 15320998. Exclusion Code: X2.15320998
257 Kwak JH, Lee JH, Ahn CW, . Black soy peptide supplementation improves glucose control in subjects with prediabetes and newly diagnosed type 2 diabetes mellitus. J Med Food. 2010;13(6):1307–12. doi: 10.1089/jmf.2010.1075. PMID: CN-00779772. Exclusion Code: X2.21091245
258 Laffel L, Chang N, Grey M, . Metformin monotherapy in youth with recent onset type 2 diabetes: experience from the prerandomization run-in phase of the TODAY study. Pediatr Diabetes. 2012 Aug;13(5):369–75. doi: 10.1111/j.1399-5448.2011.00846.x. PMID: 22369102. Exclusion Code: X5.22369102
259 Laffel LMB, Tamborlane WV, Yver A, . Pharmacokinetic and pharmacodynamic profile of the sodium-glucose co-transporter-2 inhibitor empagliflozin in young people with Type 2 diabetes: a randomized trial. Diabet Med. 2018 Aug;35(8):1096–104. doi: 10.1111/dme.13629. PMID: 29655290. Exclusion Code: X5.29655290
260 Lankisch MR, Ferlinz KC, Leahy JL, . Introducing a simplified approach to insulin therapy in type 2 diabetes: a comparison of two single-dose regimens of insulin glulisine plus insulin glargine and oral antidiabetic drugs. Diabetes Obes Metab. 2008;10(12):1178–85. doi: 10.1111/j.1463-1326.2008.00967.x. PMID: CN-00700127. Exclusion Code: X2.19040645
261 Lawson C, Ahmed SN, Brady C, . A clinic-based approach to diagnosis and management of prediabetes in high-risk children and adolescents. J Endocr Soc. 2020 Apr 1;4(4):bvaa008. doi: 10.1210/jendso/bvaa008. PMID: 32215353. Exclusion Code: X8.32215353
262 Le PT, Huisingh CE, Ashraf AP. Glycemic control and diabetic dyslipidemia in adolescents with type 2 diabetes. Endocr Pract. 2013 Nov–Dec;19(6):972–9. doi: 10.4158/ep13016.or. PMID: 23807519. Exclusion Code: X6.23807519
263 Lee HS, Park HK, Hwang JS. HbA1c and glucose intolerance in obese children and adolescents. Diabet Med. 2012 Jul;29(7):e102–5. doi: 10.1111/j.1464-5491.2012.03596.x. PMID: 22273110. Exclusion Code: X8.22273110
264 Lee JM, Eason A, Nelson C, . Screening practices for identifying type 2 diabetes in adolescents. J Adolesc Health. 2014 Feb;54(2):139–43. doi: 10.1016/j.jadohealth.2013.07.003. PMID: 23968881. Exclusion Code: X8.23968881
265 Lee KT, Yeh YH, Chang SH, . Metformin is associated with fewer major adverse cardiac events among patients with a new diagnosis of type 2 diabetes mellitus: A propensity score-matched nationwide study. Medicine (Baltimore). 2017 Jul;96(28):e7507. doi: 10.1097/md.0000000000007507. PMID: 28700501. Exclusion Code: X2.28700501
266 Lee S, Deldin AR, White D, . Aerobic exercise but not resistance exercise reduces intrahepatic lipid content and visceral fat and improves insulin sensitivity in obese adolescent girls: a randomized controlled trial. Am J Physiol Endocrinol Metab. 2013;305(10):E1222–9. doi: 10.1152/ajpendo.00285.2013. PMID: CN-01015548. Exclusion Code: X2.24045865
267 Lee S, Libman I, Hughan K, . Effects of exercise modality on insulin resistance and ectopic fat in adolescents with overweight and obesity: a randomized clinical trial. J Pediatr. 2019 Mar;206:91–8.e1. doi: 10.1016/j.jpeds.2018.10.059. PMID: 30554789. Exclusion Code: X5.30554789
268 Lennerz BS, Moss A, von Schnurbein J, . Do adolescents with extreme obesity differ according to previous treatment seeking behavior? The Youth with Extreme obesity Study (YES) cohort. Int J Obes (Lond). 2019 Jan;43(1):103–15. doi: 10.1038/s41366-018-0237-4. PMID: 30368525. Exclusion Code: X8.30368525
269 Lentferink YE, van der Aa MP, van Mill E, . Long-term metformin treatment in adolescents with obesity and insulin resistance, results of an open label extension study. Nutrition and Diabetes. 2018;8(1):47. doi: 10.1038/s41387-018-0057-6. PMID: CN-01644417. Exclusion Code: X2.30197416
270 Levitt Katz LE, Bacha F, Gidding SS, . Lipid profiles, inflammatory markers, and insulin therapy in youth with type 2 diabetes. J Pediatr. 2018;196:208–16.e2. doi: 10.1016/j.jpeds.2017.12.052. PMID: CN-01708409. Exclusion Code: X5.29398050
271 Li FF, Jiang LL, Yan RN, . Effects of saxagliptin add-on therapy to insulin on blood glycemic fluctuations in patients with type 2 diabetes: a randomized, control, open-labeled trial. Medicine (Baltimore). 2016 Oct;95(43):e5229. doi: 10.1097/md.0000000000005229. PMID: 27787387. Exclusion Code: X2.27787387
272 Li G, Han L, Wang Y, . Evaluation of ADA HbA1c criteria in the diagnosis of pre-diabetes and diabetes in a population of Chinese adolescents and young adults at high risk for diabetes: a cross-sectional study. BMJ Open. 2018 Aug 8;8(8):e020665. doi: 10.1136/bmjopen-2017-020665. PMID: 30093511. Exclusion Code: X8.30093511
273 Li J, Bergmann A, Reimann M, . A more simplified Finnish diabetes risk score for opportunistic screening of undiagnosed type 2 diabetes in a German population with a family history of the metabolic syndrome. Horm Metab Res. 2009 Feb;41(2):98–103. doi: 10.1055/s-0028-1087191. PMID: 18975253. Exclusion Code: X6.18975253
274 Li R, Wang G. To evaluate the efficacy of GLP-1 analogues on the blood sugar levels, insulin resistance, islet β-cell function and pre-diabetes of the children. Biomedical Research (India). 2017;28(10):4460–5. PMID: CN-01769274. Exclusion Code: X6.
275 Li W, Li M, Kong D. Clinical efficacy of metformin combined with lifestyle intervention for treatment of childhood obesity with hyperinsulinemia. Int J Clin Exp Med. 2019;12(6):7644–50. PMID: CN-01980780. Exclusion Code: X6.
276 Li X, Bao C, Zhao Y, . Statistical analysis on threshold of haemoglobin A1C (HBA1c) for diabetes diagnosis and the relationship between HBA1c and plasma glucose concentrations in Chinese diabetic high-risk groups. Clin Lab. 2019 Mar 1;65(3)doi: 10.7754/Clin.Lab.2018.180711. PMID: 30868839. Exclusion Code: X2.30868839
277 Li X, Ting TH, Sheng H, . Genetic and clinical characteristics of Chinese children with Glucokinase-maturity-onset diabetes of the young (GCK-MODY). BMC Pediatr. 2018 Mar 6;18(1):101. doi: 10.1186/s12887-018-1060-8. PMID: 29510678. Exclusion Code: X6.29510678
278 Li Y, Feng D, Esangbedo IC, . Insulin resistance, beta-cell function, adipokine profiles and cardiometabolic risk factors among Chinese youth with isolated impaired fasting glucose versus impaired glucose tolerance: the BCAMS study. BMJ Open Diabetes Res Care. 2020 Feb;8(1)doi: 10.1136/bmjdrc-2019-000724. PMID: 32049638. Exclusion Code: X8.32049638
279 Liang J, Fu J, Jiang Y, . TriGlycerides and high-density lipoprotein cholesterol ratio compared with homeostasis model assessment insulin resistance indexes in screening for metabolic syndrome in the chinese obese children: a cross section study. BMC Pediatr. 2015 Sep 28;15:138. doi: 10.1186/s12887-015-0456-y. PMID: 26416207. Exclusion Code: X8.26416207
280 Liao ZH, Chen YL, Li FP, . Multicenter clinical study on the efficacy and safety of inhalable insulin aerosol in the treatment of type 2 diabetes. Chin Med J. 2008;121(13):1159–64. PMID: CN-00650556. Exclusion Code: X2.18710631
281 Liese AD, Bortsov A, Günther AL, . Association of DASH diet with cardiovascular risk factors in youth with diabetes mellitus: the SEARCH for Diabetes in Youth study. Circulation. 2011 Apr 5;123(13):1410–7. doi: 10.1161/circulationaha.110.955922. PMID: 21422385. Exclusion Code: X4.21422385
282 Lindquist CH, Gower BA, Goran MI. Role of dietary factors in ethnic differences in early risk of cardiovascular disease and type 2 diabetes. Am J Clin Nutr. 2000 Mar;71(3):725–32. doi: 10.1093/ajcn/71.3.725. PMID: 10702165. Exclusion Code: X8.10702165
283 List JF, Woo V, Morales E, . Sodium-glucose cotransport inhibition with dapagliflozin in type 2 diabetes. Diabetes Care. 2009 Apr;32(4):650–7. doi: 10.2337/dc08-1863. PMID: 19114612. Exclusion Code: X2.19114612
284 Lochrie AS, Wysocki T, Buckloh LM, . Effects of a family based intervention study for overweight children: 6 month medical outcome data. Diabetes. 2010 PMID: CN-01009176. Exclusion Code: X2.
285 LoRe D, Leung CYY, Brenner L, . Parent-directed intervention in promoting knowledge of pediatric nutrition and healthy lifestyle among low-SES families with toddlers: a randomized controlled trial. Child. 2019;45(4):518–22. doi: 10.1111/cch.12682. PMID: CN-02116872. Exclusion Code: X6.
286 Love-Osborne K, Sheeder J, Zeitler P. Addition of metformin to a lifestyle modification program in adolescents with insulin resistance. J Pediatr. 2008 Jun;152(6):817–22. doi: 10.1016/j.jpeds.2008.01.018. PMID: 18492523. Exclusion Code: X2.18492523
287 Low JC, Felner EI, Muir AB, . Do obese children with diabetic ketoacidosis have type 1 or type 2 diabetes? Prim Care Diabetes. 2012 Apr;6(1):61–5. doi: 10.1016/j.pcd.2011.11.001. PMID: 22230097. Exclusion Code: X5.22230097
288 Lown EA, Lui CK, Karriker-Jaffe K, . Adverse childhood events and risk of diabetes onset in the 1979 National longitudinal survey of youth cohort. BMC Public Health. 2019 Jul 27;19(1):1007. doi: 10.1186/s12889-019-7337-5. PMID: 31351463. Exclusion Code: X8.31351463
289 Lukashevich V, Del Prato S, Araga M, . Efficacy and safety of vildagliptin in patients with type 2 diabetes mellitus inadequately controlled with dual combination of metformin and sulphonylurea. Diabetes Obes Metab. 2014 May;16(5):403–9. doi: 10.1111/dom.12229. PMID: 24199686. Exclusion Code: X2.24199686
290 Luu KT, Morgan ES, Bhanot S, . Population pharmacokinetics and pharmacodynamics of IONIS-GCGRRx, an antisense oligonucleotide for type 2 diabetes mellitus: a red blood cell lifespan model. J Pharmacokinet Pharmacodyn. 2017;44(3):179–91. doi: 10.1007/s10928-017-9505-5. PMID: CN-01454871. Exclusion Code: X2.28132162
291 Maclean JR, Chapman RH, Ferrufino CP, . Drug titration patterns and HbA 1c levels in type 2 diabetes. Int J Clin Pract. 2009 Jul;63(7):1008–16. doi: 10.1111/j.1742-1241.2009.02094.x. PMID: 19570118. Exclusion Code: X2.19570118
292 Mader JK, Jensen L, Ingwersen SH, . Pharmacokinetic properties of liraglutide as adjunct to insulin in subjects with type 1 diabetes mellitus. Clin Pharmacokinet. 2016 Nov;55(11):1457–63. doi: 10.1007/s40262-016-0413-4. PMID: 27282158. Exclusion Code: X2.27282158
293 Magkos F, Nikonova E, Fain R, . Effect of lorcaserin on glycemic parameters in patients with type 2 diabetes mellitus. Obesity (Silver Spring, Md.). 2017;25(5):842–9. doi: 10.1002/oby.21798. PMID: CN-01426236. Exclusion Code: X2.
294 Maki KC, Rains TM, Dicklin MR, . Repeatability of indices of insulin sensitivity and secretion from standard liquid meal tests in subjects with type 2 diabetes mellitus or normal or impaired fasting glucose. Diabetes Technol Ther. 2010;12(11):895–900. doi: 10.1089/dia.2010.0083. PMID: CN-00772753. Exclusion Code: X2.20879960
295 Maldonado-Hernández J, Martínez-Basila A, Salas-Fernández A, . The 13C-glucose breath test for insulin resistance assessment in adolescents: comparison with fasting and post-glucose stimulus surrogate markers of insulin resistance. J Clin Res Pediatr Endocrinol. 2016 Dec 1;8(4):419–24. doi: 10.4274/jcrpe.3260. PMID: 27354200. Exclusion Code: X8.27354200
296 Maleki F, Hosseini Nodeh Z, Rahnavard Z, . Effectiveness of training on preventative nutritional behaviors for type-2 diabetes among the female adolescents: Examination of theory of planned behavior. Med J Islam Repub Iran. 2016;30:349. PMID: 27390718. Exclusion Code: X2.27390718
297 Malloy J, Capparelli E, Gottschalk M, . Pharmacology and tolerability of a single dose of exenatide in adolescent patients with type 2 diabetes mellitus being treated with metformin: a randomized, placebo-controlled, single-blind, dose-escalation, crossover study. Clin Ther. 2009 Apr;31(4):806–15. doi: 10.1016/j.clinthera.2009.04.005. PMID: 19446153. Exclusion Code: X2.19446153
298 Mancioppi V, Solito A, Ricotti R, . Good-day: efficacy of gamification of an educational training to mediterranean diet on weight and metabolic control in paediatric obesity. preliminary data at 6 months. High Blood Press Cardiovasc Prev. 2019;26(2):171–2. doi: 10.1007/s40292-019-00308-6. PMID: CN-01976011. Exclusion Code: X6.
299 Manco M, Grugni G, Di Pietro M, . Triglycerides-to-HDL cholesterol ratio as screening tool for impaired glucose tolerance in obese children and adolescents. Acta Diabetol. 2016 Jun;53(3):493–8. doi: 10.1007/s00592-015-0824-y. PMID: 26687197. Exclusion Code: X8.26687197
300 Manios Y, Mavrogianni C, Lambrinou CP, . Two-stage, school and community-based population screening successfully identifies individuals and families at high-risk for type 2 diabetes: the Feel4Diabetes-study. BMC Endocr Disord. 2020 Mar 12;20(Suppl 1):12. doi: 10.1186/s12902-019-0478-9. PMID: 32164646. Exclusion Code: X8.32164646
301 Manning RM, Jung RT, Leese GP, . The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabet Med. 1995 May;12(5):409–15. doi: 10.1111/j.1464-5491.1995.tb00504.x. PMID: 7648803. Exclusion Code: X2.7648803
302 Mansour AA, Wanoose HL, Hani I, . Diabetes screening in Basrah, Iraq: a population-based cross-sectional study. Diabetes Res Clin Pract. 2008 Jan;79(1):147–50. doi: 10.1016/j.diabres.2007.07.016. PMID: 17767973. Exclusion Code: X2.17767973
303 Marcus MD, Wilfley DE, El Ghormli L, . Weight change in the management of youth-onset type 2 diabetes: the TODAY clinical trial experience. Pediatr Obes. 2017 Aug;12(4):337–45. doi: 10.1111/ijpo.12148. PMID: 27161901. Exclusion Code: X6.27161901
304 Marley JV, Oh MS, Hadgraft NT, . Using glycated haemoglobin testing to simplify diabetes screening in remote Aboriginal Australian health care settings. Med J Aust. 2015 Jul 6;203(1):28–32. doi: 10.5694/mja14.01575. PMID: 26126564. Exclusion Code: X8.26126564
305 Matsuura N, Amemiya S, Sugihara S, . Metformin monotherapy in children and adolescents with type 2 diabetes mellitus in Japan. Diabetol Int. 2019 Jan;10(1):51–7. doi: 10.1007/s13340-018-0361-3. PMID: 30800563. Exclusion Code: X5.30800563
306 Matthews DR, Wallace TM. Children with type 2 diabetes: the risks of complications. Horm Res. 2002;57 Suppl 1:34–9. doi: 10.1159/000053310. PMID: 11979020. Exclusion Code: X8.11979020
307 Matthews JE, Stewart MW, De Boever EH, . Pharmacodynamics, pharmacokinetics, safety, and tolerability of albiglutide, a long-acting glucagon-like peptide-1 mimetic, in patients with type 2 diabetes. J Clin Endocrinol Metab. 2008 Dec;93(12):4810–7. doi: 10.1210/jc.2008-1518. PMID: 18812476. Exclusion Code: X2.18812476
308 Mauras N, DelGiorno C, Hossain J, . Metformin use in children with obesity and normal glucose tolerance--effects on cardiovascular markers and intrahepatic fat. J Pediatr Endocrinol Metab. 2012;25(1–2):33–40. doi: 10.1515/jpem-2011-0450. PMID: 22570948. Exclusion Code: X2.22570948
309 Mayengbam S, Virtanen H, Hittel DS, . Artificially sweetened vitamin drink consumption reduces insulin sensitivity and alters one-carbon, b-vitamin dependent metabolism in adolescents. FASEB J. 2018;32(1)PMID: CN-01613734. Exclusion Code: X2.
310 Mayer-Davis EJ, Nichols M, Liese AD, . Dietary intake among youth with diabetes: the SEARCH for Diabetes in Youth Study. J Am Diet Assoc. 2006 May;106(5):689–97. doi: 10.1016/j.jada.2006.02.002. PMID: 16647326. Exclusion Code: X8.16647326
311 McCormack SE, McCarthy MA, Harrington SG, . Effects of exercise and lifestyle modification on fitness, insulin resistance, skeletal muscle oxidative phosphorylation and intramyocellular lipid content in obese children and adolescents. Pediatr Obes. 2014 Aug;9(4):281–91. doi: 10.1111/j.2047-6310.2013.00180.x. PMID: 23801526. Exclusion Code: X2.23801526
312 McGavock J, Dart A, Wicklow B. Lifestyle therapy for the treatment of youth with type 2 diabetes. Curr Diab Rep. 2015 Jan;15(1):568. doi: 10.1007/s11892-014-0568-z. PMID: 25398207. Exclusion Code: X8.25398207
313 McGavock J, Hay J, Wittmeier K, . Physical activity intensity and type 2 diabetes risk in overweight youth: the power trial, a randomized, controlled trial. Diabetes. 2014;63:A317-. doi: 10.2337/db14-833-1316. PMID: CN-01009458. Exclusion Code: X6.
314 McGill JB, Sloan L, Newman J, . Long-term efficacy and safety of linagliptin in patients with type 2 diabetes and severe renal impairment: a 1-year, randomized, double-blind, placebo-controlled study. Diabetes Care. 2013 Feb;36(2):237–44. doi: 10.2337/dc12-0706. PMID: 23033241. Exclusion Code: X2.23033241
315 McLaughlin T, Schweitzer P, Carter S, . Persistence of improvement in insulin sensitivity following a dietary weight loss programme. Diabetes Obes Metab. 2008 Dec;10(12):1186–94. doi: 10.1111/j.1463-1326.2008.00877.x. PMID: 18476986. Exclusion Code: X2.18476986
316 Meulepas MA, Braspenning JC, de Grauw WJ, . Patient-oriented intervention in addition to centrally organised checkups improves diabetic patient outcome in primary care. Qual Saf Health Care. 2008;17(5):324–8. doi: 10.1136/qshc.2006.021204. PMID: CN-00687097. Exclusion Code: X2.18842969
317 Mijailović V, Micić D, Mijailović M. Effects of a one-year weight reduction program and physical activity on obesity and comorbid conditions. Med Pregl. 2004;57(1–2):55–9. doi: 10.2298/mpns0402055m. PMID: CN-00520769. Exclusion Code: X1.15327191
318 Ming-Qiang Z, Yang-Li D, Ke H, . Maturity onset diabetes of the young (MODY) in Chinese children: genes and clinical phenotypes. J Pediatr Endocrinol Metab. 2019 Jul 26;32(7):759–65. doi: 10.1515/jpem-2018-0446. PMID: 31216263. Exclusion Code: X3.31216263
319 Mollaoğlu M, Beyazit E. Influence of diabetic education on patient metabolic control. Appl Nurs Res. 2009 Aug;22(3):183–90. doi: 10.1016/j.apnr.2007.12.003. PMID: 19616166. Exclusion Code: X2.19616166
320 Morrison JA, Glueck CJ, Daniels S, . Determinants of persistent obesity and hyperinsulinemia in a biracial cohort: a 15-year prospective study of schoolgirls. J Pediatr. 2010 Oct;157(4):559–65. doi: 10.1016/j.jpeds.2010.04.030. PMID: 20553845. Exclusion Code: X4.20553845
321 Morrison KM, Xu L, Tarnopolsky M, . Screening for dysglycemia in overweight youth presenting for weight management. Diabetes Care. 2012 Apr;35(4):711–6. doi: 10.2337/dc11-1659. PMID: 22271926. Exclusion Code: X8.22271926
322 Muzaffar H, Castelli DM, Scherer J, . The impact of web-based HOT (Healthy Outcomes for Teens) Project on risk for type 2 diabetes: a randomized controlled trial. Diabetes Technol Ther. 2014 Dec;16(12):846–52. doi: 10.1089/dia.2014.0073. PMID: 25127372. Exclusion Code: X6.25127372
323 Na LX, Li Y, Pan HZ, . Curcuminoids exert glucose-lowering effect in type 2 diabetes by decreasing serum free fatty acids: a double-blind, placebo-controlled trial. Mol Nutr Food Res. 2013;57(9):1569–77. doi: 10.1002/mnfr.201200131. PMID: CN-00987896. Exclusion Code: X2.22930403
324 Naik H, Vakilynejad M, Wu J, . Safety, tolerability, pharmacokinetics, and pharmacodynamic properties of the GPR40 agonist TAK-875: results from a double-blind, placebo-controlled single oral dose rising study in healthy volunteers. J Clin Pharmacol. 2012;52(7):1007–16. doi: 10.1177/0091270011409230. PMID: CN-00972576. Exclusion Code: X2.21610201
325 Najafipour H, Sanjari M, Shokoohi M, . Epidemiology of diabetes mellitus, pre-diabetes, undiagnosed and uncontrolled diabetes and its predictors in general population aged 15 to 75 years: a community-based study (KERCADRS) in southeastern Iran. J Diabetes. 2015 Sep;7(5):613–21. doi: 10.1111/1753-0407.12195. PMID: 25042896. Exclusion Code: X2.25042896
326 Naughton MJ, Yi-Frazier JP, Morgan TM, . Longitudinal associations between sex, diabetes self-care, and health-related quality of life among youth with type 1 or type 2 diabetes mellitus. J Pediatr. 2014 Jun;164(6):1376–83.e1. doi: 10.1016/j.jpeds.2014.01.027. PMID: 24582483. Exclusion Code: X2.24582483
327 Naylor LH, Davis EA, Kalic RJ, . Exercise training improves vascular function in adolescents with type 2 diabetes. Physiological reports. 2016;4(4)doi: 10.14814/phy2.12713. PMID: CN-01179606. Exclusion Code: X6.
328 Nelson P, Poon T, Guan X, . The incretin mimetic exenatide as a monotherapy in patients with type 2 diabetes. Diabetes Technol Ther. 2007 Aug;9(4):317–26. doi: 10.1089/dia.2006.0024. PMID: 17705687. Exclusion Code: X2.17705687
329 Newfield RS, Dewan AK, Jain S. Dyslipidemia in children with type 2 diabetes vs. obesity. Pediatr Diabetes. 2008 Apr;9(2):115–21. doi: 10.1111/j.1399-5448.2007.00345.x. PMID: 18221437. Exclusion Code: X8.18221437
330 Newsome P, Francque S, Harrison S, . Effect of semaglutide on liver enzymes and markers of inflammation in subjects with type 2 diabetes and/or obesity. Aliment Pharmacol Ther. 2019 Jul;50(2):193–203. doi: 10.1111/apt.15316. PMID: 31246368. Exclusion Code: X2.31246368
331 Ngaosuwan K, Osataphan S. Diabetes mellitus treated with medical nutritional therapy and self blood glucose monitoring: a randomized controlled trial. Chotmaihet Thangphaet [Journal of the Medical Association of Thailand]. 2015;98 Suppl 10:S66–73. PMID: CN-01165933. Exclusion Code: X2.
332 Ning G, Wang W, Li L, . Vildagliptin as add-on therapy to insulin improves glycemic control without increasing risk of hypoglycemia in Asian, predominantly Chinese, patients with type 2 diabetes mellitus. J Diabetes. 2016 May;8(3):345–53. doi: 10.1111/1753-0407.12303. PMID: 25929739. Exclusion Code: X2.25929739
333 Nip ASY, Reboussin BA, Dabelea D, . Disordered eating behaviors in youth and young adults with type 1 or type 2 diabetes receiving insulin therapy: the SEARCH for Diabetes in Youth Study. Diabetes Care. 2019 May;42(5):859–66. doi: 10.2337/dc18-2420. PMID: 30862656. Exclusion Code: X8.30862656
334 Noe A, Howard C, Thuren T, . Pharmacokinetic and pharmacodynamic characteristics of single-dose Canakinumab in patients with type 2 diabetes mellitus. Clin Ther. 2014 Nov 1;36(11):1625–37. doi: 10.1016/j.clinthera.2014.08.004. PMID: 25240532. Exclusion Code: X2.25240532
335 Nsiah-Kumi PA, Lasley S, Whiting M, . Diabetes, pre-diabetes and insulin resistance screening in Native American children and youth. Int J Obes (Lond). 2013 Apr;37(4):540–5. doi: 10.1038/ijo.2012.199. PMID: 23229738. Exclusion Code: X8.23229738
336 Numbenjapon N, Nakavachara P, Santiprabhob J, . Successful strategy to improve glucose tolerance in Thai obese youth. J Med Assoc Thai. 2010 Nov;93 Suppl 6:S131–8. PMID: 21280526. Exclusion Code: X5.21280526
337 Nupponen M, Pahkala K, Juonala M, . Metabolic syndrome from adolescence to early adulthood: effect of infancy-onset dietary counseling of low saturated fat: the Special Turku Coronary Risk Factor Intervention Project (STRIP). Circulation. 2015 Feb 17;131(7):605–13. doi: 10.1161/circulationaha.114.010532. PMID: 25605660. Exclusion Code: X2.25605660
338 Odnoletkova I, Goderis G, Nobels F, . Optimizing diabetes control in people with Type 2 diabetes through nurse-led telecoaching. Diabet Med. 2016 Jun;33(6):777–85. doi: 10.1111/dme.13092. PMID: 26872105. Exclusion Code: X2.26872105
339 Olson BP, Matter NI, Ediger MN, . Noninvasive skin fluorescence spectroscopy is comparable to hemoglobin A1c and fasting plasma glucose for detection of abnormal glucose tolerance. J Diabetes Sci Technol. 2013 Jul 1;7(4):990–1000. doi: 10.1177/193229681300700422. PMID: 23911181. Exclusion Code: X2.23911181
340 O’Malley G, Santoro N, Northrup V, . High normal fasting glucose level in obese youth: a marker for insulin resistance and beta cell dysregulation. Diabetologia. 2010 Jun;53(6):1199–209. doi: 10.1007/s00125-010-1693-0. PMID: 20204321. Exclusion Code: X8.20204321
341 Osman A, Osman NR, Fouad DA, . Vitamin D deficiency in obese children and adolescents and relation to glucose homeostasis. QJM : monthly journal of the Association of Physicians. 2018;111:i59-. doi: 10.1093/qjmed/hcy200. PMID: CN-02094737. Exclusion Code: X8.
342 Pan C, Xing X, Han P, . Efficacy and tolerability of vildagliptin as add-on therapy to metformin in Chinese patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2012 Aug;14(8):737–44. doi: 10.1111/j.1463-1326.2012.01593.x. PMID: 22369287. Exclusion Code: X2.22369287
343 Paprott R, Scheidt-Nave C, Heidemann C. Determinants of change in glycemic status in individuals with prediabetes: results from a nationwide cohort study in Germany. J Diabetes Res. 2018;2018:5703652. doi: 10.1155/2018/5703652. PMID: 30406150. Exclusion Code: X8.30406150
344 Park CY, Kang JG, Chon S, . Comparison between the therapeutic effect of metformin, glimepiride and their combination as an add-on treatment to insulin glargine in uncontrolled patients with type 2 diabetes. PLoS One. 2014;9(3):e87799. doi: 10.1371/journal.pone.0087799. PMID: 24614911. Exclusion Code: X2.24614911
345 Park SH, Jung MH, Cho WK, . Incretin secretion in obese Korean children and adolescents with newly diagnosed type 2 diabetes. Clin Endocrinol (Oxf). 2016 Jan;84(1):72–9. doi: 10.1111/cen.12802. PMID: 25903996. Exclusion Code: X6.25903996
346 Parkinson J, Tang W, Johansson CC, . Comparison of the exposure-response relationship of dapagliflozin in adult and paediatric patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2016;18(7):685–92. doi: 10.1111/dom.12647. PMID: CN-01425024. Exclusion Code: X6.27299483
347 Pastor-Villaescusa B, Canete MD, Caballero-Villarraso J, . Metformin for obesity in prepubertal and pubertal children: a randomized controlled trial. Pediatrics. 2017 Jul;140(1)doi: 10.1542/peds.2016-4285. PMID: 28759403. Exclusion Code: X2.28759403
348 Patrick K, Norman GJ, Davila EP, . Outcomes of a 12-month technology-based intervention to promote weight loss in adolescents at risk for type 2 diabetes. J Diabetes Sci Technol. 2013 May 1;7(3):759–70. doi: 10.1177/193229681300700322. PMID: 23759410. Exclusion Code: X2.23759410
349 Pearson S, Broløs EJ, Herner EB, . Screening Copenhagen school children at risk of type 2 diabetes mellitus using random capillary blood glucose. Acta Paediatr. 2007 Jun;96(6):885–9. doi: 10.1111/j.1651-2227.2007.00305.x. PMID: 17537018. Exclusion Code: X6.17537018
350 Peimani M, Rambod C, Omidvar M, . Effectiveness of short message service-based intervention (SMS) on self-care in type 2 diabetes: a feasibility study. Prim Care Diabetes. 2016 Aug;10(4):251–8. doi: 10.1016/j.pcd.2015.11.001. PMID: 26653014. Exclusion Code: X2.26653014
351 Pena A, Olson ML, Soltero EG, . Evaluating a pragmatic estimate of insulin sensitivity in Latino youth with obesity. Clinical Obesity. 2020;10(2)doi: 10.1111/cob.12353. PMID: CN-02100501. Exclusion Code: X6.
352 Peplies J, Börnhorst C, Günther K, . Longitudinal associations of lifestyle factors and weight status with insulin resistance (HOMA-IR) in preadolescent children: the large prospective cohort study IDEFICS. Int J Behav Nutr Phys Act. 2016 Sep 2;13(1):97. doi: 10.1186/s12966-016-0424-4. PMID: 27590045. Exclusion Code: X4.27590045
353 Petri KC, Jacobsen LV, Klein DJ. Comparable liraglutide pharmacokinetics in pediatric and adult populations with type 2 diabetes: a population pharmacokinetic analysis. Clin Pharmacokinet. 2015 Jun;54(6):663–70. doi: 10.1007/s40262-014-0229-z. PMID: 25603819. Exclusion Code: X8.25603819
354 Petrykiv SI, Laverman GD, de Zeeuw D, . The albuminuria-lowering response to dapagliflozin is variable and reproducible among individual patients. Diabetes Obes Metab. 2017;19(10):1363–70. doi: 10.1111/dom.12936. PMID: CN-01423531. Exclusion Code: X2.28295959
355 Phatale P, Phatale H. Prevalence of pre-diabetes, diabetes, pre-hypertension, and hypertension in children weighing more than normal. Indian J Endocrinol Metab. 2012 Dec;16(Suppl 2):S483–5. doi: 10.4103/2230-8210.104139. PMID: 23565474. Exclusion Code: X5.23565474
356 Pildes RS. Adult-onset diabetes mellitus in childhood. Metabolism. 1973 Feb;22(2):307–15. doi: 10.1016/0026-0495(73)90178-9. PMID: 4687954. Exclusion Code: X5.4687954
357 Pi-Sunyer X, Shanahan W, Fain R, . Impact of lorcaserin on glycemic control in overweight and obese patients with type 2 diabetes: analysis of week 52 responders and nonresponders. Postgrad Med. 2016 Aug;128(6):591–7. doi: 10.1080/00325481.2016.1208618. PMID: 27389084. Exclusion Code: X2.27389084
358 Plavsic L, Knezevic OM, Sovtic A, . Effects of high-intensity interval training and nutrition advice on cardiometabolic markers and aerobic fitness in adolescent girls with obesity. Appl Physiol Nutr Metab. 2020 Mar;45(3):294–300. doi: 10.1139/apnm-2019-0137. PMID: 31386826. Exclusion Code: X2.31386826
359 Pollock N, Gower B, Wenger K, . Effects of aerobic exercise on carboxylated and undercarboxylated forms of osteocalcin and their relationship to exercise-induced changes in insulin sensitivity and visceral and total body fat in overweight children. J Bone Miner Res. 2012;27 PMID: CN-01025454. Exclusion Code: X6.
360 Pozzan R, Brandão AA, da Silva SL, . Hyperglycemia, hyperinsulinemia, overweight, and high blood pressure in young adults: the Rio de Janeiro Study. Hypertension. 1997 Sep;30(3 Pt 2):650–3. doi: 10.1161/01.hyp.30.3.650. PMID: 9322998. Exclusion Code: X2.9322998
361 Proietto J, Malloy J, Zhuang D, . Efficacy and safety of methionine aminopeptidase 2 inhibition in type 2 diabetes: a randomised, placebo-controlled clinical trial. Diabetologia. 2018 Sep;61(9):1918–22. doi: 10.1007/s00125-018-4677-0. PMID: 29992370. Exclusion Code: X2.29992370
362 Pulgarón ER, Hernandez J, Dehaan H, . Clinic attendance and health outcomes of youth with type 2 diabetes mellitus. Int J Adolesc Med Health. 2015 Aug;27(3):271–4. doi: 10.1515/ijamh-2014-0021. PMID: 25153557. Exclusion Code: X8.25153557
363 Quilliam BJ, Ozbay AB, Sill BE, . The association between adherence to oral anti-diabetic drugs and hypoglycaemia in persons with Type 2 diabetes. Diabet Med. 2013 Nov;30(11):1305–13. doi: 10.1111/dme.12217. PMID: 23586474. Exclusion Code: X2.23586474
364 Raben A, Fogelholm M, Larsen TM, . PREVIEW: prevention of diabetes through lifestyle intervention and population studies in Europe and a round the world. Over 2,000 volunteers randomized to the 3-y RCT. Obesity Facts. 2015;8:126. doi: 10.1159/000382140. PMID: CN-01100834. Exclusion Code: X5.
365 Raile K, Schober E, Konrad K, . Treatment of young patients with HNF1A mutations (HNF1A-MODY). Diabet Med. 2015 Apr;32(4):526–30. doi: 10.1111/dme.12662. PMID: 25483937. Exclusion Code: X8.25483937
366 Ramadas A, Quek KF, Chan CK, . Randomised-controlled trial of a web-based dietary intervention for patients with type 2 diabetes mellitus: study protocol of myDIDeA. BMC Public Health. 2011 May 21;11:359. doi: 10.1186/1471-2458-11-359. PMID: 21599990. Exclusion Code: X6.21599990
367 Raman A, Ritchie LD, Lustig RH, . Insulin resistance is improved in overweight African American boys but not in girls following a one-year multidisciplinary community intervention program. J Pediatr Endocrinol Metab. 2010 Jan–Feb;23(1–2):109–20. doi: 10.1515/jpem.2010.23.1-2.109. PMID: 20432814. Exclusion Code: X2.20432814
368 Ramjan KA, Broderick CR, Briody JN, . The effect of whole body vibration training on insulin sensitivity in overweight adolescents: a randomized controlled trial. Endocr Rev. 2011;32(3)PMID: CN-01005815. Exclusion Code: X5.
369 Ranasinghe P, Galappaththy P, Constantine GR, . Cinnamomum zeylanicum (Ceylon cinnamon) as a potential pharmaceutical agent for type-2 diabetes mellitus: study protocol for a randomized controlled trial. Trials. 2017 Sep 29;18(1):446. doi: 10.1186/s13063-017-2192-0. PMID: 28962661. Exclusion Code: X2.28962661
370 Rasli MH, Zacharin MR. Foot problems and effectiveness of foot care education in children and adolescents with diabetes mellitus. Pediatr Diabetes. 2008 Dec;9(6):602–8. doi: 10.1111/j.1399-5448.2008.00432.x. PMID: 18647245. Exclusion Code: X5.18647245
371 Rautio N, Jokelainen J, Oksa H, . Family history of diabetes and effectiveness of lifestyle counselling on the cardio-metabolic risk profile in individuals at high risk of Type 2 diabetes: 1-year follow-up of the FIN-D2D project. Diabet Med. 2012 Feb;29(2):207–11. doi: 10.1111/j.1464-5491.2011.03388.x. PMID: 21781153. Exclusion Code: X2.21781153
372 Rave K, Roggen K, Dellweg S, . Improvement of insulin resistance after diet with a whole-grain based dietary product: results of a randomized, controlled cross-over study in obese subjects with elevated fasting blood glucose. Br J Nutr. 2007;98(5):929–36. doi: 10.1017/S0007114507749267. PMID: CN-00700397. Exclusion Code: X2.17562226
373 Raz I, Fonseca V, Kipnes M, . Efficacy and safety of taspoglutide monotherapy in drug-naive type 2 diabetic patients after 24 weeks of treatment: results of a randomized, double-blind, placebo-controlled phase 3 study (T-emerge 1). Diabetes Care. 2012;35(3):485–7. doi: 10.2337/dc11-1942. PMID: CN-00842751. Exclusion Code: X2.22301126
374 Reinehr T, Andler W, Kapellen T, . Clinical characteristics of type 2 diabetes mellitus in overweight European caucasian adolescents. Exp Clin Endocrinol Diabetes. 2005 Mar;113(3):167–70. doi: 10.1055/s-2005-837522. PMID: 15789276. Exclusion Code: X5.15789276
375 Reinehr T, Elfers C, Lass N, . Irisin and its relation to insulin resistance and puberty in obese children: a longitudinal analysis. J Clin Endocrinol Metab. 2015 May;100(5):2123–30. doi: 10.1210/jc.2015-1208. PMID: 25781361. Exclusion Code: X8.25781361
376 Reinehr T, Kleber M, Toschke AM. Lifestyle intervention in obese children is associated with a decrease of the metabolic syndrome prevalence. Atherosclerosis. 2009 Nov;207(1):174–80. doi: 10.1016/j.atherosclerosis.2009.03.041. PMID: 19442975. Exclusion Code: X2.19442975
377 Reinehr T, Schober E, Roth CL, . Type 2 diabetes in children and adolescents in a 2-year follow-up: insufficient adherence to diabetes centers. Horm Res. 2008;69(2):107–13. doi: 10.1159/000111814. PMID: 18059091. Exclusion Code: X5.18059091
378 Rhee EJ, Lee WY, Min KW, . Efficacy and safety of the dipeptidyl peptidase-4 inhibitor gemigliptin compared with sitagliptin added to ongoing metformin therapy in patients with type 2 diabetes inadequately controlled with metformin alone. Diabetes Obes Metab. 2013 Jun;15(6):523–30. doi: 10.1111/dom.12060. PMID: 23320436. Exclusion Code: X2.23320436
379 Rissanen A, Howard CP, Botha J, . Effect of anti-IL-1β antibody (canakinumab) on insulin secretion rates in impaired glucose tolerance or type 2 diabetes: results of a randomized, placebo-controlled trial. Diabetes Obes Metab. 2012 Dec;14(12):1088–96. doi: 10.1111/j.1463-1326.2012.01637.x. PMID: 22726220. Exclusion Code: X2.22726220
380 Ritchie LD, Sharma S, Ikeda JP, . Taking Action Together: a YMCA-based protocol to prevent type-2 diabetes in high-BMI inner-city African American children. Trials. 2010 May 21;11:60. doi: 10.1186/1745-6215-11-60. PMID: 20492667. Exclusion Code: X6.20492667
381 Roberge JB, Van Hulst A, Barnett TA, . Lifestyle habits, dietary factors, and the metabolically unhealthy obese phenotype in youth. J Pediatr. 2019 Jan;204:46–52.e1. doi: 10.1016/j.jpeds.2018.08.063. PMID: 30366774. Exclusion Code: X2.30366774
382 Rocchini AP, Katch V, Schork A, . Insulin and blood pressure during weight loss in obese adolescents. Hypertension (Dallas, TX: 1979). 1987;10(3):267–73. doi: 10.1161/01.hyp.10.3.267. PMID: CN-00049641. Exclusion Code: X2.
383 Roginsky MS, Barnett J. Double-blind study of phenethyldiguanide in weight control of obese nondiabetic subjects. Am J Clin Nutr. 1966 Oct;19(4):223–6. doi: 10.1093/ajcn/19.4.223. PMID: 5331741. Exclusion Code: X2.5331741
384 Rosenbaum M, Fennoy I, Accacha S, . Racial/ethnic differences in clinical and biochemical type 2 diabetes mellitus risk factors in children. Obesity (Silver Spring). 2013 Oct;21(10):2081–90. doi: 10.1002/oby.20483. PMID: 23596082. Exclusion Code: X4.23596082
385 Rosenbaum M, Nonas C, Weil R, . School-based intervention acutely improves insulin sensitivity and decreases inflammatory markers and body fatness in junior high school students. J Clin Endocrinol Metab. 2007 Feb;92(2):504–8. doi: 10.1210/jc.2006-1516. PMID: 17090635. Exclusion Code: X7.17090635
386 Rosenbloom AL, Bianchi R, Chin FT. Chemical diabetes mellitus in siblings of children with overt diabetes. Isr J Med Sci. 1972 Jun;8(6):841–2. PMID: 4559426. Exclusion Code: X6.4559426
387 Rosenstock J, Aggarwal N, Polidori D, . Dose-ranging effects of canagliflozin, a sodium-glucose cotransporter 2 inhibitor, as add-on to metformin in subjects with type 2 diabetes. Diabetes Care. 2012 Jun;35(6):1232–8. doi: 10.2337/dc11-1926. PMID: 22492586. Exclusion Code: X2.22492586
388 Rosenstock J, Banarer S, Fonseca VA, . The 11-beta-hydroxysteroid dehydrogenase type 1 inhibitor INCB13739 improves hyperglycemia in patients with type 2 diabetes inadequately controlled by metformin monotherapy. Diabetes Care. 2010 Jul;33(7):1516–22. doi: 10.2337/dc09-2315. PMID: 20413513. Exclusion Code: X2.20413513
389 Rosenstock J, Bergenstal R, Defronzo RA, . Efficacy and safety of Technosphere inhaled insulin compared with Technosphere powder placebo in insulin-naive type 2 diabetes suboptimally controlled with oral agents. Diabetes Care. 2008 Nov;31(11):2177–82. doi: 10.2337/dc08-0315. PMID: 18678610. Exclusion Code: X2.18678610
390 Rosenstock J, Rendell MS, Gross JL, . Alogliptin added to insulin therapy in patients with type 2 diabetes reduces HbA(1C) without causing weight gain or increased hypoglycaemia. Diabetes Obes Metab. 2009 Dec;11(12):1145–52. doi: 10.1111/j.1463-1326.2009.01124.x. PMID: 19758359. Exclusion Code: X2.19758359
391 Rothman RL, Malone R, Bryant B, . A randomized trial of a primary care-based disease management program to improve cardiovascular risk factors and glycated hemoglobin levels in patients with diabetes. Am J Med. 2005;118(3):276–84. doi: 10.1016/j.amjmed.2004.09.017. PMID: CN-00502496. Exclusion Code: X2.15745726
392 Sahakitrungruang T, Klomchan T, Supornsilchai V, . Obesity, metabolic syndrome, and insulin dynamics in children after craniopharyngioma surgery. Eur J Pediatr. 2011 Jun;170(6):763–9. doi: 10.1007/s00431-010-1347-8. PMID: 21107605. Exclusion Code: X2.21107605
393 Sahin NM, Kinik ST, Tekindal MA. OGTT results in obese adolescents with normal HOMA-IR values. J Pediatr Endocrinol Metab. 2013;26(3–4):285–91. doi: 10.1515/jpem-2012-0206. PMID: 23327814. Exclusion Code: X2.23327814
394 Saletsky RD, Trief PM, Anderson BJ, . Parenting style, parent-youth conflict, and medication adherence in youth with type 2 diabetes participating in an intensive lifestyle change intervention. Fam Syst Health. 2014 Jun;32(2):176–85. doi: 10.1037/fsh0000008. PMID: 24548045. Exclusion Code: X6.24548045
395 Saponaro F, Sonaglioni A, Rossi A, . Improved diastolic function in type 2 diabetes after a six month liraglutide treatment. Diabetes Res Clin Pract. 2016 Aug;118:21–8. doi: 10.1016/j.diabres.2016.04.046. PMID: 27485853. Exclusion Code: X2.27485853
396 Sauder KA, Dabelea D, Bailey-Callahan R, . Targeting risk factors for type 2 diabetes in American Indian youth: the Tribal Turning Point pilot study. Pediatr Obes. 2018 May;13(5):321–9. doi: 10.1111/ijpo.12223. PMID: 28635082. Exclusion Code: X6.28635082
397 Saunders TJ, Chaput JP, Goldfield GS, . Prolonged sitting and markers of cardiometabolic disease risk in children and youth: a randomized crossover study. Metabolism. 2013;62(10):1423–8. doi: 10.1016/j.metabol.2013.05.010. PMID: CN-00963424. Exclusion Code: X2.23773981
398 Savoye M, Caprio S, Dziura J, . A community-based intervention for diabetes risk reduction in innercity obese adolescents. Diabetologia. 2013;56:S342-. doi: 10.1007/s00125-013-3012-z. PMID: CN-01010694. Exclusion Code: X6.
399 Scheen AJ, Finer N, Hollander P, . Efficacy and tolerability of rimonabant in overweight or obese patients with type 2 diabetes: a randomised controlled study. Lancet. 2006 Nov 11;368(9548):1660–72. doi: 10.1016/s0140-6736(06)69571-8. PMID: 17098084. Exclusion Code: X2.17098084
400 Schiel R, Voigt U, Ross IS, . Structured diabetes therapy and education improves the outcome of patients with insulin treated diabetes mellitus. The 10 year follow-up of a prospective, population-based survey on the quality of diabetes care (the JEVIN Trial). Exp Clin Endocrinol Diabetes. 2006 Jan;114(1):18–27. doi: 10.1055/s-2005-873079. PMID: 16450312. Exclusion Code: X2.16450312
401 Schober E, Waldhoer T, Rami B, . Incidence and time trend of type 1 and type 2 diabetes in Austrian children 1999-2007. J Pediatr. 2009 Aug;155(2):190–3.e1. doi: 10.1016/j.jpeds.2009.03.010. PMID: 19476954. Exclusion Code: X5.19476954
402 Schwertner R, Engelsberger I, Rabl W, . Prophylactic intermitiary insulin therapy in pre-diabetic children and adolescents. Monatsschr Kinderheilkd. 1994;142(Suppl 1):S 68. PMID: CN-00339593. Exclusion Code: X1.
403 Scott SE, Breckon JD, Copeland RJ. An integrated motivational interviewing and cognitive-behavioural intervention promoting physical activity maintenance for adults with chronic health conditions: a feasibility study. Chronic illness. 2019;15(4):276–92. doi: 10.1177/1742395318769370. PMID: CN-02117501. Exclusion Code: X2.29642707
404 Seino Y, Min KW, Niemoeller E, . Randomized, double-blind, placebo-controlled trial of the once-daily GLP-1 receptor agonist lixisenatide in Asian patients with type 2 diabetes insufficiently controlled on basal insulin with or without a sulfonylurea (GetGoal-L-Asia). Diabetes Obes Metab. 2012 Oct;14(10):910–7. doi: 10.1111/j.1463-1326.2012.01618.x. PMID: 22564709. Exclusion Code: X2.22564709
405 Sénéchal M, Rempel M, Duhamel TA, . Fitness is a determinant of the metabolic response to endurance training in adolescents at risk of type 2 diabetes mellitus. Obesity (Silver Spring). 2015 Apr;23(4):823–32. doi: 10.1002/oby.21032. PMID: 25755198. Exclusion Code: X8.25755198
406 Setayeshgar S, Ekwaru JP, Maximova K, . Dietary intake and prospective changes in cardiometabolic risk factors in children and youth. Appl Physiol Nutr Metab. 2017 Jan;42(1):39–45. doi: 10.1139/apnm-2016-0215. PMID: 27959641. Exclusion Code: X4.27959641
407 Shah AS, El Ghormli L, Vajravelu ME, . Heart rate variability and cardiac autonomic dysfunction: prevalence, risk factors, and relationship to arterial stiffness in the treatment options for Type 2 Diabetes in Adolescents and Youth (TODAY) Study. Diabetes Care. 2019;42(11):2143–50. doi: 10.2337/dc19-0993. PMID: CN-01989622. Exclusion Code: X6.31501226
408 Shah R, McKay SV, Levitt Katz LE, . Adherence to multiple medications in the TODAY (Treatment Options for type 2 Diabetes in Adolescents and Youth) cohort: effect of additional medications on adherence to primary diabetes medication. J Pediatr Endocrinol Metab. 2020 Feb 25;33(2):191–8. doi: 10.1515/jpem-2019-0315. PMID: 31809265. Exclusion Code: X6.31809265
409 Shahbazian H, Aleali AM, Rashidi H, . Frequency of type I and II diabetes in newly diagnosed diabetic patients: Measuring C-Peptide level. Diabetes Metab Syndr. 2019 May–Jun;13(3):1833–5. doi: 10.1016/j.dsx.2019.04.018. PMID: 31235102. Exclusion Code: X2.31235102
410 Shaibi GQ, Cruz ML, Ball GD, . Effects of resistance training on insulin sensitivity in overweight Latino adolescent males. Med Sci Sports Exerc. 2006;38(7):1208–15. doi: 10.1249/01.mss.0000227304.88406.0f. PMID: CN-00571078. Exclusion Code: X2.16826016
411 Shalitin S, Abrahami M, Lilos P, . Insulin resistance and impaired glucose tolerance in obese children and adolescents referred to a tertiary-care center in Israel. Int J Obes (Lond). 2005 Jun;29(6):571–8. doi: 10.1038/sj.ijo.0802919. PMID: 15889115. Exclusion Code: X8.15889115
412 Sharma S, Fleming SE. Use of HbA(1C) testing to diagnose pre-diabetes in high risk African American children: a comparison with fasting glucose and HOMA-IR. Diabetes Metab Syndr. 2012 Jul–Sep;6(3):157–62. doi: 10.1016/j.dsx.2012.09.004. PMID: 23158980. Exclusion Code: X2.23158980
413 Shaw M, Savoye M, Cali A, . Effect of a successful intensive lifestyle program on insulin sensitivity and glucose tolerance in obese youth. Diabetes Care. 2009 Jan;32(1):45–7. doi: 10.2337/dc08-0808. PMID: 18840769. Exclusion Code: X6.18840769
414 Shiner M. Effect of a gluten-free diet in 17 patients with idiopathic steatorrhea; a follow-up study. Am J Dig Dis. 1963 Dec;8:969–83. doi: 10.1007/bf02239489. PMID: 14084540. Exclusion Code: X8.14084540
415 Shivaprasad HN, Bhanumathy M, Sushma G, . Salacia reticulata improves serum lipid profiles and glycemic control in patients with prediabetes and mild to moderate hyperlipidemia: a double-blind, placebo-controlled, randomized trial. J Med Food. 2013 Jun;16(6):564–8. doi: 10.1089/jmf.2013.2751. PMID: 23767865. Exclusion Code: X2.23767865
416 Shoemaker A, Cheng P, Gal RL, . Predictors of loss to follow-up among children with type 2 diabetes. Horm Res Paediatr. 2017;87(6):377–84. doi: 10.1159/000475595. PMID: 28505610. Exclusion Code: X4.28505610
417 Shomaker LB, Kelly NR, Pickworth CK, . A randomized controlled trial to prevent depression and ameliorate insulin resistance in adolescent girls at risk for type 2 diabetes. Ann Behav Med. 2016 Oct;50(5):762–74. doi: 10.1007/s12160-016-9801-0. PMID: 27333897. Exclusion Code: X4.27333897
418 Short KR, Teague AM, Klein JC, . The Effect of Handcycle Ergometer Exercise on Glucose Tolerance in Ambulatory and Non-Ambulatory Adolescents. Pediatr Exerc Sci. 2017 Feb;29(1):63–72. doi: 10.1123/pes.2016-0047. PMID: 27176627. Exclusion Code: X2.27176627
419 Shultis WA, Leary SD, Ness AR, . Haemoglobin A1c is not a surrogate for glucose and insulin measures for investigating the early life and childhood determinants of insulin resistance and Type 2 diabetes in healthy children. An analysis from the Avon Longitudinal Study of Parents and Children (ALSPAC). Diabet Med. 2006 Dec;23(12):1357–63. doi: 10.1111/j.1464-5491.2006.01990.x. PMID: 17116188. Exclusion Code: X6.17116188
420 Sigal RJ, Alberga AS, Goldfield GS, . Effects of aerobic exercise, resistance exercise or both on % body fat in overweight adolescents: the HEARTY trial. Diabetes. 2013;62:A185. doi: 10.2337/db13-680-858. PMID: CN-01062018. Exclusion Code: X5.
421 Silic A, Janez A, Tomazic J, . Effect of rosiglitazone and metformin on insulin resistance in patients infected with human immunodeficiency virus receiving highly active antiretroviral therapy containing protease inhibitor: randomized prospective controlled clinical trial. Croat Med J. 2007 Dec;48(6):791–9. doi: 10.3325/cmj.2007.6.791. PMID: 18074413. Exclusion Code: X2.18074413
422 Simon D, Coignet MC, Thibult N, . Comparison of glycosylated hemoglobin and fasting plasma glucose with two-hour post-load plasma glucose in the detection of diabetes mellitus. Am J Epidemiol. 1985 Oct;122(4):589–93. doi: 10.1093/oxfordjournals.aje.a114138. PMID: 4025302. Exclusion Code: X2.4025302
423 Skrivanek Z, Gaydos BL, Chien JY, . Dose-finding results in an adaptive, seamless, randomized trial of once-weekly dulaglutide combined with metformin in type 2 diabetes patients (AWARD-5). Diabetes Obes Metab. 2014 Aug;16(8):748–56. doi: 10.1111/dom.12305. PMID: 24762094. Exclusion Code: X2.24762094
424 Soltero EG, Konopken YP, Olson ML, . Preventing diabetes in obese Latino youth with prediabetes: a study protocol for a randomized controlled trial. BMC Public Health. 2017 Mar 16;17(1):261. doi: 10.1186/s12889-017-4174-2. PMID: 28302101. Exclusion Code: X6.28302101
425 Soltero EG, Olson ML, Williams AN, . Effects of a community-based diabetes prevention program for Latino youth with obesity: a randomized controlled trial. Obesity (Silver Spring). 2018 Dec;26(12):1856–65. doi: 10.1002/oby.22300. PMID: 30426694. Exclusion Code: X2.30426694
426 Songer TJ, Haymond MW, Glazner JE, . Healthcare and associated costs related to type 2 diabetes in youth and adolescence: the TODAY clinical trial experience. Pediatr Diabetes. 2019 Sep;20(6):702–11. doi: 10.1111/pedi.12869. PMID: 31119838. Exclusion Code: X8.31119838
427 Sönksen PH, Lowy C, Perkins JR, . Non-insulin-dependent diabetes: 10-year outcome in relation to initial response to diet and subsequent sulfonylurea therapy. Diabetes Care. 1984 May–Jun;7 Suppl 1:59–66. PMID: 6376030. Exclusion Code: X2.6376030
428 Sorkin DH, Mavandadi S, Rook KS, . Dyadic collaboration in shared health behavior change: the effects of a randomized trial to test a lifestyle intervention for high-risk Latinas. Health Psychol. 2014;33(6):566–75. doi: 10.1037/hea0000063. PMID: CN-00996445. Exclusion Code: X2.24884910
429 Spruijt-Metz D, Belcher BR, Hsu YW, . Temporal relationship between insulin sensitivity and the pubertal decline in physical activity in peripubertal Hispanic and African American females. Diabetes Care. 2013 Nov;36(11):3739–45. doi: 10.2337/dc13-0083. PMID: 23846812. Exclusion Code: X5.23846812
430 Srinivasan S, Ambler GR, Baur LA, . Randomized, controlled trial of metformin for obesity and insulin resistance in children and adolescents: improvement in body composition and fasting insulin. J Clin Endocrinol Metab. 2006 Jun;91(6):2074–80. doi: 10.1210/jc.2006-0241. PMID: 16595599. Exclusion Code: X2.16595599
431 Srinivasan SR, Frontini MG, Berenson GS. Longitudinal changes in risk variables of insulin resistance syndrome from childhood to young adulthood in offspring of parents with type 2 diabetes: the Bogalusa Heart Study. Metabolism. 2003 Apr;52(4):443–50; discussion 51-3. doi: 10.1053/meta.2003.50065. PMID: 12701056. Exclusion Code: X6.12701056
432 Stagi S, Ricci F, Bianconi M, . Retrospective evaluation of metformin and/or metformin plus a new polysaccharide complex in treating severe hyperinsulinism and insulin resistance in obese children and adolescents with metabolic syndrome. Nutrients. 2017 May 20;9(5)doi: 10.3390/nu9050524. PMID: 28531113. Exclusion Code: X5.28531113
433 Staiano AE, Abraham AA, Calvert SL. Adolescent exergame play for weight loss and psychosocial improvement: a controlled physical activity intervention. Obesity (Silver Spring). 2013 Mar;21(3):598–601. doi: 10.1002/oby.20282. PMID: 23592669. Exclusion Code: X2.23592669
434 Starkman HS, Soeldner JS, Gleason RE. Oral glucose tolerance: relationship with hemoglobin A1c. Diabetes Res Clin Pract. 1987 Nov–Dec;3(6):343–9. doi: 10.1016/s0168-8227(87)80059-1. PMID: 3311681. Exclusion Code: X4.3311681
435 Stefanaki C, Michos A, Mastorakos G, . Probiotics in Adolescent Prediabetes: A Pilot RCT on Glycemic Control and Intestinal Bacteriome. J Clin Med. 2019 Oct 21;8(10)doi: 10.3390/jcm8101743. PMID: 31640224. Exclusion Code: X4.31640224
436 Stenlöf K, Cefalu WT, Kim KA, . Efficacy and safety of canagliflozin monotherapy in subjects with type 2 diabetes mellitus inadequately controlled with diet and exercise. Diabetes Obes Metab. 2013 Apr;15(4):372–82. doi: 10.1111/dom.12054. PMID: 23279307. Exclusion Code: X2.23279307
437 Sunehag AL, Toffolo G, Campioni M, . Short-term high dietary fructose intake had no effects on insulin sensitivity and secretion or glucose and lipid metabolism in healthy, obese adolescents. J Pediatr Endocrinol Metab. 2008 Mar;21(3):225–35. doi: 10.1515/jpem.2008.21.3.225. PMID: 18540249. Exclusion Code: X5.18540249
438 Sweeney NM, Stewart C, Gaines R, . Screening for overweight and diabetes in rural Hispanic and Caucasian fifth-grade children. J Pediatr Nurs. 2007 Dec;22(6):432–9. doi: 10.1016/j.pedn.2007.09.001. PMID: 18036463. Exclusion Code: X8.18036463
439 Sylvetsky AC, Chandran A, Talegawkar SA, . Consumption of beverages containing low-calorie sweeteners, diet, and cardiometabolic health in youth with type 2 diabetes. J Acad Nutr Diet. 2020 Aug;120(8):1348–58.e6. doi: 10.1016/j.jand.2020.04.005. PMID: 32711855. Exclusion Code: X6.32711855
440 Sylvetsky AC, Nandagopal R, Nguyen TT, . Buddy Study: partners for better health in adolescents with type 2 diabetes. World J Diabetes. 2015 Dec 25;6(18):1355–62. doi: 10.4239/wjd.v6.i18.1355. PMID: 26722619. Exclusion Code: X4.26722619
441 Taha DR, Castells S, Umpaichitra V, . Beta-cell response to intravenous glucagon in African-American and Hispanic children with type 2 diabetes mellitus. J Pediatr Endocrinol Metab. 2002 Jan;15(1):59–67. doi: 10.1515/jpem.2002.15.1.59. PMID: 11822582. Exclusion Code: X6.11822582
442 Tam CH, Wang Y, Luan J, . Non-linear relationship between birthweight and cardiometabolic risk factors in Chinese adolescents and adults. Diabet Med. 2015 Feb;32(2):220–5. doi: 10.1111/dme.12630. PMID: 25388749. Exclusion Code: X4.25388749
443 Tamborlane WV, Barrientos-Pérez M, Fainberg U, . Liraglutide in children and adolescents with type 2 diabetes. N Engl J Med. 2019 Aug 15;381(7):637–46. doi: 10.1056/NEJMoa1903822. PMID: 31034184. Exclusion Code: X2.31034184
444 Tamborlane WV, Laffel LM, Weill J, . Randomized, double-blind, placebo-controlled dose-finding study of the dipeptidyl peptidase-4 inhibitor linagliptin in pediatric patients with type 2 diabetes. Pediatr Diabetes. 2018 Jun;19(4):640–8. doi: 10.1111/pedi.12616. PMID: 29171139. Exclusion Code: X2.29171139
445 Taskinen MR, Rosenstock J, Tamminen I, . Safety and efficacy of linagliptin as add-on therapy to metformin in patients with type 2 diabetes: a randomized, double-blind, placebo-controlled study. Diabetes Obes Metab. 2011 Jan;13(1):65–74. doi: 10.1111/j.1463-1326.2010.01326.x. PMID: 21114605. Exclusion Code: X2.21114605
446 Taylor JH, Xu Y, Li F, . Psychosocial predictors and moderators of weight management programme outcomes in ethnically diverse obese youth. Pediatr Obes. 2017 Dec;12(6):453–61. doi: 10.1111/ijpo.12165. PMID: 27384496. Exclusion Code: X5.27384496
447 Terlemez S, Bozdemir E, Kalkan Uçar S, . Insulin resistance in children with familial hyperlipidemia. J Pediatr Endocrinol Metab. 2018 Dec 19;31(12):1349–54. doi: 10.1515/jpem-2018-0337. PMID: 30433876. Exclusion Code: X8.30433876
448 Tester J, Sharma S, Jasik CB, . Gender differences in prediabetes and insulin resistance among 1356 obese children in Northern California. Diabetes Metab Syndr. 2013 Jul–Sep;7(3):161–5. doi: 10.1016/j.dsx.2013.06.002. PMID: 23953182. Exclusion Code: X8.23953182
449 The NS, Richardson AS, Gordon-Larsen P. Timing and duration of obesity in relation to diabetes: findings from an ethnically diverse, nationally representative sample. Diabetes Care. 2013 Apr;36(4):865–72. doi: 10.2337/dc12-0536. PMID: 23223352. Exclusion Code: X4.23223352
450 Tirucherai GS, LaCreta F, Ismat FA, . Pharmacokinetics and pharmacodynamics of dapagliflozin in children and adolescents with type 2 diabetes mellitus. Diabetes Obes Metab. 2016;18(7):678–84. doi: 10.1111/dom.12638. PMID: CN-01166739. Exclusion Code: X5.27291448
451 Toaiari M, Davì MV, Dalle Carbonare L, . Presentation, diagnostic features and glucose handling in a monocentric series of insulinomas. J Endocrinol Invest. 2013 Oct;36(9):753–8. doi: 10.3275/8942. PMID: 23608735. Exclusion Code: X2.23608735
452 TODAY Study Group. Rapid rise in hypertension and nephropathy in youth with type 2 diabetes: the TODAY clinical trial. Diabetes Care. 2013 Jun;36(6):1735–41. doi: 10.2337/dc12-2420. PMID: 23704672. Exclusion Code: X6.23704672
453 TODAY Study Group. Treatment effects on measures of body composition in the TODAY clinical trial. Diabetes Care. 2013 Jun;36(6):1742–8. doi: 10.2337/dc12-2534. PMID: 23704673. Exclusion Code: X6.23704673
454 Today Study Group. Retinopathy in youth with type 2 diabetes participating in the TODAY clinical trial. Diabetes Care. 2013 Jun;36(6):1772–4. doi: 10.2337/dc12-2387. PMID: 23704677. Exclusion Code: X5.23704677
455 TODAY Study Group. Postintervention effects of varying treatment arms on glycemic failure and β-cell function in the TODAY Trial. Diabetes Care. 2021 Jan;44(1):75–80. doi: 10.2337/dc20-0622. PMID: 33290248. Exclusion Code: X6.33290248
456 Toledo-Corral CM, Alderete TL, Richey J, . Fasting, post-OGTT challenge, and nocturnal free fatty acids in prediabetic versus normal glucose tolerant overweight and obese Latino adolescents. Acta Diabetol. 2015 Apr;52(2):277–84. doi: 10.1007/s00592-014-0634-7. PMID: 25109287. Exclusion Code: X6.25109287
457 Tomlin A, Dovey S, Tilyard M. Health outcomes for diabetes patients returning for three annual general practice checks. N Z Med J. 2007 Apr 13;120(1252):U2493. PMID: 17460743. Exclusion Code: X4.17460743
458 Torres-García R, Camarillo-Romero ES, Majluf-Cruz A, . Effect of exercise on the serum concentrations of leptin and adiponectin in adolescents with risk factors of developing diabetes. Rev Med Inst Mex Seguro Soc. 2017;55(6):708–14. PMID: CN-01621763. Exclusion Code: X1.29190863
459 Tricò D, Natali A, Arslanian S, . Identification, pathophysiology, and clinical implications of primary insulin hypersecretion in nondiabetic adults and adolescents. JCI Insight. 2018 Dec 20;3(24)doi: 10.1172/jci.insight.124912. PMID: 30568042. Exclusion Code: X2.30568042
460 Turner KM, Percival J, Dunger DB, . Adolescents’ views and experiences of treatments for Type 2 diabetes: a qualitative study. Diabet Med. 2015 Feb;32(2):250–6. doi: 10.1111/dme.12577. PMID: 25186101. Exclusion Code: X4.25186101
461 Uçkun-Kitapçi A, Teziç T, Firat S, . Obesity and type 2 diabetes mellitus: a population-based study of adolescents. J Pediatr Endocrinol Metab. 2004 Dec;17(12):1633–40. doi: 10.1515/jpem.2004.17.12.1633. PMID: 15645697. Exclusion Code: X8.15645697
462 Vajravelu ME, Lee JM, Shah R, . Association between prediabetes diagnosis and body mass index trajectory of overweight and obese adolescents. Pediatr Diabetes. 2020 Aug;21(5):743–6. doi: 10.1111/pedi.13028. PMID: 32314478. Exclusion Code: X8.32314478
463 Van Buren DJ, Wilfley DE, Marcus MD, . Depressive symptoms and glycemic control in youth with type 2 diabetes participating in the TODAY clinical trial. Diabetes Res Clin Pract. 2018 Jan;135:85–7. doi: 10.1016/j.diabres.2017.11.008. PMID: 29146120. Exclusion Code: X5.29146120
464 van den Burg EL, Schoonakker MP, van Peet PG, . Fasting in diabetes treatment (FIT) trial: study protocol for a randomised, controlled, assessor-blinded intervention trial on the effects of intermittent use of a fasting-mimicking diet in patients with type 2 diabetes. BMC Endocr Disord. 2020 Jun 24;20(1):94. doi: 10.1186/s12902-020-00576-7. PMID: 32580710. Exclusion Code: X2.32580710
465 van der Aa MP, Elst MA, van de Garde EM, . Long-term treatment with metformin in obese, insulin-resistant adolescents: results of a randomized double-blinded placebo-controlled trial. Nutr Diabetes. 2016 Aug 29;6(8):e228. doi: 10.1038/nutd.2016.37. PMID: 27571249. Exclusion Code: X2.27571249
466 van der Aa MP, Elst MA, van Mil EG, . METFORMIN: an efficacy, safety and pharmacokinetic study on the short-term and long-term use in obese children and adolescents - study protocol of a randomized controlled study. Trials. 2014 Jun 5;15:207. doi: 10.1186/1745-6215-15-207. PMID: 24899137. Exclusion Code: X6.24899137
467 van der Aa MP, Fazeli Farsani S, Kromwijk LA, . How to screen obese children at risk for type 2 diabetes mellitus? Clin Pediatr (Phila). 2014 Apr;53(4):337–42. doi: 10.1177/0009922813509480. PMID: 24243989. Exclusion Code: X8.24243989
468 Van Hulst A, Paradis G, Harnois-Leblanc S, . Lowering saturated fat and increasing vegetable and fruit intake may increase insulin sensitivity 2 years later in children with a family history of obesity. J Nutr. 2018 Nov 1;148(11):1838–44. doi: 10.1093/jn/nxy189. PMID: 30383280. Exclusion Code: X5.30383280
469 Vangeepuram N, Townsend K, Arniella G, . Recruitment in clinical versus community-based sites for a pilot youth diabetes prevention program, East Harlem, New York, 2011-2012. Prev Chronic Dis. 2016 Jan 28;13:E14. doi: 10.5888/pcd13.150449. PMID: 26820046. Exclusion Code: X5.26820046
470 Vellanki P, Smiley DD, Stefanovski D, . Randomized controlled study of metformin and sitagliptin on long-term normoglycemia remission in African American patients with hyperglycemic crises. Diabetes Care. 2016 Nov;39(11):1948–55. doi: 10.2337/dc16-0406. PMID: 27573938. Exclusion Code: X2.27573938
471 Ventura E, Davis J, Byrd-Williams C, . Reduction in risk factors for type 2 diabetes mellitus in response to a low-sugar, high-fiber dietary intervention in overweight Latino adolescents. Arch Pediatr Adolesc Med. 2009 Apr;163(4):320–7. doi: 10.1001/archpediatrics.2009.11. PMID: 19349560. Exclusion Code: X2.19349560
472 Viitasalo A, Schnurr TM, Pitkänen N, . Abdominal adiposity and cardiometabolic risk factors in children and adolescents: a Mendelian randomization analysis. Am J Clin Nutr. 2019 Nov 1;110(5):1079–87. doi: 10.1093/ajcn/nqz187. PMID: 31504107. Exclusion Code: X4.31504107
473 Vijayadeva V, Nichols GA. Impact of implementing glycated hemoglobin testing for identification of dysglycemia in youth. Perm J. 2014 Fall;18(4):21–7. doi: 10.7812/tpp/14-029. PMID: 25141989. Exclusion Code: X8.25141989
474 Vitale M, Masulli M, Rivellese AA, . Pasta consumption and connected dietary habits: associations with glucose control, adiposity measures, and cardiovascular risk factors in people with type 2 diabetes-TOSCA.IT Study. Nutrients. 2019 Dec 30;12(1)doi: 10.3390/nu12010101. PMID: 31905885. Exclusion Code: X2.31905885
475 Vos RC, Wit JM, Pijl H, . The effect of family-based multidisciplinary cognitive behavioral treatment in children with obesity: study protocol for a randomized controlled trial. Trials. 2011 May 6;12:110. doi: 10.1186/1745-6215-12-110. PMID: 21548919. Exclusion Code: X6.21548919
476 Wagner KA, Braun E, Armah SM, . Dietary Intervention for Glucose Tolerance In Teens (DIG IT): protocol of a randomized controlled trial using health coaching to prevent youth-onset type 2 diabetes. Contemp Clin Trials. 2017 Feb;53:171–7. doi: 10.1016/j.cct.2016.12.018. PMID: 28011388. Exclusion Code: X6.28011388
477 Walders-Abramson N, Venditti EM, Ievers-Landis CE, . Relationships among stressful life events and physiological markers, treatment adherence, and psychosocial functioning among youth with type 2 diabetes. J Pediatr. 2014 Sep;165(3):504–8.e1. doi: 10.1016/j.jpeds.2014.05.020. PMID: 24948348. Exclusion Code: X6.24948348
478 Wallace AS, Wang D, Shin JI, . Screening and diagnosis of prediabetes and diabetes in US children and adolescents. Pediatrics. 2020 Sep;146(3)doi: 10.1542/peds.2020-0265. PMID: 32778539. Exclusion Code: X6.32778539
479 Waller K, Kaprio J, Lehtovirta M, . Leisure-time physical activity and type 2 diabetes during a 28 year follow-up in twins. Diabetologia. 2010 Dec;53(12):2531–7. doi: 10.1007/s00125-010-1875-9. PMID: 20706830. Exclusion Code: X2.20706830
480 Walsh JJ, D’Angiulli A, Cameron JD, . Changes in the brain-derived neurotrophic factor are associated with improvements in diabetes risk factors after exercise training in adolescents with obesity: the HEARTY randomized controlled trial. Neural Plast. 2018;2018:7169583. doi: 10.1155/2018/7169583. PMID: 30363954. Exclusion Code: X5.30363954
481 Wan Q, Wang F, Wang F, . Regression to normoglycaemia by fenofibrate in pre-diabetic subjects complicated with hypertriglyceridaemia: a prospective randomized controlled trial. Diabet Med. 2010 Nov;27(11):1312–7. doi: 10.1111/j.1464-5491.2010.03107.x. PMID: 20968112. Exclusion Code: X2.20968112
482 Wang G, Radovick S, Xu X, . Strategy for early identification of prediabetes in lean populations: new insight from a prospective Chinese twin cohort of children and young adults. Diabetes Res Clin Pract. 2018 Dec;146:101–10. doi: 10.1016/j.diabres.2018.10.003. PMID: 30312713. Exclusion Code: X8.30312713
483 Wang J, Light K, Henderson M, . Consumption of added sugars from liquid but not solid sources predicts impaired glucose homeostasis and insulin resistance among youth at risk of obesity. J Nutr. 2014 Jan;144(1):81–6. doi: 10.3945/jn.113.182519. PMID: 24198307. Exclusion Code: X5.24198307
484 Wang SY, Andrews CA, Herman WH, . Incidence and risk factors for developing diabetic retinopathy among youths with type 1 or type 2 diabetes throughout the United States. Ophthalmology. 2017 Apr;124(4):424–30. doi: 10.1016/j.ophtha.2016.10.031. PMID: 27914837. Exclusion Code: X8.27914837
485 Wang X, Wang T, Yu M, . Screening of HNF1A and HNF4A mutation and clinical phenotype analysis in a large cohort of Chinese patients with maturity-onset diabetes of the young. Acta Diabetol. 2019 Mar;56(3):281–8. doi: 10.1007/s00592-018-1232-x. PMID: 30293189. Exclusion Code: X5.30293189
486 Warnakulasuriya LS, Fernando MMA, Adikaram AVN, . Metformin in the management of childhood obesity: a randomized control trial. Child Obes. 2018 Nov/Dec;14(8):553–65. doi: 10.1089/chi.2018.0043. PMID: 30070925. Exclusion Code: X6.30070925
487 Weghuber D, Forslund A, Ahlström H, . A 6-month randomized, double-blind, placebo-controlled trial of weekly exenatide in adolescents with obesity. Pediatr Obes. 2020;15(7):1–11. doi: 10.1111/ijpo.12624. PMID: CN-02198805. Exclusion Code: X2.
488 Weghuber D, Forslund A, Ahlström H, . A 6-month randomized, double-blind, placebo-controlled trial of weekly exenatide in adolescents with obesity. Pediatr Obes. 2020 Jul;15(7):e12624. doi: 10.1111/ijpo.12624. PMID: 32062862. Exclusion Code: X2.32062862
489 Weghuber D, Forslund A, Ahlström H, . Effect of exenatide on BMI-SDS and 2-hour postprandial glucose in obese adolescents. Obesity facts. 2018;11:215-. doi: 10.1159/000489691. PMID: CN-01612822. Exclusion Code: X10.
490 Weigensberg MJ, Lane CJ, Ávila Q, . Imagine HEALTH: results from a randomized pilot lifestyle intervention for obese Latino adolescents using Interactive Guided ImagerySM. BMC Complement Altern Med. 2014 Jan 17;14:28. doi: 10.1186/1472-6882-14-28. PMID: 24433565. Exclusion Code: X5.24433565
491 Weinstock RS, Braffett BH, McGuigan P, . Self-monitoring of blood glucose in youth-onset type 2 diabetes: results from the TODAY Study. Diabetes Care. 2019 May;42(5):903–9. doi: 10.2337/dc18-1854. PMID: 30833375. Exclusion Code: X6.30833375
492 Weinstock RS, Trief PM, El Ghormli L, . Parental characteristics associated with outcomes in youth with type 2 diabetes: results from the TODAY clinical trial. Diabetes Care. 2015;38(5):784–92. doi: 10.2337/dc14-2393. PMID: CN-01110117. Exclusion Code: X8.25784663
493 Whaley-Connell A, Sowers JR, McCullough PA, . Diabetes mellitus and CKD awareness: the Kidney Early Evaluation Program (KEEP) and National Health and Nutrition Examination Survey (NHANES). Am J Kidney Dis. 2009 Apr;53(4 Suppl 4):S11–21. doi: 10.1053/j.ajkd.2009.01.004. PMID: 19285607. Exclusion Code: X2.19285607
494 Wiegand S, Dannemann A, Krude H, . Impaired glucose tolerance and type 2 diabetes mellitus: a new field for pediatrics in Europe. Int J Obes (Lond). 2005 Sep;29 Suppl 2:S136–42. doi: 10.1038/sj.ijo.0803081. PMID: 16385766. Exclusion Code: X8.16385766
495 Wiegand S, l’Allemand D, Hubel H, . Metformin and placebo therapy both improve weight management and fasting insulin in obese insulin-resistant adolescents: a prospective, placebo-controlled, randomized study. Eur J Endocrinol. 2010 Oct;163(4):585–92. doi: 10.1530/EJE-10-0570. PMID: 20639355. Exclusion Code: X2.20639355
496 Wijesuriya M, Fountoulakis N, Guess N, . A pragmatic lifestyle modification programme reduces the incidence of predictors of cardio-metabolic disease and dysglycaemia in a young healthy urban South Asian population: a randomised controlled trial. BMC Med. 2017 Aug 30;15(1):146. doi: 10.1186/s12916-017-0905-6. PMID: 28851373. Exclusion Code: X5.28851373
497 Wijesuriya M, Gulliford M, Vasantharajah L, . DIABRISK-SL prevention of cardio-metabolic disease with life style modification in young urban Sri Lankan’s--study protocol for a randomized controlled trial. Trials. 2011 Sep 26;12:209. doi: 10.1186/1745-6215-12-209. PMID: 21943067. Exclusion Code: X2.21943067
498 Wilding JP, Charpentier G, Hollander P, . Efficacy and safety of canagliflozin in patients with type 2 diabetes mellitus inadequately controlled with metformin and sulphonylurea: a randomised trial. Int J Clin Pract. 2013 Dec;67(12):1267–82. doi: 10.1111/ijcp.12322. PMID: 24118688. Exclusion Code: X2.24118688
499 Wilding JP, Woo V, Soler NG, . Long-term efficacy of dapagliflozin in patients with type 2 diabetes mellitus receiving high doses of insulin: a randomized trial. Ann Intern Med. 2012 Mar 20;156(6):405–15. doi: 10.7326/0003-4819-156-6-201203200-00003. PMID: 22431673. Exclusion Code: X2.22431673
500 Wilfley D, Berkowitz R, Goebel-Fabbri A, . Binge eating, mood, and quality of life in youth with type 2 diabetes: baseline data from the today study. Diabetes Care. 2011 Apr;34(4):858–60. doi: 10.2337/dc10-1704. PMID: 21357794. Exclusion Code: X6.21357794
501 Williams AN, Konopken YP, Keller CS, . Culturally-grounded diabetes prevention program for obese Latino youth: Rationale, design, and methods. Contemp Clin Trials. 2017 Mar;54:68–76. doi: 10.1016/j.cct.2017.01.004. PMID: 28104469. Exclusion Code: X6.28104469
502 Wilson DM, Abrams SH, Aye T, . Metformin extended release treatment of adolescent obesity: a 48-week randomized, double-blind, placebo-controlled trial with 48-week follow-up. Arch Pediatr Adolesc Med. 2010 Feb;164(2):116–23. doi: 10.1001/archpediatrics.2009.264. PMID: 20124139. Exclusion Code: X2.20124139
503 Xiao H, Adams SR, Goler N, . Wellness coaching for people with prediabetes: a randomized encouragement trial to evaluate outreach methods at Kaiser Permanente, Northern California, 2013. Prev Chronic Dis. 2015 Nov 25;12:E207. doi: 10.5888/pcd12.150251. PMID: 26605707. Exclusion Code: X2.26605707
504 Xu HY, Si HY. Clinical effect of subcutaneous insulin injection combined with metformin for type 2 diabetes mellitus in children. World Chinese Journal of Digestology. 2014;22(10):1479–83. doi: 10.11569/wcjd.v22.i10.1479. PMID: CN-01001330. Exclusion Code: X1.
505 Yanovski JA, Krakoff J, Salaita CG, . Effects of metformin on body weight and body composition in obese insulin-resistant children: a randomized clinical trial. Diabetes. 2011 Feb;60(2):477–85. doi: 10.2337/db10-1185. PMID: 21228310. Exclusion Code: X6.21228310
506 Yin C, Zhang H, Xiao Y, . Shape of glucose curve can be used as a predictor for screening prediabetes in obese children. Acta Paediatr. 2014 May;103(5):e199–205. doi: 10.1111/apa.12572. PMID: 24460776. Exclusion Code: X8.24460776
507 Yin J, Wong R, Au S, . Effects of providing peer support on diabetes management in people with type 2 diabetes. Ann Fam Med. 2015 Aug;13 Suppl 1(Suppl 1):S42–9. doi: 10.1370/afm.1853. PMID: 26304971. Exclusion Code: X2.26304971
508 Yoon JS, So CH, Lee HS, . Glycated hemoglobin A1c as a screening test for detecting type 2 diabetes mellitus in obese children and adolescents. J Pediatr Endocrinol Metab. 2018 Apr 25;31(5):503–6. doi: 10.1515/jpem-2017-0463. PMID: 29652667. Exclusion Code: X8.29652667
509 Zannolli R, Rebeggiani A, Chiarelli F, . Hyperinsulinism as a marker in obese children. Am J Dis Child. 1993 Aug;147(8):837–41. doi: 10.1001/archpedi.1993.02160320039016. PMID: 8352218. Exclusion Code: X6.8352218
510 Zdravković V, Sajić S, Mitrović J, . The diagnosis of prediabetes in adolescents. J Med Biochem. 2015 Jan;34(1):38–45. doi: 10.2478/jomb-2014-0062. PMID: 28356822. Exclusion Code: X8.28356822
511 Zeitler P, Hirst K, Copeland KC, . HbA1c after a short period of monotherapy with metformin identifies durable glycemic control among adolescents with type 2 diabetes. Diabetes Care. 2015 Dec;38(12):2285–92. doi: 10.2337/dc15-0848. PMID: 26537182. Exclusion Code: X6.26537182
512 Zhang T, Zhang H, Li Y, . Long-term impact of temporal sequence from childhood obesity to hyperinsulinemia on adult metabolic syndrome and diabetes: the Bogalusa Heart Study. Sci Rep. 2017 Feb 23;7:43422. doi: 10.1038/srep43422. PMID: 28230104. Exclusion Code: X4.28230104
513 Zhong X, Wang Z, Fisher EB, . Peer support for diabetes management in primary care and community settings in Anhui Province, China. Ann Fam Med. 2015 Aug;13 Suppl 1(Suppl 1):S50–8. doi: 10.1370/afm.1799. PMID: 26304972. Exclusion Code: X2.26304972
514 Zhou QX, Wang ZY, Zhao HF, . The effects of GLP-1 analogues on pre-diabetes of the children. Exp Ther Med. 2017 Apr;13(4):1426–30. doi: 10.3892/etm.2017.4129. PMID: 28413488. Exclusion Code: X9.28413488
515 Zinman B, Gerich J, Buse JB, . Efficacy and safety of the human glucagon-like peptide-1 analog liraglutide in combination with metformin and thiazolidinedione in patients with type 2 diabetes (LEAD-4 Met+TZD). Diabetes Care. 2009 Jul;32(7):1224–30. doi: 10.2337/dc08-2124. PMID: 19289857. Exclusion Code: X2.19289857
516 Zuhri-Yafi MI, Brosnan PG, Hardin DS. Treatment of type 2 diabetes mellitus in children and adolescents. J Pediatr Endocrinol Metab. 2002 Apr;15 Suppl 1:541–6. PMID: 12017229. Exclusion Code: X8.12017229