# Appendix B Additional Methods Information

## Appendix B1 Original Literature Search Strategies

### PubMed Screening, 8/3/2020

Search Number | Query | Filters | Results
1 | “Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Tolerance”[Mesh] OR “glucose tolerance”[All Fields] OR “impaired glucose tolerance”[All Fields] OR dysglycemia[tiab] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields] | | 213,359
2 | “Blood Glucose”[Mesh] OR “blood glucose”[tiab] OR “Glucose Tolerance Test”[Mesh] OR OGTT[tiab] OR “glucose tolerance test”[ti] OR “Glycated Hemoglobin A”[Mesh] OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose”[tiab] OR “oral glucose tolerance”[tiab] | | 253,967
3 | #1 AND #2 | | 97,474
4 | “Mass Screening”[Mesh] OR screen*[tiab] | | 796,716
5 | #3 AND #4 | | 6,429
6 | #5 NOT (gestation* OR Pregnancy[Mesh]) | | 4,708
7 | #5 NOT (gestation* OR Pregnancy[Mesh]) | English | 4,331
8 | #5 NOT (gestation* OR Pregnancy[Mesh]) | English, Child: birth-18 years | 698
9 | adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab] | | 1,766,063
10 | #7 AND #9 | | 345
11 | #8 OR #10 | | 759
12 | (#11 AND humans[mesh:noexp]) OR (#11 NOT animals[mesh:noexp]) | | 758
13 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta] | | 323,325
14 | #12 AND #13 | | 11
15 | “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR (controlled[tiab] AND trial[tiab]) OR groups [tiab] OR placebo [tiab] OR randomised [tiab] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] | | 3,141,667
16 | #12 AND #15 | | 206
17 | #12 AND “Case-Control Studies”[MeSH] | | 74
18 | “Cohort Studies”Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) | | 2,550,540
19 | #12 AND #18 | | 284
20 | “Evaluation Study”[pt] OR “Comparative Study”[pt] | | 2,062,504
21 | #12 AND #20 | | 70
22 | #17 OR #19 OR #21 | | 324

### PubMed Interventions, 8/3/2020

Search Number | Query | Filters | Results
1 | “Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Tolerance”[Mesh] OR “glucose tolerance”[All Fields] OR “impaired glucose tolerance”[All Fields] OR dysglycemia[tiab] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields] | | 213,359
2 | Actos[tiab] OR Albiglutide[tiab] OR Amaryl[tiab] OR Biguanides[Mesh] OR Biguanides[tiab] OR Bydureon[tiab] OR Byetta[tiab] OR DiaBeta[tiab] OR “Dipeptidyl-Peptidase IV Inhibitors”[Mesh] OR “Dipeptidyl-Peptidase IV Inhibitors”[Pharmacological Action] OR “Dipeptidyl peptidase IV inhibitor”[tiab] OR “Dipeptidyl peptidase IV inhibitors”[tiab] OR dulaglutide[Supplementary Concept] OR dulaglutide[tiab] OR exenatide[Supplementary Concept] OR Exenatide[tiab] OR Fortamet[tiab] OR Gliclazide[Mesh] OR Gliclazide[tiab] OR glimepiride[tiab] OR Glipizide[Mesh] OR glipizide[tiab] OR “GLP-1 receptor agonist”[tiab] OR “GLP-1 receptor agonists”[tiab] OR “Glucagon-like peptide-1 receptor agonist”[tiab] OR “Glucagon-like peptide-1 receptor agonists”[tiab] OR Glucophage[tiab] OR Glucotrol[tiab] OR “Glucotrol XL”[tiab] OR Glumetza[tiab] OR Glyburide[Mesh] OR glyburide[tiab] OR “Glynase PresTab”[tiab] OR Linagliptin[Mesh] OR Linagliptin[tiab] OR Liraglutide[Mesh] OR liraglutide[tiab] OR lixisenatide[Supplementary Concept] OR lixisenatide[tiab] OR Lyxumia[tiab] OR Meglitinides[tiab] OR Metformin[Mesh] OR Metformin[tiab] OR Micronase[tiab] OR nateglinide[Supplementary Concept] OR Nateglinide[tiab] OR Ozempic[tiab] OR pioglitazone[Supplementary Concept] OR Pioglitazone[tiab] OR Prandin[tiab] OR Repaglinide[tiab] OR rosiglitazone[Supplementary Concept] OR Rosiglitazone[tiab] OR Saxagliptin[tiab] OR semaglutide[Supplementary Concept] OR semaglutide[tiab] OR Sitagliptin[tiab] OR “Sitagliptin Phosphate”[Mesh] OR “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”[Mesh] OR “Sulfonylurea Compounds”[Mesh] OR Starlix[tiab] OR Sulfonylureas[tiab] OR Tanzeum[tiab] OR Thiazolidinediones[Mesh] OR Thiazolidinediones[tiab] OR Tolazamide[Mesh] OR Tolazamide[tiab] OR Tolbutamide[Mesh] OR tolbutamide[tiab] OR Trulicity[tiab] OR TZDs[tiab] OR Victoza[tiab] OR vildagliptin[Supplementary Concept] OR vildagliptin[tiab] | | 78,684
3 | #1 AND #2 | | 23,456
4 | advice[tiab] OR “Behavior Therapy”[Mesh] OR “behavior therapy”[tiab] OR (behavior*[tiab] AND therap*[tiab]) OR (behavior*[tiab] AND chang*[tiab]) OR (behavior*[tiab] AND modification*[tiab]) OR “Caloric Restriction”[Mesh] OR ((child*[tiab] AND parent*[tiab]) and therap*[tiab]) OR Counseling[Mesh] OR counsel*[tiab] OR “cognitive behavior”[tiab] OR “cognitive behavioral”[tiab] OR “cognitive therap*”[tiab] OR CBT[ti] OR “Diabetes Prevention Program”[tiab] OR “Diabetes Prevention Programme”[tiab] OR DPP[tiab] OR (“Diabetes Prevention”[tiab] AND (program*[tiab] OR stud*[tiab] OR trial*[tiab])) OR diet[ti] OR “Diet, Carbohydrate-Restricted”[Mesh] OR “Diet, Fat-Restricted”[Mesh] OR “Diet, Mediterranean”[Mesh] OR “Diet, Reducing”[Mesh] OR “Diet Therapy”[Mesh] OR dietary[ti] OR “Directive Counseling”[Mesh] OR Exercise[Mesh] OR exercise[ti] OR “Exercise Therapy”[Mesh] OR “family intervention*”[tiab] OR “family therap*”[tiab] OR “Feedback, Psychological”[Mesh] OR “group therap*”[tiab] OR “Health Behavior”[Majr] OR “health behavior”[tiab] OR “health behaviors”[tiab] OR “health behavioral”[tiab] “health behaviours”[tiab] OR “health behaviour”[tiab] OR “Health Education”[Mesh] OR “Health Education as Topic”[Mesh] OR “health education”[tiab] OR “Health Promotion”[Majr] OR “health promotion”[tiab] OR “Life Style”[Mesh] OR lifestyle[tiab] OR “life style”[tiab] OR “Lifestyle Intervention”[Mesh] OR “Motivational Interviewing”[Mesh] OR “motivational interviewing”[tiab] OR “non pharmacologic intervention”[tiab] OR “nonpharmacologic intervention”[tiab] OR “parent* intervention*”[tiab] OR “Patient Education as Topic”[Mesh] OR “patient education”[tiab] OR “physical activity”[ti] OR “physically active”[ti] OR “psychological feedback”[tiab] OR “Risk Reduction Behavior”[Mesh] OR “Risk Reduction Behavior”[tiab] OR “Weight Loss”[Mesh] OR “Weight Reduction Programs”[Mesh] | | 507,576
5 | #1 AND #4 | | 19,500
6 | #3 OR #5 | | 41,039
7 | (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) | | 38,332
8 | (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) | English | 34,717
9 | (#6 AND Humans[Mesh:NOEXP]) OR (#6 NOT Animals[Mesh:NOEXP]) | English, Child: birth-18 years | 2,985
10 | adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab] | | 1,766,063
11 | #8 AND #10 | | 1,507
12 | #9 OR #11 | | 3,429
13 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR “retrospective cohort”[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 10,840,629
14 | #12 NOT #13 | | 2,846
15 | #14 NOT (gestation* OR Pregnancy[Mesh]) | | 2,500
16 | “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR (controlled[tiab] AND trial[tiab]) OR groups [tiab] OR placebo [tiab] OR randomised [tiab] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] | | 3,141,667
17 | #15 AND #16 | | 999
18 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta] | | 323,325
19 | #15 AND #18 | | 76
20 | #15 AND “Case-Control Studies”[MeSH] | | 188
21 | #15 AND (“Cohort Studies”[Mesh:NOEXP] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | | 519
22 | #15 AND (“Evaluation Study”[pt] OR “Comparative Study”[pt]) | | 252

### Cochrane Library Screening, 8/3/2020

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] OR [mh “Glucose Tolerance”] OR “glucose tolerance” OR “impaired glucose tolerance” OR dysglycemia:ti,ab OR IGT OR “impaired fasting glucose” OR IFG OR [mh “Glucose Intolerance”] OR “glucose intolerance” OR [mh “Prediabetic State”] OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” | 34233
#2 | [mh “Blood Glucose”] OR “blood glucose”:ti,ab OR [mh “Glucose Tolerance Test”] OR OGTT:ti,ab OR “glucose tolerance test”:ti OR [mh “Glycated Hemoglobin A”] OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose”:ti,ab OR “oral glucose tolerance”:ti,ab | 45778
#3 | #1 AND #2 | 19244
#4 | [mh “Mass Screening”] OR screen*:ti,ab | 67390
#5 | #3 AND #4 | 1702
#6 | #5 NOT (gestation* OR [mh Pregnancy]) | 1521
#7 | adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child*:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR pediatric:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage:ti,ab,kw OR teenaged:ti,ab,kw OR teenager*:ti,ab,kw OR toddler*:ti,ab,kw | 248461
#8 | #6 AND #7 | 197

### Cochrane Library Interventions, 8/3/2020

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] OR [mh “Glucose Tolerance”] OR “glucose tolerance” OR “impaired glucose tolerance” OR dysglycemia:ti,ab OR IGT OR “impaired fasting glucose” OR IFG OR [mh “Glucose Intolerance”] OR “glucose intolerance” OR [mh “Prediabetic State”] OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” | 34233
#2 | Actos:ti,ab OR Albiglutide:ti,ab OR Amaryl:ti,ab OR [mh Biguanides] OR Biguanides:ti,ab OR Bydureon:ti,ab OR Byetta:ti,ab OR DiaBeta:ti,ab OR [mh “Dipeptidyl-Peptidase IV Inhibitors”] OR “Dipeptidyl peptidase IV inhibitor”:ti,ab OR “Dipeptidyl peptidase IV inhibitors”:ti,ab OR dulaglutide:ti,ab OR Exenatide:ti,ab OR Fortamet:ti,ab OR [mh Gliclazide] OR Gliclazide:ti,ab OR glimepiride:ti,ab OR [mh Glipizide] OR glipizide:ti,ab OR “GLP-1 receptor agonist”:ti,ab OR “GLP-1 receptor agonists”:ti,ab OR “Glucagon-like peptide-1 receptor agonist”:ti,ab OR “Glucagon-like peptide-1 receptor agonists”:ti,ab OR Glucophage:ti,ab OR Glucotrol:ti,ab OR “Glucotrol XL”:ti,ab OR Glumetza:ti,ab OR [mh Glyburide] OR glyburide:ti,ab OR “Glynase PresTab”:ti,ab OR [mh Linagliptin] OR Linagliptin:ti,ab OR [mh Liraglutide] OR liraglutide:ti,ab OR lixisenatide:ti,ab OR Lyxumia:ti,ab OR Meglitinides:ti,ab OR [mh Metformin] OR Metformin:ti,ab OR Micronase:ti,ab OR Nateglinide:ti,ab OR Ozempic:ti,ab OR Pioglitazone:ti,ab OR Prandin:ti,ab OR Repaglinide:ti,ab OR Rosiglitazone:ti,ab OR Saxagliptin:ti,ab OR semaglutide:ti,ab OR Sitagliptin:ti,ab OR [mh “Sitagliptin Phosphate”] OR [mh “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”] OR [mh “Sulfonylurea Compounds”] OR Starlix:ti,ab OR Sulfonylureas:ti,ab OR Tanzeum:ti,ab OR [mh Thiazolidinediones] OR Thiazolidinediones:ti,ab OR [mh Tolazamide] OR Tolazamide:ti,ab OR [mh Tolbutamide] OR tolbutamide:ti,ab OR Trulicity:ti,ab OR TZDs:ti,ab OR Victoza:ti,ab OR vildagliptin:ti,ab | 21765
#3 | #1 AND #2 | 9227
#4 | advice:ti,ab OR [mh “Behavior Therapy”] OR “behavior therapy”:ti,ab OR (behavior*:ti,ab AND therap*:ti,ab) OR (behavior*:ti,ab AND chang*:ti,ab) OR (behavior*:ti,ab AND modification*:ti,ab) OR [mh “Caloric Restriction”] OR ((child*:ti,ab AND parent*:ti,ab) and therap*:ti,ab) OR [mh Counseling] OR counsel*:ti,ab OR “cognitive behavior”:ti,ab OR “cognitive behavioral”:ti,ab OR “cognitive therap*”:ti,ab OR CBT:ti OR “Diabetes Prevention Program”:ti,ab OR “Diabetes Prevention Programme”:ti,ab OR DPP:ti,ab OR (“Diabetes Prevention”:ti,ab AND (program*:ti,ab OR stud*:ti,ab OR trial*:ti,ab)) OR diet:ti OR [mh “Diet, Carbohydrate-Restricted”] OR [mh “Diet, Fat-Restricted”] OR [mh “Diet, Mediterranean”] OR [mh “Diet, Reducing”] OR [mh “Diet Therapy”] OR dietary:ti OR [mh “Directive Counseling”] OR [mh Exercise] OR exercise:ti OR [mh “Exercise Therapy”] OR “family intervention*”:ti,ab OR “family therap*”:ti,ab OR [mh “Feedback, Psychological”] OR “group therap*”:ti,ab OR [mh ^”Health Behavior”] OR “health behavior”:ti,ab OR “health behaviors”:ti,ab OR “health behavioral”:ti,ab “health behaviours”:ti,ab OR “health behaviour”:ti,ab OR [mh “Health Education”] OR [mh “Health Education as Topic”] OR “health education”:ti,ab OR [mh ^”Health Promotion”] OR “health promotion”:ti,ab OR [mh “Life Style”] OR lifestyle:ti,ab OR “life style”:ti,ab OR [mh “Lifestyle Intervention”] OR [mh “Motivational Interviewing”] OR “motivational interviewing”:ti,ab OR “non pharmacologic intervention”:ti,ab OR “nonpharmacologic intervention”:ti,ab OR “parent* intervention*”:ti,ab OR [mh “Patient Education as Topic”] OR “patient education”:ti,ab OR “physical activity”:ti OR “physically active”:ti OR “psychological feedback”:ti,ab OR [mh “Risk Reduction Behavior”] OR “Risk Reduction Behavior”:ti,ab OR [mh “Weight Loss”] OR [mh “Weight Reduction Programs”] | 181889
#5 | #1 AND #4 | 8940
#6 | #3 OR #5 | 16313
#7 | #6 NOT ([mh animals] NOT [mh humans]) | 16313
#8 | adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child*:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR pediatric:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage:ti,ab,kw OR teenaged:ti,ab,kw OR teenager*:ti,ab,kw OR toddler*:ti,ab,kw | 248461
#9 | #7 AND #8 | 1360
#10 | #9 NOT (gestation* OR [mh Pregnancy]) | 1162

### PubMed Interventions Addendum #1, 8/4/2020

Search Number | Query | Filters | Results
1 | “Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Tolerance”[Mesh] OR “glucose tolerance”[All Fields] OR “impaired glucose tolerance”[All Fields] OR dysglycemia[tiab] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields] | | 213,453
2 | advice[tiab] OR “Behavior Therapy”[Mesh] OR “behavior therapy”[tiab] OR (behavior*[tiab] AND therap*[tiab]) OR (behavior*[tiab] AND chang*[tiab]) OR (behavior*[tiab] AND modification*[tiab]) OR “Caloric Restriction”[Mesh] OR ((child*[tiab] AND parent*[tiab]) and therap*[tiab]) OR Counseling[Mesh] OR counsel*[tiab] OR “cognitive behavior”[tiab] OR “cognitive behavioral”[tiab] OR “cognitive therap*”[tiab] OR CBT[ti] OR “Diabetes Prevention Program”[tiab] OR “Diabetes Prevention Programme”[tiab] OR DPP[tiab] OR (“Diabetes Prevention”[tiab] AND (program*[tiab] OR stud*[tiab] OR trial*[tiab])) OR diet[ti] OR “Diet, Carbohydrate-Restricted”[Mesh] OR “Diet, Fat-Restricted”[Mesh] OR “Diet, Mediterranean”[Mesh] OR “Diet, Reducing”[Mesh] OR “Diet Therapy”[Mesh] OR dietary[ti] OR “Directive Counseling”[Mesh] OR Exercise[Mesh] OR exercise[ti] OR “Exercise Therapy”[Mesh] OR “family intervention*”[tiab] OR “family therap*”[tiab] OR “Feedback, Psychological”[Mesh] OR “group therap*”[tiab] OR “Health Behavior”[Majr] OR “health behavior”[tiab] OR “health behaviors”[tiab] OR “health behavioral”[tiab] OR “health behaviours”[tiab] OR “health behaviour”[tiab] OR “Health Education”[Mesh] OR “Health Education as Topic”[Mesh] OR “health education”[tiab] OR “Health Promotion”[Majr] OR “health promotion”[tiab] OR “Life Style”[Mesh] OR lifestyle[tiab] OR “life style”[tiab] OR “Lifestyle Intervention”[Mesh] OR “Motivational Interviewing”[Mesh] OR “motivational interviewing”[tiab] OR “non pharmacologic intervention”[tiab] OR “nonpharmacologic intervention”[tiab] OR “parent* intervention*”[tiab] OR “Patient Education as Topic”[Mesh] OR “patient education”[tiab] OR “physical activity”[ti] OR “physically active”[ti] OR “psychological feedback”[tiab] OR “Risk Reduction Behavior”[Mesh] OR “Risk Reduction Behavior”[tiab] OR “Weight Loss”[Mesh] OR “Weight Reduction Programs”[Mesh] | | 1,475,119
3 | #1 AND #2 | | 37,820
4 | (#3 AND Humans[Mesh:NOEXP]) OR (#3 NOT Animals[Mesh:NOEXP]) | | 33,767
5 | (#3 AND Humans[Mesh:NOEXP]) OR (#3 NOT Animals[Mesh:NOEXP]) | English | 31,056
6 | (#3 AND Humans[Mesh:NOEXP]) OR (#3 NOT Animals[Mesh:NOEXP]) | English, Child: birth-18 years | 3,077
7 | adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab] | | 1,766,520
8 | #5 AND #7 | | 1,778
9 | #6 OR #8 | | 3,617
10 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR “retrospective cohort”[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 10,842,788
11 | #9 NOT #10 | | 2,978
12 | #11 NOT (gestation* OR Pregnancy[Mesh]) | | 2,547
13 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta] | | 323,538
14 | #12 AND #13 | | 88
15 | “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR (controlled[tiab] AND trial[tiab]) OR groups [tiab] OR placebo [tiab] OR randomised [tiab] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] | | 3,142,672
16 | #12 AND #15 | | 918
17 | #12 AND “Case-Control Studies”[MeSH] | | 165
18 | #12 AND (“Cohort Studies”[Mesh:NOEXP] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | | 496
19 | #12 AND (“Evaluation Study”[pt] OR “Comparative Study”[pt]) | | 224

### Cochrane Library Interventions Addendum #1, 8/4/2020

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] OR [mh “Glucose Tolerance”] OR “glucose tolerance” OR “impaired glucose tolerance” OR dysglycemia:ti,ab OR IGT OR “impaired fasting glucose” OR IFG OR [mh “Glucose Intolerance”] OR “glucose intolerance” OR [mh “Prediabetic State”] OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” | 34233
#2 | advice:ti,ab OR [mh “Behavior Therapy”] OR “behavior therapy”:ti,ab OR (behavior*:ti,ab AND therap*:ti,ab) OR (behavior*:ti,ab AND chang*:ti,ab) OR (behavior*:ti,ab AND modification*:ti,ab) OR [mh “Caloric Restriction”] OR ((child*:ti,ab AND parent*:ti,ab) and therap*:ti,ab) OR [mh Counseling] OR counsel*:ti,ab OR “cognitive behavior”:ti,ab OR “cognitive behavioral”:ti,ab OR “cognitive therap*”:ti,ab OR CBT:ti OR “Diabetes Prevention Program”:ti,ab OR “Diabetes Prevention Programme”:ti,ab OR DPP:ti,ab OR (“Diabetes Prevention”:ti,ab AND (program*:ti,ab OR stud*:ti,ab OR trial*:ti,ab)) OR diet:ti OR [mh “Diet, Carbohydrate-Restricted”] OR [mh “Diet, Fat-Restricted”] OR [mh “Diet, Mediterranean”] OR [mh “Diet, Reducing”] OR [mh “Diet Therapy”] OR dietary:ti OR [mh “Directive Counseling”] OR [mh Exercise] OR exercise:ti OR [mh “Exercise Therapy”] OR “family intervention*”:ti,ab OR “family therap*”:ti,ab OR [mh “Feedback, Psychological”] OR “group therap*”:ti,ab OR [mh ^”Health Behavior”] OR “health behavior”:ti,ab OR “health behaviors”:ti,ab OR “health behavioral”:ti,ab OR “health behaviours”:ti,ab OR “health behaviour”:ti,ab OR [mh “Health Education”] OR [mh “Health Education as Topic”] OR “health education”:ti,ab OR [mh ^”Health Promotion”] OR “health promotion”:ti,ab OR [mh “Life Style”] OR lifestyle:ti,ab OR “life style”:ti,ab OR [mh “Lifestyle Intervention”] OR [mh “Motivational Interviewing”] OR “motivational interviewing”:ti,ab OR “non pharmacologic intervention”:ti,ab OR “nonpharmacologic intervention”:ti,ab OR “parent* intervention*”:ti,ab OR [mh “Patient Education as Topic”] OR “patient education”:ti,ab OR “physical activity”:ti OR “physically active”:ti OR “psychological feedback”:ti,ab OR [mh “Risk Reduction Behavior”] OR “Risk Reduction Behavior”:ti,ab OR [mh “Weight Loss”] OR [mh “Weight Reduction Programs”] | 181924
#3 | #1 AND #2 | 8941
#4 | #3 NOT ([mh animals] NOT [mh humans]) | 8941
#5 | adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child*:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR pediatric:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage:ti,ab,kw OR teenaged:ti,ab,kw OR teenager*:ti,ab,kw OR toddler*:ti,ab,kw | 248464
#6 | #4 AND #5 | 844
#7 | #6 NOT (gestation* OR [mh Pregnancy]) | 700

### PubMed Interventions Addendum #2, 8/19/2020

Search Number | Query | Filters | Results
1 | “Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Tolerance”[Mesh] OR “Glucose Intolerance”[MeSH] OR “Prediabetic State”[MeSH] | | 143,540
2 | (“diabetes mellitus type 2”[All Fields] OR dysglycemia[tiab] OR “glucose tolerance”[All Fields] OR “glucose intolerance”[All Fields] OR IGT OR “impaired fasting glucose” OR IFG OR “impaired glucose tolerance”[All Fields] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “type 2 diabetes mellitus”[All Fields]) NOT (Medline[sb]) | | 17,008
3 | #1 OR #2 | | 160,548
5 | #3 NOT (“Diabetes Mellitus, Type 1”[Mesh] OR “diabetes mellitus type 1” OR “type 1 diabetes”) | | 143,845
6 | (hypoglycemic agents[mh] OR “Hypoglycemic Agents” [Pharmacological Action]) OR (“hypoglycemic agent*”[tiab] NOT Medline[sb]) | | 259,681
7 | #5 AND #6 | | 41,304
8 | (Insulin[Mesh] OR “Insulin, Long-Acting”[Mesh] OR “Insulin, Isophane”[Mesh] OR “Insulin Glargine”[Mesh]) OR (insulin[tiab] NOT medline[sb]) | | 219,909
9 | #5 AND #8 | | 28,029
10 | #7 OR #9 | | 47,259
11 | (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) | | 42,806
12 | (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) | English | 39,189
13 | (#10 AND Humans[Mesh:NOEXP]) OR (#10 NOT Animals[Mesh:NOEXP]) | English, Child: birth-18 years | 1,942
14 | (adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab]) NOT Medline[sb] | | 203,552
15 | #12 AND #14 | | 305
16 | #13 OR #15 | | 2,247
17 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR “retrospective cohort”[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 10,860,747
18 | #16 NOT #17 | | 1,767
19 | #15 NOT (gestation* OR Pregnancy[Mesh]) | | 265
20 | “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR (controlled[tiab] AND trial[tiab]) OR groups [tiab] OR placebo [tiab] OR randomised [tiab] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] | | 3,151,828
21 | #19 AND #20 | | 77
22 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta] | | 325,513
23 | #19 AND #22 | | 10
24 | #19 AND “Case-Control Studies”[MeSH] | | 0
25 | #19 AND (“Cohort Studies”[Mesh:NOEXP] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | | 7
26 | #19 AND (“Evaluation Study”[pt] OR “Comparative Study”[pt]) | | 0

### Cochrane Library Interventions Addendum #2, 8/20/2020

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] OR [mh “Glucose Tolerance”] OR “glucose tolerance” OR “impaired glucose tolerance” OR dysglycemia:ti,ab OR IGT OR “impaired fasting glucose” OR IFG OR [mh “Glucose Intolerance”] OR “glucose intolerance” OR [mh “Prediabetic State”] OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” | 34234
#2 | #1 NOT ([mh “Diabetes Mellitus, Type 1”] OR “diabetes mellitus type 1”:ti,ab,kw OR “type 1 diabetes”:ti,ab,kw) | 33099
#3 | [mh “hypoglycemic agents”] OR “hypoglycemic agent*”:ti,ab,kw | 8175
#4 | #2 AND #3 | 5220
#5 | [mh Insulin] OR [mh “Insulin, Long-Acting”] OR [mh “Insulin, Isophane”] OR [mh “Insulin Glargine”] OR insulin:ti,ab,kw | 58978
#6 | #2 AND #5 | 18697
#7 | #4 OR #6 | 20183
#8 | adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child*:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR pediatric:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage:ti,ab,kw OR teenaged:ti,ab,kw OR teenager*:ti,ab,kw OR toddler*:ti,ab,kw | 248470
#9 | #7 AND #8 | 1492
#10 | #9 NOT (gestation* OR [mh Pregnancy]) | 1322

### PubMed Interventions Addendum #3, 5/3/2021

Search Number | Query | Filters | Results
1 | “Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Intolerance”[MeSH] OR “Prediabetic State”[MeSH] | | 150,744
2 | (“diabetes mellitus type 2”[All Fields] OR dysglycemia[tiab] OR “glucose tolerance”[All Fields] OR “glucose intolerance”[All Fields] OR IGT OR “impaired fasting glucose” OR IFG OR “impaired glucose tolerance”[All Fields] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “type 2 diabetes mellitus”[All Fields]) NOT (Medline[sb]) | | 18,860
3 | #1 OR #2 | | 169,604
4 | #3 NOT (“Diabetes Mellitus, Type 1”[Mesh] OR “diabetes mellitus type 1” OR “type 1 diabetes”) | | 152,347
5 | (hypoglycemic agents[mh] OR “Hypoglycemic Agents” [Pharmacological Action]) OR (“hypoglycemic agent*”[tiab] NOT Medline[sb]) | | 266,210
6 | #4 AND #5 | | 43,303
7 | (Insulin[Mesh] OR “Insulin, Long-Acting”[Mesh] OR “Insulin, Isophane”[Mesh] OR “Insulin Glargine”[Mesh]) OR (insulin[tiab] NOT medline[sb]) | | 225,745
8 | #4 AND #7 | | 29,218
9 | #6 OR #8 | | 49,756
10 | (#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP]) | | 45,102
11 | (#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP]) | English | 41,438
12 | (#9 AND Humans[Mesh:NOEXP]) OR (#9 NOT Animals[Mesh:NOEXP]) | English, Child: birth-18 years | 2,019
13 | #11 AND ((adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab]) NOT Medline[sb]) | | 316
14 | #12 NOT #13 | | 2,019
15 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR “retrospective cohort”[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 11,199,555
16 | #14 NOT #15 | | 1,608
17 | #16 NOT (gestation* OR Pregnancy[Mesh]) | | 1,461
18 | “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR (controlled[tiab] AND trial[tiab]) OR groups [tiab] OR placebo [tiab] OR randomised [tiab] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] | | 3,313,682
19 | #17 AND #18 | | 712
20 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta] | | 362,198
21 | #17 AND #20 | | 32
22 | #17 AND “Case-Control Studies”[MeSH] | | 176
23 | #17 AND (“Cohort Studies”[Mesh:NOEXP] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | | 397
24 | #17 AND (“Evaluation Study”[pt] OR “Comparative Study”[pt]) | | 198

### PubMed Screening, 5/3/2021

Search Number | Query | Filters | Results
1 | “Diabetes Mellitus, Type 2”[Mesh] OR “glucose tolerance”[All Fields] OR “impaired glucose tolerance”[All Fields] OR dysglycemia[tiab] OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance”[MeSH] OR “glucose intolerance”[All Fields] OR “Prediabetic State”[MeSH] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “diabetes mellitus type 2”[All Fields] OR “type 2 diabetes mellitus”[All Fields] | | 224,878
2 | “Blood Glucose”[Mesh] OR “blood glucose”[tiab] OR “Glucose Tolerance Test”[Mesh] OR OGTT[tiab] OR “glucose tolerance test”[ti] OR “Glycated Hemoglobin A”[Mesh] OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose”[tiab] OR “oral glucose tolerance”[tiab] | | 264,030
3 | #1 AND #2 | | 101,723
4 | #3 NOT (“Diabetes Mellitus, Type 1”[Mesh] OR “diabetes mellitus type 1” OR “type 1 diabetes”) | | 94,239
5 | #4 AND (“Mass Screening”[Mesh] OR screen*[tiab]) | | 6,345
6 | #5 NOT (gestation* OR Pregnancy[Mesh]) | | 4,617
7 | #5 NOT (gestation* OR Pregnancy[Mesh]) | English | 4,272
8 | #5 NOT (gestation* OR Pregnancy[Mesh]) | English, Child: birth-18 years | 605
9 | adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab] | | 1,850,962
10 | #7 AND #9 | | 301
11 | #8 OR #10 | | 665
12 | (#11 AND Humans[mesh:noexp]) OR (#11 NOT Animals[mesh:noexp]) | | 664
13 | (#11 AND Humans[mesh:noexp]) OR (#11 NOT Animals[mesh:noexp]) | from 2019/8/3 - 3000/12/12 | 60
14 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta] | | 362,198
15 | #13 AND #14 | | 2
16 | “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR (controlled[tiab] AND trial[tiab]) OR groups [tiab] OR placebo [tiab] OR randomised [tiab] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] | | 3,313,682
17 | #13 AND #16 | | 19
18 | #13 AND “Case-Control Studies”[MeSH] | | 5
19 | “Cohort Studies”[Mesh] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) | | 2,694,511
20 | #13 AND #19 | | 21
21 | “Evaluation Study”[pt] OR “Comparative Study”[pt] | | 2,087,906
22 | #13 AND #21 | | 0

### PubMed Interventions, 5/3/2021

Search Number | Query | Filters | Results
1 | “Diabetes Mellitus, Type 2”[Mesh] OR “Glucose Intolerance”[MeSH] OR “Prediabetic State”[MeSH] | | 150,744
2 | (“diabetes mellitus type 2”[All Fields] OR dysglycemia[tiab] OR “glucose tolerance”[All Fields] OR “glucose intolerance”[All Fields] OR IGT OR “impaired fasting glucose” OR IFG OR “impaired glucose tolerance”[All Fields] OR “prediabetic state”[All Fields] OR prediabet* OR “pre diabetes”[All Fields] OR “type 2 diabetes mellitus”[All Fields]) NOT (Medline[sb]) | | 18,860
3 | #1 OR #2 | | 169,604
4 | #3 NOT (“Diabetes Mellitus, Type 1”[Mesh] OR “diabetes mellitus type 1” OR “type 1 diabetes”) | | 152,347
5 | (hypoglycemic agents[mh] OR “Hypoglycemic Agents” [Pharmacological Action]) OR (“hypoglycemic agent*”[tiab] NOT Medline[sb]) | | 266,210
6 | #4 AND #5 | | 43,303
7 | (Insulin[Mesh] OR “Insulin, Long-Acting”[Mesh] OR “Insulin, Isophane”[Mesh] OR “Insulin Glargine”[Mesh]) OR (insulin[tiab] NOT medline[sb]) | | 225,745
8 | #4 AND #7 | | 29,218
9 | Actos[tiab] OR Albiglutide[tiab] OR Amaryl[tiab] OR Biguanides[Mesh] OR Biguanides[tiab] OR Bydureon[tiab] OR Byetta[tiab] OR DiaBeta[tiab] OR “Dipeptidyl-Peptidase IV Inhibitors”[Mesh] OR “Dipeptidyl-Peptidase IV Inhibitors”[Pharmacological Action] OR “Dipeptidyl peptidase IV inhibitor”[tiab] OR “Dipeptidyl peptidase IV inhibitors”[tiab] OR dulaglutide[Supplementary Concept] OR dulaglutide[tiab] OR exenatide[Supplementary Concept] OR Exenatide[tiab] OR Fortamet[tiab] OR Gliclazide[Mesh] OR Gliclazide[tiab] OR glimepiride[tiab] OR Glipizide[Mesh] OR glipizide[tiab] OR “GLP-1 receptor agonist”[tiab] OR “GLP-1 receptor agonists”[tiab] OR “Glucagon-like peptide-1 receptor agonist”[tiab] OR “Glucagon-like peptide-1 receptor agonists”[tiab] OR Glucophage[tiab] OR Glucotrol[tiab] OR “Glucotrol XL”[tiab] OR Glumetza[tiab] OR Glyburide[Mesh] OR glyburide[tiab] OR “Glynase PresTab”[tiab] OR Linagliptin[Mesh] OR Linagliptin[tiab] OR Liraglutide[Mesh] OR liraglutide[tiab] OR lixisenatide[Supplementary Concept] OR lixisenatide[tiab] OR Lyxumia[tiab] OR Meglitinides[tiab] OR Metformin[Mesh] OR Metformin[tiab] OR Micronase[tiab] OR nateglinide[Supplementary Concept] OR Nateglinide[tiab] OR Ozempic[tiab] OR pioglitazone[Supplementary Concept] OR Pioglitazone[tiab] OR Prandin[tiab] OR Repaglinide[tiab] OR rosiglitazone[Supplementary Concept] OR Rosiglitazone[tiab] OR Saxagliptin[tiab] OR semaglutide[Supplementary Concept] OR semaglutide[tiab] OR Sitagliptin[tiab] OR “Sitagliptin Phosphate”[Mesh] OR “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”[Mesh] OR “Sulfonylurea Compounds”[Mesh] OR Starlix[tiab] OR Sulfonylureas[tiab] OR Tanzeum[tiab] OR Thiazolidinediones[Mesh] OR Thiazolidinediones[tiab] OR Tolazamide[Mesh] OR Tolazamide[tiab] OR Tolbutamide[Mesh] OR tolbutamide[tiab] OR Trulicity[tiab] OR TZDs[tiab] OR Victoza[tiab] OR vildagliptin[Supplementary Concept] OR vildagliptin[tiab] | | 82,627
10 | #4 AND #9 | | 20,543
11 | advice[tiab] OR “Behavior Therapy”[Mesh] OR “behavior therapy”[tiab] OR (behavior*[tiab] AND therap*[tiab]) OR (behavior*[tiab] AND chang*[tiab]) OR (behavior*[tiab] AND modification*[tiab]) OR “Caloric Restriction”[Mesh] OR ((child*[tiab] AND parent*[tiab]) and therap*[tiab]) OR Counseling[Mesh] OR counsel*[tiab] OR “cognitive behavior”[tiab] OR “cognitive behavioral”[tiab] OR “cognitive therap*”[tiab] OR CBT[ti] OR “Diabetes Prevention Program”[tiab] OR “Diabetes Prevention Programme”[tiab] OR DPP[tiab] OR (“Diabetes Prevention”[tiab] AND (program*[tiab] OR stud*[tiab] OR trial*[tiab])) OR diet[ti] OR “Diet, Carbohydrate-Restricted”[Mesh] OR “Diet, Fat-Restricted”[Mesh] OR “Diet, Mediterranean”[Mesh] OR “Diet, Reducing”[Mesh] OR “Diet Therapy”[Mesh] OR dietary[ti] OR “Directive Counseling”[Mesh] OR Exercise[Mesh] OR exercise[ti] OR “Exercise Therapy”[Mesh] OR “family intervention*”[tiab] OR “family therap*”[tiab] OR “Feedback, Psychological”[Mesh] OR “group therap*”[tiab] OR “Health Behavior”[Majr] OR “health behavior”[tiab] OR “health behaviors”[tiab] OR “health behavioral”[tiab] OR “health behaviours”[tiab] OR “health behaviour”[tiab] OR “Health Education”[Mesh] OR “health education”[tiab] OR “Health Promotion”[Majr] OR “health promotion”[tiab] OR “Life Style”[Mesh] OR lifestyle[tiab] OR “life style”[tiab] OR “Motivational Interviewing”[Mesh] OR “motivational interviewing”[tiab] OR “non pharmacologic intervention”[tiab] OR “nonpharmacologic intervention”[tiab] OR “parent* intervention*”[tiab] OR “Patient Education as Topic”[Mesh] OR “patient education”[tiab] OR “physical activity”[ti] OR “physically active”[ti] OR “psychological feedback”[tiab] OR “Risk Reduction Behavior”[Mesh] OR “Risk Reduction Behavior”[tiab] OR “Weight Loss”[Mesh] OR “Weight Reduction Programs”[Mesh] | | 1,544,095
12 | #4 AND #11 | | 30,288
13 | #6 OR #8 OR #10 OR #12 | | 72,197
14 | (#13 AND Humans[Mesh:NOEXP]) OR (#13 NOT Animals[Mesh:NOEXP]) | | 66,506
15 | (#13 AND Humans[Mesh:NOEXP]) OR (#13 NOT Animals[Mesh:NOEXP]) | English | 61,430
16 | (#13 AND Humans[Mesh:NOEXP]) OR (#13 NOT Animals[Mesh:NOEXP]) | Child: birth-18 years | 3,828
17 | (adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab]) NOT Medline[sb] | | 225,420
18 | #14 AND #17 | | 436
19 | #16 OR #18 | | 4,264
20 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “cross-sectional”[tw] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR “retrospective cohort”[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 11,199,555
21 | #19 NOT #20 | | 3,636
22 | #21 NOT (gestation* OR Pregnancy[Mesh]) | | 3,009
23 | #21 NOT (gestation* OR Pregnancy[Mesh]) | from 2019/8/3 - 3000/12/12 | 316
24 | “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH] OR (controlled[tiab] AND trial[tiab]) OR groups [tiab] OR placeb o [tiab] OR randomised [tiab] OR randomized [tiab] OR randomly [tiab] OR trial [tiab] | | 3,313,682
25 | #23 AND #24 | | 139
26 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] OR “meta synthesis”[ti] OR “systematic literature review”[ti] OR “this systematic review”[tw] OR “cochrane database syst rev”[ta] | | 362,198
27 | #23 AND #26 | | 16
28 | #23 AND “Case-Control Studies”[MeSH] | | 24
29 | #23 AND (“Cohort Studies”[Mesh:NOEXP] OR “Epidemiologic Studies”[Mesh] OR “Follow-up Studies”[Mesh] OR “prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields]))) | | 71
30 | #23 AND (“Evaluation Study”[pt] OR “Comparative Study”[pt]) | | 11

### Cochrane Library Screening, 5/3/2021

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] OR “glucose tolerance” OR “impaired glucose tolerance” OR dysglycemia:ti,ab OR IGT OR “impaired fasting glucose” OR IFG OR [mh “Glucose Intolerance”] OR “glucose intolerance” OR [mh “Prediabetic State”] OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” | 36248
#2 | [mh “Blood Glucose”] OR “blood glucose”:ti,ab OR [mh “Glucose Tolerance Test”] OR OGTT:ti,ab OR “glucose tolerance test”:ti OR [mh “Glycated Hemoglobin A”] OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose”:ti,ab OR “oral glucose tolerance”:ti,ab | 48756
#3 | #1 AND #2 | 20381
#4 | [mh “Mass Screening”] OR screen*:ti,ab | 73937
#5 | #3 AND #4 | 1840
#6 | #5 NOT (gestation* OR [mh Pregnancy]) | 1645
#7 | adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child*:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR pediatric:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage:ti,ab,kw OR teenaged:ti,ab,kw OR teenager*:ti,ab,kw OR toddler*:ti,ab,kw | 289615
#8 | #6 AND #7 | 213
#9 | #8 with Cochrane Library publication date Between Aug 2019 and Dec 2021 | 41
#10 | #9 NOT ([mh “Diabetes Mellitus, Type 1”] OR “diabetes mellitus type 1”:ti,ab,kw OR “type 1 diabetes”:ti,ab,kw) | 38

### Cochrane Library Interventions, 5/3/2021

ID | Search | Hits
#1 | [mh “Diabetes Mellitus, Type 2”] OR “glucose tolerance” OR “impaired glucose tolerance” OR dysglycemia:ti,ab OR IGT OR “impaired fasting glucose” OR IFG OR [mh “Glucose Intolerance”] OR “glucose intolerance” OR [mh “Prediabetic State”] OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” | 36248
#2 | #1 NOT ([mh “Diabetes Mellitus, Type 1”] OR “diabetes mellitus type 1”:ti,ab,kw OR “type 1 diabetes”:ti,ab,kw) | 35092
#3 | Actos:ti,ab OR Albiglutide:ti,ab OR Amaryl:ti,ab OR [mh Biguanides] OR Biguanides:ti,ab OR Bydureon:ti,ab OR Byetta:ti,ab OR DiaBeta:ti,ab OR [mh “Dipeptidyl-Peptidase IV Inhibitors”] OR “Dipeptidyl peptidase IV inhibitor”:ti,ab OR “Dipeptidyl peptidase IV inhibitors”:ti,ab OR dulaglutide:ti,ab OR Exenatide:ti,ab OR Fortamet:ti,ab OR [mh Gliclazide] OR Gliclazide:ti,ab OR glimepiride:ti,ab OR [mh Glipizide] OR glipizide:ti,ab OR “GLP-1 receptor agonist”:ti,ab OR “GLP-1 receptor agonists”:ti,ab OR “Glucagon-like peptide-1 receptor agonist”:ti,ab OR “Glucagon-like peptide-1 receptor agonists”:ti,ab OR Glucophage:ti,ab OR Glucotrol:ti,ab OR “Glucotrol XL”:ti,ab OR Glumetza:ti,ab OR [mh Glyburide] OR glyburide:ti,ab OR “Glynase PresTab”:ti,ab OR [mh Linagliptin] OR Linagliptin:ti,ab OR [mh Liraglutide] OR liraglutide:ti,ab OR lixisenatide:ti,ab OR Lyxumia:ti,ab OR Meglitinides:ti,ab OR [mh Metformin] OR Metformin:ti,ab OR Micronase:ti,ab OR Nateglinide:ti,ab OR Ozempic:ti,ab OR Pioglitazone:ti,ab OR Prandin:ti,ab OR Repaglinide:ti,ab OR Rosiglitazone:ti,ab OR Saxagliptin:ti,ab OR semaglutide:ti,ab OR Sitagliptin:ti,ab OR [mh “Sitagliptin Phosphate”] OR [mh “Sitagliptin Phosphate, Metformin Hydrochloride Drug Combination”] OR [mh “Sulfonylurea Compounds”] OR Starlix:ti,ab OR Sulfonylureas:ti,ab OR Tanzeum:ti,ab OR [mh Thiazolidinediones] OR Thiazolidinediones:ti,ab OR [mh Tolazamide] OR Tolazamide:ti,ab OR [mh Tolbutamide] OR tolbutamide:ti,ab OR Trulicity:ti,ab OR TZDs:ti,ab OR Victoza:ti,ab OR vildagliptin:ti,ab | 22966
#4 | #2 AND #3 | 9584
#5 | #2 AND ([mh “hypoglycemic agents”] OR “hypoglycemic agent*”:ti,ab,kw) | 5438
#6 | #2 AND ([mh Insulin] OR [mh “Insulin, Long-Acting”] OR [mh “Insulin, Isophane”] OR [mh “Insulin Glargine”] OR insulin:ti,ab,kw) | 19860
#7 | #4 OR #5 OR #6 | 23813
#8 | advice:ti,ab OR [mh “Behavior Therapy”] OR “behavior therapy”:ti,ab OR (behavior*:ti,ab AND therap*:ti,ab) OR (behavior*:ti,ab AND chang*:ti,ab) OR (behavior*:ti,ab AND modification*:ti,ab) OR [mh “Caloric Restriction”] OR ((child*:ti,ab AND parent*:ti,ab) and therap*:ti,ab) OR [mh Counseling] OR counsel*:ti,ab OR “cognitive behavior”:ti,ab OR “cognitive behavioral”:ti,ab OR “cognitive therap*”:ti,ab OR CBT:ti OR “Diabetes Prevention Program”:ti,ab OR “Diabetes Prevention Programme”:ti,ab OR DPP:ti,ab OR (“Diabetes Prevention”:ti,ab AND (program*:ti,ab OR stud*:ti,ab OR trial*:ti,ab)) OR diet:ti OR [mh “Diet, Carbohydrate-Restricted”] OR [mh “Diet, Fat-Restricted”] OR [mh “Diet, Mediterranean”] OR [mh “Diet, Reducing”] OR [mh “Diet Therapy”] OR dietary:ti OR [mh “Directive Counseling”] OR [mh Exercise] OR exercise:ti OR [mh “Exercise Therapy”] OR “family intervention*”:ti,ab OR “family therap*”:ti,ab OR [mh “Feedback, Psychological”] OR “group therap*”:ti,ab OR [mh ^”Health Behavior”] OR “health behavior”:ti,ab OR “health behaviors”:ti,ab OR “health behavioral”:ti,ab OR “health behaviours”:ti,ab OR “health behaviour”:ti,ab OR [mh “Health Education”] OR “health education”:ti,ab OR [mh ^”Health Promotion”] OR “health promotion”:ti,ab OR [mh “Life Style”] OR lifestyle:ti,ab OR “life style”:ti,ab OR [mh “Motivational Interviewing”] OR “motivational interviewing”:ti,ab OR “non pharmacologic intervention”:ti,ab OR “nonpharmacologic intervention”:ti,ab OR “parent* intervention*”:ti,ab OR [mh “Patient Education as Topic”] OR “patient education”:ti,ab OR “physical activity”:ti OR “physically active”:ti OR “psychological feedback”:ti,ab OR [mh “Risk Reduction Behavior”] OR “Risk Reduction Behavior”:ti,ab OR [mh “Weight Loss”] OR [mh “Weight Reduction Programs”] | 195053
#9 | #1 AND #8 | 9525
#10 | #7 OR #9 | 27598
#11 | #10 NOT (gestation* OR [mh Pregnancy]) | 26684
#12 | #11 NOT ([mh animals] NOT [mh humans]) | 26684
#13 | adolescen*:ti,ab,kw OR boys:ti,ab,kw OR child*:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR infant*:ti,ab,kw OR pediatric:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage:ti,ab,kw OR teenaged:ti,ab,kw OR teenager*:ti,ab,kw OR toddler*:ti,ab,kw | 289615
#14 | #12 AND #13 | 1771
#15 | #14 with Cochrane Library publication date from Aug 2019 to Dec 2021 | 267 (3 are reviews)
#16 | #15 with Publication Year from 2019 to 2021, in Trials | 182

### ClinicalTrials.gov, 5/3/2021

Screening (40 results)

[underlined: Condition box:] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance” OR “Prediabetic State” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”)

AND

[underlined: Other terms box:] (“blood glucose” OR OGTT OR “glucose tolerance test” OR “Glycated Hemoglobin A” OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose” OR “HbA(1c)” OR HbA1 OR HbA1c OR “HbA 1c” OR “glycosylated hemoglobin” OR “glycated hemoglobin” OR “oral glucose tolerance”) AND (screen* OR screening)

Used child limits Age Group Child (birth-17)

[underlined: Expert search:] ((“blood glucose” OR OGTT OR “glucose tolerance test” OR “Glycated Hemoglobin A” OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose” OR “HbA(1c)” OR HbA1 OR HbA1c OR “HbA 1c” OR “glycosylated hemoglobin” OR “glycated hemoglobin” OR “oral glucose tolerance”) AND (screen* OR screening)) AND AREA[ConditionSearch] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance” OR “Prediabetic State” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] “Child”

### Interventions (integrates terms for hypoglycemic agents and insulin)

A. Pharmacologic Interventions (322 results)

[underlined: Condition box:] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “Prediabetic State” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”)

AND

[underlined: Intervention/treatment box:] (Actos OR Albiglutide OR Amaryl OR Biguanides OR Bydureon OR Byetta OR DiaBeta OR “Dipeptidyl-Peptidase IV Inhibitors” OR “Dipeptidyl peptidase IV inhibitor” OR dulaglutide OR Exenatide OR Fortamet OR Gliclazide OR glimepiride OR Glipizide OR “GLP-1 receptor agonist” OR “GLP-1 receptor agonists” OR “Glucagon-like peptide-1 receptor agonist” OR “Glucagon-like peptide-1 receptor agonists” OR Glucophage OR Glucotrol OR Glumetza OR Glyburide OR “Glynase PresTab” hypoglycemic agent* OR “hypoglycemic agents” OR insulin OR Linagliptin OR Liraglutide OR lixisenatide OR Lyxumia OR Meglitinides OR Metformin OR Micronase OR Ozempic OR Pioglitazone OR Prandin OR Repaglinide OR Rosiglitazone OR Saxagliptin OR semaglutide OR Sitagliptin OR “Sulfonylurea Compounds” OR Starlix OR Sulfonylureas OR Tanzeum OR Thiazolidinediones OR Tolazamide OR Tolbutamide OR Trulicity OR TZDs OR Victoza OR vildagliptin)

Used child limits Age Group Child (birth-17)

[underlined: In Expert Search box:] AREA[ConditionSearch] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “Prediabetic State” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”) AND AREA[InterventionSearch] (Actos OR Albiglutide OR Amaryl OR Biguanides OR Bydureon OR Byetta OR DiaBeta OR “Dipeptidyl-Peptidase IV Inhibitors” OR “Dipeptidyl peptidase IV inhibitor” OR dulaglutide OR Exenatide OR Fortamet OR Gliclazide OR glimepiride OR Glipizide OR “GLP-1 receptor agonist” OR “GLP-1 receptor agonists” OR “Glucagon-like peptide-1 receptor agonist” OR “Glucagon-like peptide-1 receptor agonists” OR Glucophage OR Glucotrol OR Glumetza OR Glyburide OR “Glynase PresTab” hypoglycemic agent* OR “hypoglycemic agents” OR insulin OR Linagliptin OR Liraglutide OR lixisenatide OR Lyxumia OR Meglitinides OR Metformin OR Micronase OR Ozempic OR Pioglitazone OR Prandin OR Repaglinide OR Rosiglitazone OR Saxagliptin OR semaglutide OR Sitagliptin OR “Sulfonylurea Compounds” OR Starlix OR Sulfonylureas OR Tanzeum OR Thiazolidinediones OR Tolazamide OR Tolbutamide OR Trulicity OR TZDs OR Victoza OR vildagliptin) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] “Child”

B. Non-pharmacologic interventions (186 results)

[underlined: Condition box:] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “Prediabetic State” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”)

AND

[underlined: Non-Pharmacological Interventions in Treatment/Interventions box:] (advice OR “Behavior Therapy” OR (behavior* AND therap*) OR (behavior* AND chang*) OR (behavior* AND modification*) OR “Caloric Restriction” OR ((child* AND parent*) and therap*) OR counsel* OR “cognitive behavior” OR “cognitive behavioral” OR “cognitive therap*” OR CBT OR “Diabetes Prevention Program” OR “Diabetes Prevention Programme” OR DPP OR (“Diabetes Prevention” AND (program* OR stud* OR trial*)) OR diet OR dietary OR Exercise OR “family intervention*” OR “family therap*” OR “Feedback, Psychological” OR “group therap*” OR “Health Behavior” OR “health behaviors” OR “health behavioral” OR “health behaviours” OR “health behaviour” OR “health behavioural” OR “Health Education” OR “Health Education as Topic” OR “health education” OR “Health Promotion” OR “health promotion” OR “Life Style” OR lifestyle OR “life style” OR “Lifestyle Intervention” OR “Motivational Interviewing” OR “motivational interviewing” OR “non pharmacologic intervention” OR “nonpharmacologic intervention” OR “parent* intervention*” OR “patient education” OR “physical activity” OR “physically active” OR “psychological feedback” OR “Risk Reduction Behavior” OR “Risk Reduction Behavior” OR “Weight Loss” OR “Weight Reduction Programs”)

Used child limits Age Group Child (birth-17)

[underlined: In Expert Search box:] AREA[ConditionSearch] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “Prediabetic State” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”) AND AREA[InterventionSearch] (advice OR “Behavior Therapy” OR (behavior* AND therap*) OR (behavior* AND chang*) OR (behavior* AND modification*) OR “Caloric Restriction” OR ((child* AND parent*) and therap*) OR counsel* OR “cognitive behavior” OR “cognitive behavioral” OR “cognitive therap*” OR CBT OR “Diabetes Prevention Program” OR “Diabetes Prevention Programme” OR DPP OR (“Diabetes Prevention” AND (program* OR stud* OR trial*)) OR diet OR dietary OR Exercise OR “family intervention*” OR “family therap*” OR “Feedback, Psychological” OR “group therap*” OR “Health Behavior” OR “health behaviors” OR “health behavioral” OR “health behaviours” OR “health behaviour” OR “health behavioural” OR “Health Education” OR “Health Education as Topic” OR “health education” OR “Health Promotion” OR “health promotion” OR “Life Style” OR lifestyle OR “life style” OR “Lifestyle Intervention” OR “Motivational Interviewing” OR “motivational interviewing” OR “non pharmacologic intervention” OR “nonpharmacologic intervention” OR “parent* intervention*” OR “patient education” OR “physical activity” OR “physically active” OR “psychological feedback” OR “Risk Reduction Behavior” OR “Risk Reduction Behavior” OR “Weight Loss” OR “Weight Reduction Programs”) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] “Child”

## Appendix B2 Eligibility Criteria

| Include | Exclude
Populations | All KQs: Studies of people younger than age 18; studies of participants without obvious symptoms of diabetes (e.g., for KQ 1, studies of unselected populations that may include some participants with unrecognized symptoms of diabetes such as fatigue); nonpregnant women with a history of gestational diabetes (if they are >1 year postpartum); studies that substantially overlap this age range (e.g., ages 14–65 years) were eligible if results for younger participants were reported separately. At least 50% of the study population must have met the review eligibility criteria or results must have been reported separately for the population eligible for the review.; KQs 1, 2: Asymptomatic, nonpregnant children and adolescents; KQs 3: Asymptomatic, nonpregnant children and adolescents with screen-detected prediabetes or type 2 diabetes (3a and 3b) or with recently diagnosed type 2 diabetes (3c); studies of people with Maturity Onset Diabetes of the Young (MODY) were also eligible.; KQ 4: Asymptomatic, nonpregnant children and adolescents with screen-detected prediabetes or type 2 diabetes; nonpregnant children and adolescents with recently diagnosed type 2 diabetes; studies of people with MODY were also eligible.; KQs 5–6: Asymptomatic, nonpregnant children and adolescents with screen-detected prediabetes; Specific populations: Studies that examined whether effectiveness of screening or intervention differed based on age, sex, race/ethnicity, BMI, sexual maturity rating, age of menarche, and socioeconomic status were examined. | KQs 1–6: Studies limited to or predominately comprising adults or pregnant women; persons with symptomatic prediabetes or type 2 diabetes (e.g., weight loss, polyuria, blurred vision, headache); persons with a recent hospitalization; persons taking antipsychotics or glucocorticoids; persons with known cardiovascular disease or severe chronic kidney disease; persons living in an institution; other persons with medical conditions limiting their applicability to primary care–based populations (e.g., those with acute illness); KQ 3c: Studies limited to or predominately comprising persons who have had diabetes for more than 1 year or with more advanced diabetes (e.g., persons already taking insulin or other medications; persons with proliferative retinopathy, nephropathy)
Screening | KQs 1, 2: Screening (targeted or universal) for prediabetes^*^ or diabetes; tests include hemoglobin A1c, FPG, and the OGTT | All other tests, such as genetic testing for the risk of prediabetes or diabetes or testing for autoantibodies, which may be used for further evaluation after a diabetes diagnosis (e.g., to assess for type 1 or type 2 diabetes)
Interventions | KQs 3–6: Primary care–relevant behavioral counseling or pharmacotherapy interventions for glycemic control. Behavioral counseling interventions provided alone or as part of a larger multicomponent intervention on diet and nutrition, physical activity, sedentary behavior, or a combination thereof, including but not limited to assessment with feedback, advice, collaborative goal setting, assistance, exercise prescriptions (referral to exercise facility or program), or arrangement of further contacts; Interventions delivered via face-to-face contact, telephone, print materials, or technology (e.g., computer based, text messages, remote video feed) and delivered by a number of potential interventionists, including but not limited to clinicians, nurses, exercise specialists, dietitians, nutritionists, and behavioral health specialists; Dietary counseling may involve:; - Increased consumption of fruits, vegetables, whole grains, fat-free or low-fat dairy, and/or lean proteins; - Limited consumption of sodium, saturated fat, trans fat, and/or sugar-sweetened food and beverages; Physical activity counseling may involve:; - Aerobic activities that involve repeated use of large muscles, such as walking, cycling, and swimming; - Resistance training designed to improve physical strength; - Reduction of sedentary behaviors; - Optional or access to guided physical activity or exercise classes; Limited guided physical activity (i.e., 1 to 2 sessions) or provision of food samples is allowed if intention is to teach or demonstrate healthy lifestyle principles | - Counseling interventions aimed at depression; - Prenatal or postnatal dietary counseling; - Counseling interventions with components that are not feasible for implementation in healthcare settings (e.g., occupational/worksite-, church-, or school-based interventions conducted within existing social networks); - Social marketing (e.g., media campaigns); - Policy (e.g., local or state public/health policy); - Stress management interventions (e.g., meditation, yoga, tai chi); - Use of incentives (e.g., paying persons to lose weight); - Supervised exercise with the goal of assessing effects of exercise; - Dietary counseling solely focused on increasing intake of specific vitamins, micronutrients, herbal supplements, spices (e.g., ginger, cinnamon), or antioxidants through dietary change or supplementation, or counseling on alcohol; - Surgery
Comparisons | KQs 1, 2: No screening or alternative screening strategies; KQ 3a: Comparison based on timing; sooner vs. later intervention (i.e., starting intervention upon detection by screening vs. starting later based on clinical diagnosis); clinical diagnosis refers to any approach based on development of symptoms (e.g., polyuria, polydipsia, paresthesia, vision changes) or monitoring of biomarkers (e.g., increase in hemoglobin A1c above a certain threshold); KQs 3b, 3c: No intervention, placebo, usual care (can include minimal intervention), different treatment targets (e.g., glucose or blood pressure targets), wait-list, or attention control (for lifestyle interventions); KQ 4: All comparisons eligible for KQ 3; KQs 5–6: Sooner vs. later intervention, no intervention, placebo, usual care, wait-list, or attention control (for lifestyle interventions) | Comparative effectiveness (head-to-head) trials of medications or behavioral counseling without another eligible control group
Outcomes | KQs 1, 3, 6: Mortality, cardiovascular morbidity (including myocardial infarction, stroke, congestive heart failure), chronic kidney disease, amputation, skin ulcers, visual impairment (including blindness), periodontitis (including tooth loss), moderate to severe neuropathy, and quality of life; KQ 2: Labeling, anxiety, harms from false-positive results, burden, inconvenience, depression, and unnecessary testing and treatment; KQ 4: Serious side effects from treatment, including gastrointestinal side effects, mortality, myocardial infarction, stroke, cancer, and hypoglycemic events requiring medical attention; burden and inconvenience; KQ 5: Development of type 2 diabetes | KQs 1, 3, 5, 6: Studies with less than 6 months of followup
Study Designs | All KQs: Controlled clinical trials; KQs 2, 4: Controlled prospective cohort studies and case-control studies are also eligible; KQ 6: Controlled prospective cohort studies are also eligible | Modeling studies, systematic reviews,^†^ case series, case reports, uncontrolled observational studies, retrospective cohort studies, editorials, and all other study designs not mentioned
Settings | Studies conducted in or recruited from primary care settings or settings otherwise applicable to primary care, including school-based health centers and other community settings that provide primary care or are referable from primary care (i.e., screening/interventions that could feasibly be implemented in or referred from primary care) | Settings not generalizable to primary care (e.g., inpatient hospital units, emergency departments, nursing home and other institutional settings, school-based curricula or programs that are not referable from primary care, occupational settings)
Countries | Studies conducted in countries categorized as “Very High” on the Human Development Index in the 2019 Human Development Report (as defined by the United Nations Development Programme) | Studies conducted in countries that are categorized as lower than “Very High” on the Human Development Index in the 2019 Human Development Report
Language | English | Languages other than English
Study Quality | Good or Fair | Poor (according to design-specific USPSTF criteria)

* Prediabetes includes individuals who meet criteria for IFG, IGT, and those with an A1c from 5.7 to 6.4 percent.

† Systematic reviews were excluded from the evidence review. However, separate searches were conducted to identify relevant systematic reviews, and the citations of all studies included in those systematic reviews were reviewed to ensure that the database searches have captured all relevant primary studies.

Abbreviations: A1c=glycated hemoglobin; BMI=body mass index; FPG=fasting plasma glucose; IFG=impaired fasting glucose; IGT=impaired glucose tolerance; KQ=key question; MODY=Maturity Onset Diabetes of the Young; OGTT=oral glucose tolerance test; USPSTF=U.S. Preventive Services Task Force.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies will be graded “fair” if any or all of the following problems occur without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.

Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^56^

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

#### Definition of Ratings Based on Above Criteria

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has a fatal flaw, such as uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015 ^56^