# Appendix A Additional Background and Contextual Questions

## Contextual Questions (CQs)

CQ 1 a. What percentage of children and adolescents with prediabetes progress to type 2 diabetes, remain prediabetic or return to normal glycemia or glucose tolerance (without intervention), and over what time frame?
  b. What percentage of children and adolescents with type 2 diabetes return to normal glycemia or glucose tolerance or to the prediabetes range (without intervention), and over what time frame?
  c. How does this differ by baseline hemoglobin (Hb) glycated hemoglobin (A1c) level, fasting glucose level, or glucose tolerance?

Overall, current available studies are limited but suggest that many children and adolescents with prediabetes (22% to 52%) return to normal glycemia or glucose tolerance without intervention over 6 months to 2 years.

A limited number of randomized, controlled trials (RCTs) of prediabetes had control groups that received no intervention, allowing an opportunity to follow those subjects over the course of the study to assess natural history. These studies suggested that a large portion of children and adolescents with prediabetes will remain with prediabetes or revert to normoglycemia over a 2-year period; this pattern appears similar regardless of the method of measuring glycemia or glucose tolerance. The largest of these was the HEALTHY study. This study randomized 21 schools to the control arm, collected baseline metabolic health data on 6^th^ graders, and then collected the same data again 2 years later. Of those with prediabetes at baseline (n=128, HgA1C 5.7-6.4), the 2-year followup assessments revealed that 51 (39.8%) had a normal HgA1c, 76 (59.4%) persisted with prediabetes, and 1 (0.8%) progressed to diabetes. By comparison, of those with A1c <5.7 at baseline (n=3,852), 3,761 (97.6%) remained <5.7 at the 2-year followup, 88 (2.3%) progressed to prediabetes, and 3 (0.1%) progressed to diabetes. Of those with an elevated fasting plasma glucose (FPG) at baseline (100-125 mg/dL, n=635), 330 (52%) regressed to <100 mg/dL at followup, 298 (46.9%) remained between 100-125 mg/dL and 7 (1.1%) progressed to FPG greater than or equal to 126 mg/dL. By comparison, of those with baseline FPG <100 mg/dL (n=3,345), 2,774 (82.9%) remained <100 mg/dL at followup, 567 (17%) progressed to 100-125 mg/dL, and 4 (0.1%) progressed to FPG ≥ 126 mg/dL at followup.^72^ The placebo arm of a small trial of adolescents ages 10 to 16 years who were obese found that the 22 percent (6 of 21) who had oral glucose tolerance test (OGTT) 2-hour blood glucose greater than or equal to 130 at baseline converted to less than 130 at the 6-month followup without intervention.^64^

No identified prospective cohort studies have followed children with prediabetes or diabetes over time to determine what proportion return to normoglycemia without intervention. Two cohort studies followed youth with prediabetes for 2 years and found that 8 percent to 24 percent progressed to type 2 diabetes, while 45 to 65 percent reverted to normal glucose tolerance, but both studies involved some lifestyle intervention for participants.^7,^ ^73^ One of the cohort studies was conducted in an obesity clinic and followed children with prediabetes over 2 years. It provided dietary counseling and evaluation every 5 to 6 months, but it did not have a group who received no intervention. Of 162 adolescents with prediabetes at baseline, 102 (65%) reverted to normal glucose tolerance at 2 years, 44 (27%) had persistent prediabetes, and 13 (8%) progressed to type 2 diabetes.^73^ A similar smaller cohort study in the same obesity clinic followed a subset of children and adolescents with prediabetes over 18 to 24 months, providing biannual nutrition and physical activity counseling. It found that of 33 children and adolescents with prediabetes at baseline, 15 (45.5%) reverted to normal glucose tolerance at followup, 10 (30.3%) maintained prediabetes, and 8 (24.2%) progressed to type 2 diabetes.^7^

One additional cohort study followed American Indian children and adolescents from the southwestern United States from 1965 to 2007.^74^ Of 2,095 children and adolescents ages 10 to 19 years, they identified 62 with prediabetes (HgA1c 5.7-6.4) at baseline and followed them through age 39 years. It is unclear (in the article) whether the children and adolescents received any interventions for obesity or prediabetes during the followup period. The study did not report how many of the 62 children and adolescents with prediabetes went on to develop diabetes, but it did include bar graphs with incidence rates for diabetes cases per 1,000 person-years and bar graphs with rate ratios. Male children with prediabetes (n=13) had a fourfold higher incidence rate of diabetes at followup compared with those with baseline HgA1c of 5.3 or less (n=831), while female children with prediabetes at baseline (n=49) had a sevenfold higher incidence of diabetes than female children with baseline HgA1c of 5.3 or less (n=964). Median time from diagnosis of prediabetes to diabetes or last examination before diabetes developed was 5.2 years. Results were similar for prediabetes as defined by FPG or 2-h postprandial blood glucose.

CQ 2. a Does screening for prediabetes or type 2 diabetes change the intermediate outcomes of HbA1c level, FPG level, 2-hour glucose tolerance test results, subclinical retinopathy, microalbuminuria, or subclinical neuropathy for children and adolescents?

This review identified no studies for CQ 2a.

b Do interventions for children and adolescents with screen-detected or recently diagnosed type 2 diabetes or prediabetes change the intermediate outcomes of HbA1c level, FPG level, 2-hour glucose tolerance test results, subclinical retinopathy, microalbuminuria, or subclinical neuropathy?

### Summary

Among those recently diagnosed with type 2 diabetes, metformin improved glycemia, including A1c and FPG levels, compared with placebo in one trial; rosiglitazone combined with metformin improved glycemic control, as measured by A1c <8 percent and/or need for rescue insulin, compared with metformin alone or metformin and lifestyle in one trial, but only while rosiglitazone was being used (i.e., there was no long-term protective effect from prior use); liraglutide combined with metformin resulted in improved glycemia, as measured by A1c and FPG, compared with metformin and placebo in one trial. Among those with prediabetes, lifestyle improved 2-h glucose, but not fasting glucose or A1c, compared with usual care in one trial; data on rosiglitazone were inconclusive because of early trial discontinuation. There was no evidence that metformin combined with rosiglitazone or combined with lifestyle affected microalbuminuria compared with metformin alone in one trial. We found no trials (absence of evidence) demonstrating that interventions for children and adolescents with recently diagnosed type 2 diabetes or prediabetes change subclinical retinopathy or subclinical neuropathy.

### Impact of Interventions on Glycemia in Children/Adolescents With Recently Diagnosed Type 2 Diabetes

Three studies (4 articles) examined the glycemic impact of treating recently diagnosed type 2 diabetes.^53,^ ^63,^ ^75,^ ^76^ A double-blind RCT (also included in KQ 4) conducted across 44 sites in the United States, Russia, Ukraine, Belarus, and Poland examined whether screening for type 2 diabetes changed the intermediate outcomes of A1c and FPG.^63^ In that trial, Jones et al examined the impact of metformin (titrated up to 2,000 mg/day as tolerated [mean final dose of metformin=1,798 mg]) versus placebo in 82 children ages 10 to 16 years who were previously or newly diagnosed with type 2 diabetes. Some participants may have had a previous diagnosis of type 2 diabetes and taken oral glucose-lowering medication previously (but at least 28 days before trial start). The independent Data and Safety Monitoring Board recommended an end to the double-blind period (all participants were switched to open-label metformin) based on 8-week data showing that 70.0 percent of the placebo subjects had required rescue medication for exceeding the predetermined glycemic threshold compared with 15.8 percent of metformin subjects. At the end of double-blind treatment, the adjusted mean FPG had significantly decreased in the metformin group but increased in the placebo group (−2.4 mmol/l [−42.9 mg/dl] vs. +1.2 mmol/l [+21.4 mg/dl]; p<0.001). The mean adjusted HbA1c level at the end of the double-blind period was also significantly lower in the metformin group compared with the placebo group (7.5 vs. 8.6%, respectively; p<0.001). The proportion of subjects who met at least one of the American Diabetes Association (ADA) glycemic treatment target levels (FPG <7.0 mmol/l [<126 mg/dl] or HbA1c <7.0%) by their last double-blind treatment visit was 84 percent for the metformin group compared with 22 percent for the placebo group.

In the TODAY trial (described in KQs 3 and 4),^53^ 699 adolescents who were obese, ages 10 to 17 years, and with recent onset of type 2 diabetes (mean duration of diagnosed type 2 diabetes=7.8 months) were randomized to metformin, metformin plus rosiglitazone, or metformin plus lifestyle program. The primary outcome was loss of glycemic control, defined as a glycated hemoglobin level of at least 8 percent for 6 months or sustained metabolic decompensation requiring insulin. The authors reported that 51.7 percent (95% CI, 45.3 to 58.2), 38.6 percent (95% CI, 32.4 to 44.9), and 46.6 percent (95% CI, 40.2 to 53.0) of participants experienced loss of glycemic control in the metformin, metformin plus rosiglitazone, and metformin plus lifestyle interventions, respectively. Metformin plus rosiglitazone was associated with a 25.3 percent decrease in the occurrence of the loss of glycemic control compared with metformin alone (p=0.006); the glycemic impact of metformin plus lifestyle intervention did not differ significantly from that of metformin alone or metformin plus rosiglitazone. In TODAY2,^76^ a followup study of 572 TODAY participants, rosiglitazone was permanently discontinued in those who had been assigned to that arm. All participants continued receiving metformin monotherapy at the same dose they were taking at the end of TODAY, and add-on insulin therapy was continued or started in participants who had metabolic decompensation during followup. After 36 months, the rate of glycemic failure did not differ among participants who were previously randomized to any of the three TODAY treatment arms (metformin, metformin plus rosiglitazone, or metformin plus lifestyle program). By the end of the 96 months’ total observation period (including TODAY and TODAY2), 173 participants (25.6% of the original cohort) remained free of glycemic failure. There were no statistically significant differences by sex or race/ethnicity.

The third study was a double-blind multicenter (25 countries) RCT examining the glycemic impact of metformin plus liraglutide (up to 1.8 mg per day) vs metformin plus placebo in 134 participants aged 10 to 17 years with type 2 diabetes (mean duration 1.9 years).^75^ All participants were encouraged to follow a diet and exercise regimen. The authors reported that 23 percent and 15 percent of liraglutide-metformin and metformin only participants, respectively, were also taking basal insulin at baseline; their insulin dosage was reduced by 20 percent at the time of randomization but could be increased back up to the baseline dose (but no higher) after completion of the dose-escalation period. The primary end point was the change from baseline in the A1c level, and secondary end points included change in FPG level. Mean A1c levels at week 26 were reduced from baseline by 0.64 percentage points in the liraglutide group, whereas the levels increased by 0.42 percentage points in the placebo group (estimated treatment difference, −1.06 percentage points [95% CI, −1.65 to −0.46]; p<0.001). Moreover, 63.7 percent of the patients in the liraglutide group, as compared with 36.5 percent in the placebo group, attained A1c levels of less than 7.0 percent (p<0.001). Liraglutide was also superior to placebo in reducing FPG levels by 26 weeks (−1.08 mmol/L vs. 0.80 mmol/L).

### Impact of Interventions on Other Intermediate Outcomes in Children/Adolescents With Recently Diagnosed Type 2 Diabetes

The TODAY trial examined the development of microalbuminuria (albumin:creatinine ratio of 30 or more, with albumin measured in milligrams per deciliter and creatinine in grams per deciliter).^77^ The prevalence of microalbuminuria increased from 6.3 to 16.6 percent by the end of the study, but the incidence of new cases of microalbuminuria did not differ across treatment arms.

No studies examined subclinical retinopathy or subclinical nephropathy and reported results that were eligible for this report. The TODAY study reported on the prevalence of retinopathy among study participants using retinal images that were taken during the last year of the study, but it did not report data separated by the three study groups nor did it collect baseline data to enable reporting of changes in or incidence of retinopathy.^78^

### Impact of Interventions on Glycemia in Children/Adolescents With Prediabetes

Lifestyle: An RCT (described in KQ 5) compared a lifestyle program (Bright Bodies [BB]) with standard clinical care (CC) among 75 racially/ethnically diverse adolescents who were obese (ages 10-16 years) with prediabetes as defined by an elevated OGTT 2-h blood glucose (130-199 mg/dL; using a range that was slightly wider than the current prediabetes criteria of 140 to 199 mg/dL).^64^ The BB intervention was family based, tailored for inner-city minority children and their families, and consisted of two 50-min exercise sessions per week, one weekly weigh-in, and a 40-min nutrition/behavior modification class. Participants were encouraged to exercise 3 additional days per week and given guidance on making healthy food choices including low-fat foods of moderate portions. The primary outcomes were change in 2-h blood glucose level and percentage conversion from elevated to nonelevated 2-h blood glucose level (<130 mg/dL) at the 6-month followup. The BB group experienced a greater decrease in 2-h glucose compared with CC (27.2 vs. 10.1 mg/dL; difference=17.1 [95% CI −29.0 to −5.1]; p=0.005). In addition, more participants in the BB experienced conversion to normal 2-h glucose (<130 mg/dL) compared with CC (p=0.003). Fasting glucose and A1c did not differ between groups at 6 months.

Rosiglitazone. In a pilot randomized, double-blind, placebo-controlled study, 21 adolescents who were obese (between ages 13 and 18 years) with impaired glucose tolerance (diagnosed via OGTT) received either rosiglitazone (8 mg daily) or placebo over 4 months.^79^ Nutritional and exercise recommendations were given to both groups. The study was stopped early because recruitment became difficult due to concerns that had emerged from the literature regarding cardiac complications associated with rosiglitazone. Fifty-eight percent (n=7) in the rosiglitazone group vs. 44 percent (n=4) in the placebo group converted from impaired glucose tolerance (IGT) to normal glucose tolerance (p=0.53). Fasting glucose and A1c were collected during the study but not reported.

CQ 3. a Do interventions for (or does knowledge of) prediabetes change body mass index (BMI), weight, or healthy behaviors?

In summary, three studies were identified that addressed whether interventions for prediabetes or if knowledge of prediabetes was associated with changes in BMI and weight.^64,^ ^68,^ ^79^ No studies were identified that examined changes in healthy behaviors. Included studies compared lifestyle with standard care^64^ and rosiglitazone with placebo,^79^ and assessed the association of prediabetes identification with BMI.^68^ All three studies reported on BMI,^64,^ ^68,^ ^79^ and two studies reported on weight.^64,^ ^79^ Two of the included studies were RCTs, and one was a cohort study. All three studies were conducted in the United States and included racially diverse samples. Overall, studies reported that lifestyle interventions for children and adolescents with prediabetes improved the intermediate outcomes of weight and BMI compared with controls, rosiglitazone did not reduce weight or BMI compared with placebo, and prediabetes identification was associated with decreases in BMI in adolescents who were obese and overweight.

Two RCTs of prediabetes interventions reported on changes in BMI and weight.^64,^ ^79^ One study (described in KQ 5) recruited adolescents from an obesity clinic (n=75) and compared the lifestyle invention BB with standard care.^64^ Participating adolescents (ages 10-16 years) were required to have an elevated OGTT 2-h glucose (130-199 mg/dl), a BMI greater than 95^th^ percentile, and a Tanner stage of greater than 2. The final sample included mostly nonwhite (66%) females (70%). At 6 months, participation in BB was associated with a significant decrease in weight (−3.1 kg [95% CI, −5.3 to −0.9]) and BMI (−1.05 kg/m2 [95% CI, −1.78 to −0.32]; z-score, −0.09 [95% CI, −0.14 to −0.04]) compared with standard care. The second included trial (n=23) compared rosiglitazone with placebo and recruited participants from the same obesity clinic as in the BB study.^79^ Participants were between the ages of 13 and 18 years, had IGT or impaired fasting glucose (IFG)-IGT, and were in Tanner stage II-IV with a BMI z-score greater than 2 for age and sex. In the sample of mostly nonwhite (76%) females (57%), the study reported no significant differences in BMI (0.07 vs. −0.016, p=0.757) or weight changes (1.81 vs. 0.61, p=0.541) when comparing rosiglitazone with placebo at posttreatment.

A U.S.-based retrospective cohort study (n=4,184) using data from the Children’s Hospital of Philadelphia examined the association between prediabetes identification and BMI.^68^ In a sample of children (ages 10 to 18 years) who were overweight or obese (BMI z-score ≥1.04), the study compared differences in BMI z-score before and after available HbA1c tests. Median followup was 9.7 years. Youth were categorized as “screened” if at least one HbA1c result was available. Prediabetes was defined as 5.7 percent to 6.4 percent, 39 to 46 mmol/mol, and normal was defined as less than 5.7 percent, less than 39 mmol/mol. Using an adjusted model (adjusting for BMI z-score at HbA1c, age at HbA1c, sex, race, ethnicity, and insurance type), the study reported that children who had an HbA1c in the prediabetes range had a greater decrease in BMI z-score slope than children with a normal HbA1c (pre/post difference of −0.050/y [prediabetes] vs. −0.027 [normal], difference in difference: −0.023/year [95% CI, −0.042 to −0.004]). Children who had an HbA1c in the prediabetes range also had a greater decrease in BMI z-score slope than age-matched “unscreened” children who were obese (difference in difference: −0.031/year [95% CI, −0.042 to −0.021]) adjusting for BMI z-score at HbA1c (or matched age), age, sex, race, ethnicity, and insurance type. Limitations of the study include a lack of any information about whether or how prediabetes diagnosis was conveyed to patients, whether patients were provided counseling or interventions, whether patients changed behaviors as a result of HbA1c testing or prediabetes diagnosis, and reasons for testing (e.g., testing may be more likely for children who were obese who were initiating interventions for their obesity).

CQ 3. b Do interventions for (or does knowledge of) type 2 diabetes change BMI, weight, or healthy behaviors?

Two RCTs were identified that examined the association between diabetes interventions and changes in BMI, weight, and healthy behaviors.^18,^ ^53,^ ^63,^ ^65,^ ^66,^ ^80^ No studies were identified that examined if knowledge of diabetes was associated with BMI, weight, or healthy behaviors. The two identified trials examined metformin,^18,^ ^53,^ ^63,^ ^65,^ ^66,^ ^80^ metformin plus rosiglitazone,^18,^ ^53,^ ^65,^ ^66,^ ^80^ and lifestyle intervention.^18,^ ^53,^ ^65,^ ^66,^ ^80^ One trial (TODAY) was conducted in the United States,^18,^ ^53,^ ^65,^ ^66,^ ^80^ and one trial included sites within multiple countries.^63^ Both trials included racially diverse samples. Overall, studies reported that interventions including metformin (e.g., metformin alone, metformin plus lifestyle intervention) were associated with decreases in BMI and weight when compared with active comparisons (e.g., metformin plus rosiglitazone); one study reported that metformin was not associated with significant changes compared with control. Studies comparing metformin with metformin plus lifestyle reported significant differences in BMI change and average weight change at shorter followups (e.g., 6 months). Differences between metformin and metformin plus lifestyle were not found for meaningful reductions in weight or when average weight change was examined at longer followups (e.g., 24 months). Studies also reported that interventions that included rosiglitazone (e.g., metformin plus rosiglitazone) were associated with increases in BMI when compared with other active comparators (e.g., metformin alone, metformin plus lifestyle). The findings of the two included trials were mixed. In addition, the TODAY study reported that the combination of metformin plus lifestyle was associated with improved health behaviors compared with metformin plus rosiglitazone for males at 6 months, although data were missing for many participants. Significant differences in health behaviors were not found between other intervention groups (e.g., metformin alone vs. metformin plus lifestyle, metformin alone vs. metformin plus rosiglitazone) among males, and no significant differences were found between groups among females.

One trial^63^ conducted in multiple countries included children between the ages 8-16 years with a previous or new diabetes diagnosis. In the sample of mostly nonwhite (63%) females (70%), no significant differences were reported in the mean changes for BMI or weight when comparing metformin with placebo (−0.5 kg/m^2^ vs. −0.4 kg/m^2^ and −1.5 kg vs. −0.9 kg, respectively) at 16 weeks posttreatment.^63^

The second identified trial was the TODAY study (described in KQ 3).^18,^ ^53,^ ^65,^ ^66,^ ^80^ At 6 months, the combination of metformin plus lifestyle was associated with significant decreases in BMI compared with metformin alone (−0.21 vs. 0.35, p=0.0201) or in comparison with metformin plus rosiglitazone (−0.21 vs. 0.70, p=0.0002). At 24 months, significant differences in BMI were reported between metformin plus rosiglitazone compared with metformin alone (2.93 vs. 1.57; p<0.0001) and when comparing metformin plus rosiglitazone with metformin plus lifestyle (2.93 vs. 1.52, p<0.001).

For average change in percentage overweight (defined as BMI minus BMI at the 50th percentile for age and sex, divided by BMI at the 50th percentile), the TODAY study reported that both metformin alone (−1.42 percentage points) and metformin plus lifestyle (−3.64 percentage points) were associated with significant decreases. The study also reported that metformin plus rosiglitazone was associated with a significant increase in percentage overweight (0.81 percentage points). The overall comparison and the comparison across all three groups were significant for this outcome at 6 months (p<0.001). At 24 months, differences between metformin plus rosiglitazone compared with metformin alone (0.89 percentage points vs. −4.42 percentage points), and metformin plus rosiglitazone compared with metformin plus lifestyle (0.89 percentage points vs. −5.02 percentage points) remained statistically significant (p<0.001). The differences between metformin and metformin and lifestyle were no longer significant at 24 months.^18,^ ^53,^ ^65,^ ^66,^ ^80^

The TODAY study also reported on the proportion of children with a meaningful reduction (≥7 percentage points) in percentage overweight posttreatment. A higher proportion of children in the metformin plus lifestyle group had a meaningful reduction in overweight participants compared with metformin plus rosiglitazone (31.2% vs. 16.7%, p<0.001) at 6 months. The study did not report any significant differences when comparing metformin plus lifestyle versus metformin alone (31.2% vs. 24.3%, p=NS).^18,^ ^53,^ ^65,^ ^66,^ ^80^

In addition, the TODAY study reported on the association between interventions and health behaviors.^80^ However, the results for these outcomes may have a high risk of bias because of missing data (with data missing for 36 percent to 41 percent of participants, depending on the time point). At 6 months, males in the metformin plus lifestyle group were more likely to improve their eating habits and sedentary lifestyles compared with males in the metformin plus rosiglitazone group (50% vs. 26%, p=0.01). No significant differences were found between metformin plus lifestyle and metformin plus rosiglitazone at 24 months. Also, no significant differences were found between metformin plus lifestyle and metformin alone or between metformin alone and metformin plus rosiglitazone at 6 or 24 months. No significant differences in health behaviors were reported for females at 6 or 24 months across the three intervention groups.^80^

CQ 4 What is the frequency of agreement among screening tests (HbA1c level, FPG level, and 2-hour glucose tolerance test) for prediabetes and type 2 diabetes?

We focused on studies from very high HDI countries with at least 100 participants that reported relevant outcomes and used (at least some) data collected within the past 10 years. Studies were required to report frequency of agreement between at least two of the relevant tests and to use current criteria for diagnosis of prediabetes or type 2 diabetes (based on the ADA guidelines); we excluded studies that used older criteria. We included eight articles (Appendix A Table 2). Of those eight, one compared A1c and OGTT,^81^ two compared A1c and FPG,^72,^ ^82^ and five compared the results of all three tests (A1c, FPG, and OGTT).^83–87^ Sample sizes ranged from 117 to 3,980. Five of the studies were conducted in the United States. The studies typically enrolled youths who were obese and overweight. Many of the studies reported relatively large differences in the proportion of youths diagnosed with prediabetes or diabetes when using different tests.^72,^ ^81,^ ^82,^ ^85,^ ^87^ For example, a study of 902 predominantly black youths conducted in the United States reported that prediabetes prevalence was 54.3 percent based on A1c compared with only 5.6 percent when using OGTT, and a study of 149 predominately Hispanic youths reported a diabetes or prediabetes (combined) prevalence of 48 percent based on A1c compared with 12 percent based on FPG and 16 percent based on OGTT.^81,^ ^87^

These findings are consistent with evidence in adults. Further, elevations in A1c, FPG, and OGTT results may represent somewhat different metabolic states. The 2021 evidence review for the USPSTF on screening for prediabetes and diabetes in adults summarized a systematic review on the prevalence of prediabetes that would be identified by various screening tests.^88^ The review identified five studies (with a total of 17,108 adults) that showed generally low agreement between HbA1c, fasting plasma glucose, and 2-hour glucose tolerance test.^88^ For example, using ADA criteria, the prevalence of prediabetes by any test was 54 percent.^88^ Of those, 25 percent had isolated IFG, 6 percent isolated IGT, 22 percent isolated HbA1c criteria, 7 percent IFG and IGT, 27 percent IFG and HbA1c criteria, 4 percent IGT and HBA1c criteria, and 9 percent had all three.^88^

CQ 5 Are there risk assessment tools that are feasible for use in primary care settings, accurately predict the risk of prediabetes or type 2 diabetes for children and adolescents, and have been externally validated in U.S. populations?

We found two risk assessment tools for predicting risk of type 2 diabetes or prediabetes that have been validated in U.S. children or adolescents. Hannon and colleagues conducted a cluster-randomized clinical trial (published in 2017) to study the feasibility and effectiveness of a computerized clinical decision support system called Child Health Improvement Through Computer Automation (CHICA).^89–94^ The risk assessment tool compiled relevant inputs from the parent section of a previsit questionnaire (family history, race/ethnicity), the clinic staff prescreening form (patient height and weight), and a physician worksheet (signs and symptoms of insulin resistance or conditions associated with insulin resistance). CHICA analyzes these inputs and identifies those at “high risk for type 2 diabetes” using the ADA guidelines from 2000 (i.e., if they had BMI ≥85^th^ percentile and two or more of the following risk factors: a family history of type 2 diabetes in a first- or second-degree relative, black race, Hispanic ethnicity, maternal history of diabetes or gestational diabetes, and signs of or conditions associated with insulin resistance) (the article did not provide additional details about what signs or conditions were considered as associated with insulin resistance). If high risk, it recommended screening for type 2 diabetes using FPG and HbA1c where prediabetes was defined as FPG 95 to 125 mg/dL and HbA1c 5.7 to 6.5 percent, and diabetes as FPG greater than125 mg/dL and HbA1c greater than 6.5 percent. Children age 10 years or older (n=1,369) attending four primary care clinics in Indiana were included. The primary outcome was the percentage of youths identified with documented risk factors for type 2 diabetes. The authors found that the screening rate was significantly higher after using the tool, but the authors noted that using the tool did not lead to more patients being diagnosed with prediabetes or type 2 diabetes (although the study was not designed or powered for that outcome). The authors found that when using FPG, 33.3 percent of control patients screened and 22.2 percent of intervention patients had FPG in the prediabetes range, and none were in the diabetes range. When using HbA1c, 31.2 percent of control patients and 20.6 percent of intervention patients had levels in the prediabetes range, and only one patient in the intervention group was diagnosed with diabetes.

DuBose and colleagues developed an adapted version of the adult risk assessment tool called Tool for Assessing Glucose ImpairmenT (TAG-IT) for an adolescent population (published in 2012) and named it Tool for Assessing Glucose ImpairmenT among Adolescents (TAG-IT-A).^95,^ ^96^ They used data from a national U.S. sample from the Centers for Disease Control and Prevention’s National Health and Nutrition Examination Survey (NHANES) from 1999 to 2008. To develop TAG-IT-A, the authors followed the development process of TAG-IT. They used multiple regression to calculate the association of individual patient factors (age, race, sex, BMI, resting heart rate, hypertension diagnosis [measured resting blood pressure or physician diagnosis]) and fasting blood glucose and FPG greater than or equal to 100 mg/dL, defined as IFG. They then used regression to calculate the association of the group of significant factors with FPG level and calculated weighted scores for each factor to create a TAG-IT-A scoring system. The scoring system involves each predictive factor being given a score, modeled after the Charlson Comorbidity Index.^97^ Odds ratios (ORs) from 1.0 to 1.19 were assigned 0 points, ORs from 1.2 to 1.49 were assigned 1 point, ORs from 1.5 to 2.49 were assigned 2 points, etc. The score from each factor is added together to create a final score, and as scores increased from 3 or higher, the authors reported that sensitivity of TAG-IT-A improved. The authors found that there was a positive and significant relationship between FPG and age (ages 12-14 years), sex (male), BMI (obese), and resting heart rate (≥70 beats per minute), which are the four components that create the TAG-IT-A score. TAG-IT-A score was predictive of IFG with an area under the receiver operating curve (AUC)=0.61 (confidence interval not reported), indicating inadequate discrimination. Although the AUC was lower than it was found for the original TAG-IT tool, it was thought that TAG-IT-A may not be as predictive in adolescents because other variables that are not captured may be important, such as aerobic fitness, pubertal development, and physical activity levels.

We identified one additional tool that has not been studied in the United States but was studied in a European pediatric population. Gray and colleagues conducted an accuracy evaluation (published in 2019) of a previously developed risk prediction tool called PRESTARt, comparing it with a reference standard of clinician assessment of whether the participant was high or low risk of developing type 2 diabetes in their lifetime.^98^ Aside from stating that two clinicians independently judged each participant, with a third adjudicating if needed, no additional details are provided about how lifetime risk status was established. The authors recruited 636 adolescents age 12 to 14 years from five European countries (Germany, Greece, Portugal, Spain, and the United Kingdom). They found that participants were high risk if they were overweight/obese and had at least one other risk factor from among the following: high waist circumference, family history of diabetes, parental obesity, not breast fed, high sugar intake, high screen time, low physical activity, and low fruit and vegetable intake. The AUC when comparing PRESTARt and clinician assessment was 0.74 (95% CI, 0.71 to 0.78).

Appendix A Table 1 Screening Recommendations of Other Groups

Organization, Year | Screening Recommendation | Risk Factors Considered | Frequency of Screening
American Diabetes Association, 2020^47^ | Screen children after onset of puberty or age 10 years who are overweight or obese and have one or more additional risk factors with FPG or 2-h PG after 75-g OGTT, or an A1c | Puberty; age (after 10 years); overweight (BMI ≥85th percentile) or obese (BMI ≥95th percentile); additional risk factors include maternal history of diabetes or GDM during the child’s gestation, family history of type 2 diabetes in first- or second-degree relative, race/ethnicity (Native American, African American, Latino, Asian American, Pacific Islander), or signs of insulin resistance or conditions associated with insulin resistance (acanthosis nigricans, hypertension, dyslipidemia, polycystic ovary syndrome, or small-for-gestational-age birth weight) | Repeat screening every 3 years or more frequently if BMI is increasing
Diabetes Canada, 2018^69^ | Screen nonpubertal children with at least three risk factors and pubertal children with at least two risk factors with a combination of A1c and a FPG test or a random PG test | Obesity (BMI >95th percentile for age and gender), member of a high-risk ethnic group (e.g., aboriginal, African, Asian, Hispanic, or South Asian descent), family history of type 2 diabetes or exposure to hyperglycemia in utero and symptoms of insulin resistance (including acanthosis nigricans, hypertension, dyslipidemia, NAFLD) | Repeat screening every 2 years in nonpubertal children with ≥3 risk factors and in pubertal children with ≥2 risk factors, in children with IFG or impaired glucose tolerance, in children with use of atypical antipsychotic medications, and in children with PCOS
International Society for Pediatric and Adolescent Diabetes, 2014^70^ | Screen children and adolescents using American Diabetes Association criteria including using a FPG test, a 2-h postchallenge glucose test, or a hemoglobin A1c | NR | Does not specify, but supporting the American Diabetes Association criteria implies every 3 years or more frequent if BMI is increasing
National Institute for Health and Care Excellence (NICE), 2015^52^ | Does not have a true screening recommendation, but it states to “think about the possibility of type 2 diabetes in children and young people with suspected diabetes” | Family history of type 2 diabetes, obese at presentation, are of black or Asian family origin, have no insulin requirement or an insulin requirement of <0.5 units/kg body weight/day after the partial remission phase, and demonstrate evidence of insulin resistance | NR
Pediatric Endocrine Society (PES) Drugs and Therapeutics Committee, 2012^71^ | Screen children who are asymptomatic or minimally symptomatic and at risk with HbA1c test | HbA1c is unreliable in those with sickle-cell carrier status | NR

Abbreviations: BMI=body mass index; FPG=fasting plasma glucose; GDM=gestational diabetes mellitus; HbA1c=glycated hemoglobin; IFG=impaired fasting glucose; NAFLD=non-alcoholic fatty liver disease; NICE=National Institute for Health and Care Excellence; NR=not reported; OGTT=oral glucose tolerance test; PCOS=polycystic ovary syndrome; PES=Pediatric Endocrine Society; PG=2-h plasma glucose.

Appendix A Table 2 Studies That Compared Agreement Among Screening Tests, by Comparison

Author, Year | Comparison | N | Age, Mean (Range) | Country | Race and Ethnicity | Main Results
Hitt et al, 2016^81^ | A1c and OGTT | 902 | 11.6 (2 to 18 y) | U.S. | 70% Black | Diabetes prevalence: based on A1c was 2.9% (n=26) vs. 1.7% (n=15) based on OGTT; Prediabetes prevalence: based on A1c was 54.3% (n=491) vs. 5.6% (n=51) based on OGTT
Buse et al, 2013^72^; HEALTHY | A1c and FPG | 3,980 | 11 (10 to 14 y) | U.S. | 91.5% White | 3.2% had A1c of 5.7%-6.4%; 16.0% had IFG. Of those with A1c of 5.7% to 6.4% (128 participants), 63.3% had normal fasting glucose (<100) and 36.7% had IFG. Of those with normal A1c (<5.7%) (3,852 participants), 84.7% had normal fasting glucose and 15.3% had IFG
Tester et al, 2013^82^ | A1c and FPG | 1,356 | 11 (2 to 19 y) | U.S. | 14% Black; 49% Hispanic | Prediabetes prevalence was 20.7% based on A1c vs. 7.8% based on IFG
Kim et al, 2019^83^ | A1c, FPG, and OGTT | 190 | 12.6 (NR) | South Korea | NR | Diabetes prevalence: based on A1c was 22.1% (n=42) vs. 21.1% (n=40) based on OGTT; Prediabetes prevalence: based on A1c was 21.6% (n=41) vs. 17.4% (n=33) based on OGTT; Diagnostic sensitivity (for diabetes) was lower for FPG (63.8%) than for A1c (89.4%) or OGTT (85.1%)
Yoon et al, 2018^84^ | A1c, FPG, and OGTT | 236 | 10.4 (NR) | South Korea | NR | Diabetes prevalence: 17% (n=39) based on OGTT. Prediabetes prevalence: 22% (n=52) based on OGTT. Using ADA cutoffs, A1c had sensitivity of 87.2% and specificity of 98.5% for detecting diabetes and FPG had 66.7% and 99.0%, respectively (compared with OGTT reference standard)
Chan et al, 2016^85^ | A1c, FPG, and OGTT | 117 | 14.1 (10 to 18 y) | U.S. | 22% White; 17% Black; 59% Hispanic | About half of the participants met criteria for prediabetes or diabetes based on either OGTT (40.2%) or HbA1c (51.3%), but only 9% met FPG criteria for prediabetes or diabetes
Galhardo and Shield, 2015^86^ | A1c, FPG, and OGTT | 266 | 12.3 (8.9 to 17.6 y) | Portugal | 90% White | Diabetes prevalence: 1 (0.4%) based on A1c vs 0 (0%) based on OGTT; Prediabetes prevalence: 32 (12%) based on A1c vs. 13 (4.9%) based on OGTT; A1c had AUC of 0.59 (95% CI, 0.40 to 0.78) and FPG had AUC of 0.76 (95% CI, 0.66 to 0.87) using OGTT as the reference standard
Brar et al, 2014^87^ | A1c, FPG, and OGTT | 149 | 13.0 to 13.8 (NR) | U.S. | 71% Hispanic | Prediabetes or type 2 diabetes prevalence: 71 (48%) based on A1c vs. 18 (12%) based on FPG vs. 24 (16%) based on OGTT

Abbreviations: ADA=American Diabetes Association; AUC=area under the curve; CI=confidence interval; FPG=fasting plasma glucose; IFG=impaired fasting glucose; NR=not reported; OGTT=oral glucose tolerance test.