# References

1 Guirguis-Blake JM, Senger CA, Webber EM, . Screening for Chronic Obstructive Pulmonary Disease: Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2016;315(13):1378–93. 10.1001/jama.2016.2654 27046366
2 U. S. Preventive Services Task Force, Siu AL, Bibbins-Domingo K, . Screening for Chronic Obstructive Pulmonary Disease: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;315(13):1372–7. 10.1001/jama.2016.2638 27046365
3 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2021.
4 Global Initiative for Chronic Obstructive Lung Disease. Global Strategy for the Diagnosis, Management, and Prevention of Chronic Obstructive Pulmonary Disease: 2020 Report. https://goldcopd.org/wp-content/uploads/2019/12/GOLD-2020-FINAL-ver1.2-03Dec19_WMV.pdf. Accessed: 2020.
5 Antó JM, Vermeire P, Vestbo J, . Epidemiology of chronic obstructive pulmonary disease. Eur Respir J. 2001;17(5):982–94. 10.1183/09031936.01.17509820 11488336
6 Mannino DM, Watt G, Hole D, . The natural history of chronic obstructive pulmonary disease. Eur Respir J. 2006;27(3):627–43. 10.1183/09031936.06.00024605 16507865
7 Lange P, Celli B, Agustí A, . Lung-Function Trajectories Leading to Chronic Obstructive Pulmonary Disease. New England Journal of Medicine. 2015;373(2):111–22. 10.1056/NEJMoa1411532 26154786
8 Rennard SI, Drummond MB. Early chronic obstructive pulmonary disease: definition, assessment, and prevention. Lancet. 2015;385(9979):1778–88. 10.1016/S0140-6736(15)60647-X 25943942
9 Qaseem A, Wilt TJ, Weinberger SE, . Diagnosis and management of stable chronic obstructive pulmonary disease: a clinical practice guideline update from the American College of Physicians, American College of Chest Physicians, American Thoracic Society, and European Respiratory Society. Ann Intern Med. 2011;155(3):179–91. 10.7326/0003-4819-155-3-201108020-00008 21810710
10 Global Initiative for Chronic Obstructive Lung Disease. Global Strategy for the Diagnosis, Management, and Prevention of Chronic Obstructive Pulmonary Disease: 2022 Report. 2022.
11 Centers for Disease Control and Prevention, National Center for Health Statistics. Underlying Cause of Death 1999-2020. http://wonder.cdc.gov/ucd-icd10.html. Accessed: December 22, 2021.
12 Centers for Disease Control and Prevention. COPD Data and Statistics. https://www.cdc.gov/copd/data.html. Accessed: September 15, 2021.
13 Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Division of Population Health. BRFSS Prevalence & Trends Data. https://nccd.cdc.gov/BRFSSPrevalence/rdPage.aspx?rdReport=DPH_BRFSS.ExploreByTopic&irbLocationType=StatesAndMMSA&islClass=CLASS03&islTopic=TOPIC14&islYear=2020&rdRnd=5282. Accessed: September 15, 2021.
14 Varmaghani M, Dehghani M, Heidari E, . Global prevalence of chronic obstructive pulmonary disease: systematic review and meta-analysis. East Mediterr Health J. 2019;25(1):47–57. 10.26719/emhj.18.014 30919925
15 Singh D, Agusti A, Anzueto A, . Global Strategy for the Diagnosis, Management, and Prevention of Chronic Obstructive Lung Disease: the GOLD science committee report 2019. European Respiratory Journal. 2019;53(5):05. 10.1183/13993003.00164-2019
16 Wheaton AG, Liu Y, Croft JB, . Chronic Obstructive Pulmonary Disease and Smoking Status - United States, 2017. MMWR Morb Mortal Wkly Rep. 2019;68(24):533–8. 10.15585/mmwr.mm6824a1 31220055
17 Blanc PD, Annesi-Maesano I, Balmes JR, . The Occupational Burden of Nonmalignant Respiratory Diseases. An Official American Thoracic Society and European Respiratory Society Statement. American journal of respiratory and critical care medicine. 2019;199(11):1312–34. 10.1164/rccm.201904-0717ST 31149852
18 Balmes J, Becklake M, Blanc P, . American Thoracic Society Statement: Occupational contribution to the burden of airway disease. American journal of respiratory and critical care medicine. 2003;167(5):787–97. 10.1164/rccm.167.5.787 12598220
19 Diaz-Guzman E, Mannino DM. Epidemiology and prevalence of chronic obstructive pulmonary disease. Clin Chest Med. 2014;35(1):7–16. 10.1016/j.ccm.2013.10.002 24507833
20 National Clinical Guideline Centre. National Institute for Health and Clinical Excellence: Guidance. Chronic Obstructive Pulmonary Disease: Management of Chronic Obstructive Pulmonary Disease in Adults in Primary and Secondary Care. London: Royal College of Physicians (UK) National Clinical Guideline Centre - Acute and Chronic Conditions.; 2010.
21 Smoking-attributable mortality, years of potential life lost, and productivity losses--United States, 2000-2004. MMWR Morb Mortal Wkly Rep. 2008;57(45):1226–8.19008791
22 Ferguson GT, Enright PL, Buist AS, . Office spirometry for lung health assessment in adults: a consensus statement from the National Lung Health Education Program. Respir Care. 2000;45(5):513–30.10813228
23 Hnizdo E, Sullivan PA, Bang KM, . Association between chronic obstructive pulmonary disease and employment by industry and occupation in the US population: a study of data from the Third National Health and Nutrition Examination Survey. Am J Epidemiol. 2002;156(8):738–46. 10.1093/aje/kwf105 12370162
24 Pleasants RA, Riley IL, Mannino DM. Defining and targeting health disparities in chronic obstructive pulmonary disease. International Journal of Copd. 2016;11:2475–96.27785005
25 Gaffney AW, Hawks L, White AC, . Health Care Disparities Across the Urban-Rural Divide: A National Study of Individuals with COPD. J Rural Health. 2020. 10.1111/jrh.12525
26 Ni H, Xu J. COPD-related Mortality by Sex and Race Among Adults Aged 25 and Over: United States, 2000-2014. NCHS Data Brief. 2016(256):1–8.
27 Laffey KG, Nelson AD, Laffey MJ, . Chronic respiratory disease disparity between American Indian/Alaska Native and white populations, 2011-2018. BMC Public Health. 2021;21(1):1466. 10.1186/s12889-021-11528-8 34320979
28 Cornelius ME, Wang TW, Jamal A, . Tobacco product use among adults—United States, 2019. Morbidity and Mortality Weekly Report. 2020;69(46):1736.33211681
29 National Center for Health Statistics. Health, United States, 2019. Hyattsville, MD.2021. PMID. 10.15620/cdc:100685
30 Kuhn BT, Wick KD, Schivo M. An Update in Health Disparities in COPD in the USA. Current Pulmonology Reports. 2021. 10.1007/s13665-021-00268-0
31 Larsson K, Janson C, Stallberg B, . Impact of COPD diagnosis timing on clinical and economic outcomes: the ARCTIC observational cohort study. International Journal of Copd. 2019;14:995–1008. 10.2147/COPD.S195382 31190785
32 Sun Y, Zhou J. New insights into early intervention of chronic obstructive pulmonary disease with mild airflow limitation. International Journal of Copd. 2019;14:1119–25. 10.2147/COPD.S205382 31213792
33 Patel JG, Nagar SP, Dalal AA. Indirect costs in chronic obstructive pulmonary disease: a review of the economic burden on employers and individuals in the United States. Int J Chron Obstruct Pulmon Dis. 2014;9:289–300. 10.2147/copd.S57157 24672234
34 Hangaard S, Kronborg T, Hejlesen OK. Characteristics of Subjects With Undiagnosed COPD Based on Post-Bronchodilator Spirometry Data. Respir Care. 2019;64(1):63–70. 10.4187/respcare.06296 30087194
35 Johnson KM, Bryan S, Ghanbarian S, . Characterizing undiagnosed chronic obstructive pulmonary disease: a systematic review and meta-analysis. Respiratory Research. 2018;19(1):26. 10.1186/s12931-018-0731-1 29415723
36 Colak Y, Afzal S, Nordestgaard BG, . Prognosis of asymptomatic and symptomatic, undiagnosed COPD in the general population in Denmark: a prospective cohort study. Lancet Respir Med. 2017;5(5):426–34. 10.1016/S2213-2600(17)30119-4 28389225
37 Buffels J, Degryse J, Heyrman J, . Office spirometry significantly improves early detection of COPD in general practice: the DIDASCO Study. Chest. 2004;125(4):1394–9. 10.1378/chest.125.4.1394 15078751
38 Tinkelman DG, Price D, Nordyke RJ, . COPD screening efforts in primary care: what is the yield? Prim Care Respir J. 2007;16(1):41–8. 10.3132/pcrj.2007.00009 17297526
39 Frith P, Crockett A, Beilby J, . Simplified COPD screening: validation of the PiKo-6® in primary care. Prim Care Respir J. 2011;20(2):190–8, 2 p following 8. 10.4104/pcrj.2011.00040 21597667
40 Yawn BP, Mapel DW, Mannino DM, . Development of the Lung Function Questionnaire (LFQ) to identify airflow obstruction. Int J Chron Obstruct Pulmon Dis. 2010;5:1–10.20368906
41 Hanania NA, Mannino DM, Yawn BP, . Predicting risk of airflow obstruction in primary care: Validation of the lung function questionnaire (LFQ). Respir Med. 2010;104(8):1160–70. 10.1016/j.rmed.2010.02.009 20226647
42 Price DB, Tinkelman DG, Halbert RJ, . Symptom-based questionnaire for identifying COPD in smokers. Respiration. 2006;73(3):285–95. 10.1159/000090142 16330875
43 Price DB, Tinkelman DG, Nordyke RJ, . Scoring system and clinical application of COPD diagnostic questionnaires. Chest. 2006;129(6):1531–9. 10.1378/chest.129.6.1531 16778271
44 Martinez FJ, Raczek AE, Seifer FD, . Development and initial validation of a self-scored COPD Population Screener Questionnaire (COPD-PS). Copd. 2008;5(2):85–95. 10.1080/15412550801940721 18415807
45 Weiss G, Steinacher I, Lamprecht B, . Development and validation of the Salzburg COPD-screening questionnaire (SCSQ): a questionnaire development and validation study. NPJ Primary Care Respiratory Medicine. 2017;27(1):4. 10.1038/s41533-016-0005-7
46 Martinez FJ, Mannino D, Leidy NK, . A New Approach for Identifying Patients with Undiagnosed Chronic Obstructive Pulmonary Disease. American journal of respiratory and critical care medicine. 2017;195(6):748–56. 10.1164/rccm.201603-0622OC 27783539
47 Yawn BP, Han M, Make BM, . Protocol Summary of the COPD Assessment in Primary Care To Identify Undiagnosed Respiratory Disease and Exacerbation Risk (CAPTURE) Validation in Primary Care Study. Chronic Obstr Pulm Dis. 2021;8(1). 10.15326/jcopdf.2020.0155
48 Kjeldgaard P, Lykkegaard J, Spillemose H, . Multicenter study of the COPD-6 screening device: feasible for early detection of chronic obstructive pulmonary disease in primary care? International journal of COPD [serial on the Internet]. 2017 [cited KQ Search - Cochrane; 12: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01412190/full.
49 Bai JW, Chen XX, Liu S, . Smoking cessation affects the natural history of COPD. Int J Chron Obstruct Pulmon Dis. 2017;12:3323–8. 10.2147/copd.S150243 29180862
50 Anthonisen NR, Connett JE, Kiley JP, . Effects of smoking intervention and the use of an inhaled anticholinergic bronchodilator on the rate of decline of FEV1. The Lung Health Study. Jama. 1994;272(19):1497–505.7966841
51 Anthonisen NR, Skeans MA, Wise RA, . The effects of a smoking cessation intervention on 14.5-year mortality: a randomized clinical trial. Ann Intern Med. 2005;142(4):233–9. 10.7326/0003-4819-142-4-200502150-00005 15710956
52 Riley CM, Sciurba FC. Diagnosis and Outpatient Management of Chronic Obstructive Pulmonary Disease: A Review. JAMA. 2019;321(8):786–97. 10.1001/jama.2019.0131 30806700
53 Diab N, Gershon AS, Sin DD, . Underdiagnosis and Overdiagnosis of Chronic Obstructive Pulmonary Disease. American journal of respiratory and critical care medicine. 2018;198(9):1130–9. 10.1164/rccm.201804-0621CI 29979608
54 Hansen JG, Pedersen L, Overvad K, . The Prevalence of chronic obstructive pulmonary disease among Danes aged 45-84 years: population-based study. Copd. 2008;5(6):347–52. 10.1080/15412550802522635 19353348
55 Shahab L, Jarvis MJ, Britton J, . Prevalence, diagnosis and relation to tobacco dependence of chronic obstructive pulmonary disease in a nationally representative population sample. Thorax. 2006;61(12):1043–7. 10.1136/thx.2006.064410 17040932
56 Johnston KN, Young M, Grimmer-Somers KA, . Why are some evidence-based care recommendations in chronic obstructive pulmonary disease better implemented than others? Perspectives of medical practitioners. Int J Chron Obstruct Pulmon Dis. 2011;6:659–67. 10.2147/copd.S26581 22259242
57 Vollmer WM, Gíslason T, Burney P, . Comparison of spirometry criteria for the diagnosis of COPD: results from the BOLD study. Eur Respir J. 2009;34(3):588–97. 10.1183/09031936.00164608 19460786
58 Schermer TR, Jacobs JE, Chavannes NH, . Validity of spirometric testing in a general practice population of patients with chronic obstructive pulmonary disease (COPD). Thorax. 2003;58(10):861–6. 10.1136/thorax.58.10.861 14514938
59 Enright P, Vollmer WM, Lamprecht B, . Quality of spirometry tests performed by 9893 adults in 14 countries: the BOLD Study. Respir Med. 2011;105(10):1507–15. 10.1016/j.rmed.2011.04.008 21549584
60 Hardie JA, Buist AS, Vollmer WM, . Risk of over-diagnosis of COPD in asymptomatic elderly never-smokers. Eur Respir J. 2002;20(5):1117–22. 10.1183/09031936.02.00023202 12449163
61 Mamary AJ, Stewart JI, Kinney GL, . Race and Gender Disparities are Evident in COPD Underdiagnoses Across all Severities of Measured Airflow Obstruction. Chronic Obstr Pulm Dis. 2018;5(3):177–84. 10.15326/jcopdf.5.3.2017.0145 30584581
62 Foreman MG, Zhang L, Murphy J, . Early-onset chronic obstructive pulmonary disease is associated with female sex, maternal factors, and African American race in the COPDGene Study. American journal of respiratory and critical care medicine. 2011;184(4):414–20. 10.1164/rccm.201011-1928OC 21562134
63 Wells GA, Shea BJ, O’Connell DP, J., . The Newcastle-Ottawa Scale (NOS) for Assessing the Quality of Nonrandomised Studies in Meta-Analysis. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: June 27, 2017.
64 American Thoracic Society. St. George’s Respiratory Questionnaire (SGRQ). https://www.thoracic.org/members/assemblies/assemblies/srn/questionaires/sgrq.php. Accessed: 2020.
65 American Thoracic Society. COPD Assessment Test (CAT). https://www.thoracic.org/members/assemblies/assemblies/srn/questionaires/copd.php. Accessed: 2020.
66 Altenburg WA, ten Hacken NH, Bossenbroek L, . Short- and long-term effects of a physical activity counselling programme in COPD: a randomized controlled trial. Respir Med. 2015;109(1):112–21. 10.1016/j.rmed.2014.10.020 25499548
67 Bischoff EW, Akkermans R, Bourbeau J, . Comprehensive self management and routine monitoring in chronic obstructive pulmonary disease patients in general practice: randomised controlled trial. BMJ. 2012;345:e7642. 10.1136/bmj.e7642 23190905
68 Fastenau A, van Schayck OC, Winkens B, . Effectiveness of an exercise training programme COPD in primary care: A randomized controlled trial. Respir Med. 2020;165:105943. 10.1016/j.rmed.2020.105943 32308200
69 Jolly K, Sidhu MS, Hewitt CA, . Self management of patients with mild COPD in primary care: randomised controlled trial. BMJ. 2018;361:k2241. 10.1136/bmj.k2241 29899047
70 Liang J, Abramson MJ, Russell G, . Interdisciplinary COPD intervention in primary care: a cluster randomised controlled trial. European Respiratory Journal. 2019;53(4). 10.1183/13993003.01530-2018
71 Markun S, Rosemann T, Dalla-Lana K, . Care in Chronic Obstructive Lung Disease (CAROL): a randomised trial in general practice. European Respiratory Journal. 2018;51(5):05. 10.1183/13993003.01873-2017
72 Martinez FJ, Rabe KF, Lipworth BJ, . Glycopyrrolate/Formoterol Fumarate Metered Dose Inhaler Improves Lung Function versus Monotherapies in GOLD Category A Patients with COPD: Pooled Data from the Phase III PINNACLE Studies. International Journal of Copd. 2020;15:99–106. 10.2147/COPD.S229794 32021148
73 Nyberg A, Tistad M, Wadell K. Can the COPD web be used to promote self-management in patients with COPD in swedish primary care: a controlled pragmatic pilot trial with 3 month- and 12 month follow-up. Scand J Prim Health Care. 2019;37(1):69–82. 10.1080/02813432.2019.1569415 30700230
74 Roman M, Larraz C, Gomez A, . Efficacy of pulmonary rehabilitation in patients with moderate chronic obstructive pulmonary disease: a randomized controlled trial. BMC Fam Pract. 2013;14:21. 10.1186/1471-2296-14-21 23399113
75 Tashkin DP, Celli B, Senn S, . A 4-year trial of tiotropium in chronic obstructive pulmonary disease. N Engl J Med. 2008;359(15):1543–54. 10.1056/NEJMoa0805800 18836213
76 Vestbo J, Anderson JA, Brook RD, . Fluticasone furoate and vilanterol and survival in chronic obstructive pulmonary disease with heightened cardiovascular risk (SUMMIT): a double-blind randomised controlled trial. Lancet. 2016;387(10030):1817–26. PMID: 27203508 10.1016/S0140-6736(16)30069-1 27203508
77 Voncken-Brewster V, Tange H, de Vries H, . A randomized controlled trial evaluating the effectiveness of a web-based, computer-tailored self-management intervention for people with or at risk for COPD. International Journal of Copd. 2015;10:1061–73. 10.2147/COPD.S81295 26089656
78 Wan ES, Kantorowski A, Polak M, . Long-term effects of web-based pedometer-mediated intervention on COPD exacerbations. Respir Med. 2020;162:105878. 10.1016/j.rmed.2020.105878 32056676
79 Weldam SWM, Schuurmans MJ, Zanen P, . The effectiveness of a nurse-led illness perception intervention in COPD patients: a cluster randomised trial in primary care. ERJ open res. 2017;3(4). 10.1183/23120541.00115-2016
80 Zwar NA, Bunker JM, Reddel HK, . Early intervention for chronic obstructive pulmonary disease by practice nurse and GP teams: a cluster randomized trial. Fam Pract. 2016;33(6):663–70.27535327
81 Price DB, Voorham J, Brusselle G, . Inhaled corticosteroids in COPD and onset of type 2 diabetes and osteoporosis: matched cohort study. NPJ Primary Care Respiratory Medicine. 2019;29(1):38. 10.1038/s41533-019-0150-x
82 Wang MT, Liou JT, Lin CW, . Association of Cardiovascular Risk With Inhaled Long-Acting Bronchodilators in Patients With Chronic Obstructive Pulmonary Disease: A Nested Case-Control Study. JAMA Intern Med. 2018;[Epub ahead of print]. PMID: 29297057. 10.1001/jamainternmed.2017.7720 29297057
83 Crim C, Calverley PMA, Anderson JA, . Pneumonia risk with inhaled fluticasone furoate and vilanterol in COPD patients with moderate airflow limitation: The SUMMIT trial. Respir Med. 2017;131:27–34. 10.1016/j.rmed.2017.07.060 28947039
84 Rabe KF, Halpin DMG, Han MK, . Composite endpoints in COPD: clinically important deterioration in the UPLIFT trial. Respiratory Research. 2020;21(1):177. 10.1186/s12931-020-01431-y 32646424
85 Halpin DMG, Tashkin DP, Celli BR, . Effect of Tiotropium on Outcomes in Patients With COPD, Categorized Using the New GOLD Grading System: Results of the UPLIFT R Randomized Controlled Trial. Chronic Obstr Pulm Dis. 2015;2(3):236–51. 10.15326/jcopdf.2.3.2014.0142 28848846
86 Moy ML, Martinez CH, Kadri R, . Long-Term Effects of an Internet-Mediated Pedometer-Based Walking Program for Chronic Obstructive Pulmonary Disease: Randomized Controlled Trial. J Med Internet Res. 2016;18(8):e215. 10.2196/jmir.5622 27502583
87 Decramer M, Celli B, Kesten S, . Effect of tiotropium on outcomes in patients with moderate chronic obstructive pulmonary disease (UPLIFT): a prespecified subgroup analysis of a randomised controlled trial. Lancet. 2009;374(9696):1171–8. 10.1016/S0140-6736(09)61298-8 19716598
88 Tashkin DP, Celli BR, Decramer M, . Efficacy of tiotropium in COPD patients with FEV1 >/= 60% participating in the UPLIFT(R) trial. Copd. 2012;9(3):289–96. 10.3109/15412555.2012.656211 22432932
89 Haroon SM, Jordan RE, O’Beirne-Elliman J, . Effectiveness of case finding strategies for COPD in primary care: a systematic review and meta-analysis. NPJ Primary Care Respiratory Medicine. 2015;25:15056. 10.1038/npjpcrm.2015.56
90 Katsimigas A, Tupper OD, Ulrik CS. Opportunistic screening for COPD in primary care: a pooled analysis of 6,710 symptomatic smokers and ex-smokers. International Journal of Copd. 2019;14:1633–8. 10.2147/COPD.S204190 31413558
91 Hemmingsen UB, Stycke M, Dollerup J, . Guideline-Based Early Detection of Chronic Obstructive Pulmonary Disease in Eight Danish Municipalities: The TOP-KOM Study. Pulm Med. 2017;2017:7620397. 10.1155/2017/7620397 28321336
92 Preteroti M, Whitmore GA, Vandemheen KL, . Population-based case-finding to identify subjects with undiagnosed asthma or COPD. European Respiratory Journal. 2020;55(6). 10.1183/13993003.00024-2020
93 Balata H, Harvey J, Barber PV, . Spirometry performed as part of the Manchester community-based lung cancer screening programme detects a high prevalence of airflow obstruction in individuals without a prior diagnosis of COPD. Thorax. 2020;75(8):655–60. 10.1136/thoraxjnl-2019-213584 32444437
94 Ruparel M, Quaife SL, Dickson JL, . Prevalence, Symptom Burden, and Underdiagnosis of Chronic Obstructive Pulmonary Disease in a Lung Cancer Screening Cohort. Annals of the American Thoracic Society. 2020;17(7):869–78. 10.1513/AnnalsATS.201911-857OC 32164439
95 Marcos PJ, Malo de Molina R, Casamor R. Risk stratification for COPD diagnosis through an active search strategy in primary care. International Journal of Copd. 2016;11:431–7. 10.2147/COPD.S98659 27042035
96 Haroon S, Adab P, Riley RD, . Predicting risk of undiagnosed COPD: development and validation of the TargetCOPD score. European Respiratory Journal. 2017;49(6):06. 10.1183/13993003.02191-2016
97 Ray E, Culliford D, Kruk H, . Specialist Respiratory Outreach: a case-finding initiative for identifying undiagnosed COPD in primary care. 2020.
98 Soriano JB, Molina J, Miravitlles M. Combining case-finding methods for COPD in primary care: a large, two-stage design study. Int J Tuberc Lung Dis. 2018;22(1):106–11. 10.5588/ijtld.17.0334 29297434
99 Wu J, Ye Y, Li C, . Correlation of Inhaled Long-Acting Bronchodilators With Adverse Cardiovascular Outcomes in Patients With Stable COPD: A Bayesian Network Meta-Analysis of Randomized Controlled Trials. J Cardiovasc Pharmacol. 2019;74(3):255–65. 10.1097/FJC.0000000000000705 31306366
100 Yang M, Zhang Y, Cheng H, . Association of tiotropium use and the risk of adverse cardiovascular events in patients with chronic obstructive pulmonary disease: a meta-analysis of randomized controlled trials. Eur J Clin Pharmacol. 2020;76(6):795–805. 10.1007/s00228-020-02853-9 32274526
101 Zhang Q, Li S, Zhou W, . Risk of Pneumonia with Different Inhaled Corticosteroids in COPD Patients: A Meta-Analysis. Copd. 2020:1–8. 10.1080/15412555.2020.1787369
102 Tricco AC, Strifler L, Veroniki AA, . Comparative safety and effectiveness of long-acting inhaled agents for treating chronic obstructive pulmonary disease: a systematic review and network meta-analysis. BMJ Open. 2015;5(10):e009183. 10.1136/bmjopen-2015-009183
103 Tashkin DP. Smoking Cessation in Chronic Obstructive Pulmonary Disease. Semin. 2015;36(4):491–507. 10.1055/s-0035-1555610
104 Arabyat RM, Raisch DW, Bakhireva L. Influenza vaccination for patients with chronic obstructive pulmonary disease: Implications for pharmacists. Res Social Adm Pharm. 2018;14(2):162–9. 10.1016/j.sapharm.2017.02.010 28533080
105 van Eerd EA, van der Meer RM, van Schayck OC, . Smoking cessation for people with chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2016(8):CD010744. 10.1002/14651858.CD010744.pub2
106 Trethewey SP, Patel N, Turner AM. Interventions to Increase the Rate of Influenza and Pneumococcal Vaccination in Patients with Chronic Obstructive Pulmonary Disease: A Scoping Review. Medicina (Kaunas). 2019;55(6). 10.3390/medicina55060277
107 Danielsen SE, Lochen ML, Medbo A, . A new diagnosis of asthma or COPD is linked to smoking cessation - the Tromso study. International Journal of Copd. 2016;11:1453–8. 10.2147/COPD.S108046 27418818
108 Schauer GL, Wheaton AG, Malarcher AM, . Health-care Provider Screening and Advice for Smoking Cessation Among Smokers With and Without COPD: 2009-2010 National Adult Tobacco Survey. Chest. 2016;149(3):676–84. 10.1378/chest.14-2965 26291388
109 Melzer AC, Feemster LC, Crothers K, . Respiratory and Bronchitic Symptoms Predict Intention to Quit Smoking among Current Smokers with, and at Risk for, Chronic Obstructive Pulmonary Disease. Annals of the American Thoracic Society. 2016;13(9):1490–6. 10.1513/AnnalsATS.201601-075OC 27268422
110 Kotz D, Wesseling G, Huibers MJ, . Efficacy of confronting smokers with airflow limitation for smoking cessation. Eur Respir J. 2009;33(4):754–62. 10.1183/09031936.00116308 19129277
111 McClure JB, Ludman E, Grothaus L, . Immediate and short-term impact of a brief motivational smoking intervention using a biomedical risk assessment: the Get PHIT trial. Nicotine Tob Res. 2009;11(4):394–403. 10.1093/ntr/ntp004 19299409
112 Parkes G, Greenhalgh T, Griffin M, . Effect on smoking quit rate of telling patients their lung age: the Step2quit randomised controlled trial. Bmj. 2008;336(7644):598–600. 10.1136/bmj.39503.582396.25 18326503
113 Risser NL, Belcher DW. Adding spirometry, carbon monoxide, and pulmonary symptom results to smoking cessation counseling: a randomized trial. J Gen Intern Med. 1990;5(1):16–22. 10.1007/bf02602303 2405112
114 Sippel JM, Osborne ML, Bjornson W, . Smoking cessation in primary care clinics. J Gen Intern Med. 1999;14(11):670–6. 10.1046/j.1525-1497.1999.11088.x 10571715
115 Ronaldson SJ, Dyson L, Clark L, . The impact of lung function case-finding tests on smoking behaviour: A nested randomised trial within a case-finding cohort. Health Sci Rep. 2018;1(6):e41. 10.1002/hsr2.41 30623078
116 McCarthy B, Casey D, Devane D, . Pulmonary rehabilitation for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2015(2):CD003793. 10.1002/14651858.CD003793.pub3 25705944
117 Higashimoto Y, Ando M, Sano A, . Effect of pulmonary rehabilitation programs including lower limb endurance training on dyspnea in stable COPD: A systematic review and meta-analysis. Respir Investig. 2020;58(5):355–66. 10.1016/j.resinv.2020.05.010
118 Jácome C, Marques A. Short- and Long-term Effects of Pulmonary Rehabilitation in Patients With Mild COPD: A COMPARISON WITH PATIENTS WITH MODERATE TO SEVERE COPD. Journal of cardiopulmonary rehabilitation and prevention. 2016;36(6):445–53. 10.1097/hcr.0000000000000219 27779550
119 Schroff P, Hitchcock J, Schumann C, . Pulmonary Rehabilitation Improves Outcomes in Chronic Obstructive Pulmonary Disease Independent of Disease Burden. Ann Am Thorac Soc. 2017;14(1):26–32. 10.1513/AnnalsATS.201607-551OC 27739881
120 Korkmaz Ekren P, Gürgün A, Elmas Uysal F, . Effects of pulmonary rehabilitation in patients with mild-to-moderate chronic obstructive pulmonary disease: Bottom of an iceberg. Turk J Phys Med Rehabil. 2018;64(2):162–9. 10.5606/tftrd.2018.1006 31453507
121 Nici L, Mammen MJ, Charbek E, . Pharmacologic management of chronic obstructive pulmonary disease. An official American Thoracic Society clinical practice guideline. American journal of respiratory and critical care medicine. 2020;201(9):e56–e69.32283960
122 Celli BR, Anderson JA, Cowans NJ, . Pharmacotherapy and Lung Function Decline in Patients with Chronic Obstructive Pulmonary Disease: A Systematic Review. American Journal of Respiratory & Critical Care Medicine. 2020;23:23. 10.1164/rccm.202005-1854OC
123 Agusti A, Celli B, Faner R. What does endotyping mean for treatment in chronic obstructive pulmonary disease? Lancet. 2017;390(10098):980–7. 10.1016/S0140-6736(17)32136-0 28872030
124 Cheng SL, Lin CH, Wang CC, . Comparison between COPD Assessment Test (CAT) and modified Medical Research Council (mMRC) dyspnea scores for evaluation of clinical symptoms, comorbidities and medical resources utilization in COPD patients. Journal of the Formosan Medical Association. 2019;118(1 Pt 3):429–35. 10.1016/j.jfma.2018.06.018 30150099
125 Global Initiative for Chronic Obstructive Lung Disease. Global Strategy for the Diagnosis, Management, and Prevention of Chronic Obstructive Pulmonary Disease: 2021 Report. https://goldcopd.org/wp-content/uploads/2020/11/GOLD-REPORT-2021-v1.1-25Nov20_WMV.pdf. Accessed: 2021.
126 UK National Screening Committee. UK NSC recommendation on Chronic Obstructive Pulmonary Disease. https://legacyscreening.phe.org.uk/copd. Accessed: 2020.
127 Guirguis-Blake JM, Senger CA, Webber EM, . Agency for Healthcare Research and Quality (US). 2016:04.
128 Kotz D, Wesseling G, Huibers MJ, . Efficacy of confrontational counselling for smoking cessation in smokers with previously undiagnosed mild to moderate airflow limitation: study protocol of a randomized controlled trial. BMC Public Health. 2007;7:332. 10.1186/1471-2458-7-332 18005415
129 Kotz D, Vos R, Huibers MJ. Ethical analysis of the justifiability of labelling with COPD for smoking cessation. J Med Ethics. 2009;35(9):534–40. 10.1136/jme.2009.029280 19717691
130 Kotz D, Huibers MJ, West RJ, . What mediates the effect of confrontational counselling on smoking cessation in smokers with COPD? Patient Educ Couns. 2009;76(1):16–24. 10.1016/j.pec.2008.11.017 19150590
131 McClure JB, Ludman EJ, Grothaus L, . Impact of a brief motivational smoking cessation intervention the Get PHIT randomized controlled trial. Am J Prev Med. 2009;37(2):116–23. 10.1016/j.amepre.2009.03.018 19524389
132 McClure JB, Ludman EJ, Grothaus L, . Impact of spirometry feedback and brief motivational counseling on long-term smoking outcomes: a comparison of smokers with and without lung impairment. Patient Educ Couns. 2010;80(2):280–3. 10.1016/j.pec.2009.11.002 20434863
133 Morris JF, Temple W. Spirometric “lung age” estimation for motivating smoking cessation. Prev Med. 1985;14(5):655–62. 10.1016/0091-7435(85)90085-4 4070195