# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Brandy Peaker, MD, MPH, and Howard Tracer, MD, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Barbara Yawn, MD, MSc, FAAFP; Richard Mularski, MD, MSHS, MCR; and Jerry Krishnan MD, PhD, who provided expert review of the draft report; the Centers for Disease Control and Prevention for providing federal partner review of the draft report; and Melinda Davies, MAIS, and Jill Pope, BA, for technical and editorial assistance at the Center for Health Research.