# Chapter 4 Discussion

## Summary of Findings and Comparison to Last Review

### Effectiveness of Screening for COPD

To date, there are still no completed studies evaluating the effectiveness of screening or active case finding for COPD on patient health outcomes (i.e., improves COPD morbidity, mortality or HRQoL) (Table 17). However, there are many studies, not included in this review, that demonstrate that active case finding (i.e., systematically assessing for symptoms and/or risk factors and performing spirometry) can identify persons yet undiagnosed with COPD, the vast majority of which are single arm or uncontrolled studies evaluating the yield of COPD.^89–94^ Comparative studies evaluating systematic screening approaches demonstrate that active case finding identifies more COPD than usual care.^89,^ ^95–97^ Overall these studies, mostly conducted outside the US, evaluate a range of approaches (i.e., use of questionnaires, electronic case-finding algorithms, handheld flow meters, coupling spirometry to lung cancer screening, direct invitation to spirometry); regardless of the approach, studies targeting those at higher risk (e.g., based on smoking history, occupational exposure) or those using pre-screening questionnaires can identify many persons with yet undiagnosed COPD. And use of pre-screening questionnaires in case finding can reduce the number of spirometry tests performed.^98^

Table 17 Summary of Targeted Evidence Update in the Context of the Prior Systematic Review to Support the 2016 USPSTF Screening for COPD Recommendation^*^

| Evidence summary in 2016 | New evidence findings | Limitations of new evidence | Consistency of new evidence with prior evidence findings
KQ1: Effectiveness of screening | No trials evaluated the effectiveness of screening or active case finding for COPD on patient health outcomes (i.e., COPD morbidity, mortality, HRQoL). | No published or ongoing trials identified. | NA | NA
KQ2: Treatment benefits in screen relevant populations | Overall, the included treatment evidence (14 trials^†^) for bronchodilators and ICS was largely limited to subgroup analyses, almost exclusively among individuals with moderate, and primarily the more severe end of moderate, COPD (e.g., FEV_1_ 60% predicted). Even among these groups, the only consistent benefit observed was reduced COPD exacerbations with no consistent benefits in mortality, dyspnea, or HRQoL. | Based on 3 trials, LABA, LAMA, ICS or LABA/ICS can reduce COPD exacerbations in persons with moderate COPD. Based subgroup analyses from one trial, LAMA (i.e., tiotropium) can reduce clinically important deterioration (composite outcome) in persons with moderate COPD and exacerbations in minimally symptomatic (i.e., GOLD category A) persons with moderate airflow obstruction.; Based on 13 trials, no consistent benefit for a range of non-pharmacologic interventions (i.e., self-management, exercise counseling, supervised exercise, pulmonary rehabilitation, clinician education) observed across multiple outcomes. | Subgroup analysis of LAMA in GOLD category A limited to 357 persons.; Non-pharmacologic intervention trials were generally small, had usual comparator groups in settings which may provide more care than typically received in the US, and/or had suboptimal uptake of the intervention, all of which may limit the ability to detect a true benefit. | Generally consistent for limited benefit of bronchodilators and ICS for reduction in exacerbation outcomes only in mainly persons with moderate COPD with unclear wider applicability to screen-detected persons with COPD.; Signal for benefit of tiotropium for COPD on exacerbations in minimally symptomatic persons who may be more representative of a screen-detected population despite moderate airflow obstruction.; New evidence for non-pharmacologic interventions with no consistent benefit across different outcomes.
KQ3: Treatment harms in screen relevant populations | Overall, limited data on serious harms reported in included treatment trials (8 trials) suggested no substantial serious adverse effects for most bronchodilators and ICS. | Based on 3 trials and 2 large observational studies, initiation of LAMA or LABA is associated with an increase in risk of serious cardiovascular events and treatment with ICS is associated with an increase in the risk of developing diabetes. Three self-management intervention trials did not demonstrate any serious harms. | Harms are not consistently reported in trials of pharmacologic and non-pharmacologic interventions. Treatment trials are limited in their ability to detect uncommon or longer-term harms. | Generally consistent for no serious harms from treatment trials, but large observational studies in screen-relevant populations suggest possible harms for LAMA or LABA initiation or use of ICS. Evidence, not limited to screen-relevant populations, suggest that LABA, but not LAMA, can increase risk of cardiovascular disease, and long-term ICS use may adversely affect bone health.
CQ: COPD diagnosis on recommender preventive services | Overall, the included evidence (5 studies) did not demonstrate a benefit for the incremental value of adding spirometry to smoking cessation. And no studies evaluated spirometry or the incremental benefit of having a diagnosis of COPD on vaccination uptake. | Based on 3 included non-pharmacologic intervention trials and 1 additional comparative study looking at receipt of spirometry results (or ‘lung age’), detection of COPD did not increase smoking cessation. One trial evaluating clinician education demonstrated an increase in the uptake of influenza vaccination. | Limited evidence with varying study designs evaluating the benefit of screening for COPD on the uptake of preventive services. | Generally consistent for no consistent benefit of spirometry or screening for COPD on smoking cessation. Benefits were only observed in one trial that has not yet been reproduced. Still no comparative studies demonstrating the incremental benefit of spirometry or identification of COPD on uptake of recommended vaccinations or lung cancer screening.

* Questions around the diagnostic accuracy and inaccuracy (harms) of questionnaires, spirometry and other screeners were not addressed in this review

† Two long-acting beta agonist (LABA) studies, one ICS-LABA combination study, five tiotropium studies (LAMA), and six ICS studies

Abbreviations: COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in one second; GOLD = Global Initiative for Chronic Obstructive Lung Disease; HRQol = health related quality of life; ICS = inhaled corticosteroid; IG = intervention group; LABA = long-acting beta agonist; LAMA = long acting muscarinic antagonist; NA = not applicable

Currently, there is one cluster RCT, COPD Assessment in Primary Care To Identify Undiagnosed Respiratory Disease and Exacerbation Risk (CAPTURE), of screening for COPD underway (Appendix E Table 1).^47^ This trial evaluates screening with a 5-item questionnaire and peak flow measurement in persons ages 45 to 80 years old in primary care, without any restrictions on smoking history. It has a planned 5-year follow-up and includes outcomes on changes to clinical care, patient symptoms, exacerbations, hospitalizations and mortality. This trial is scheduled to be completed in July 2022.

### Treatment of Screen-Relevant COPD

Similar to the previous review’s findings, we found no trials of pharmacologic treatment of COPD in screen-detected patients. However, we did identify 16 trials, or subgroup analyses from trials, evaluating the treatment of mild to moderate, or minimally symptomatic, COPD which met our inclusion criteria for screen-relevant COPD (Table 17).^66–80,^ ^86^ Three of these trials evaluated inhaled bronchodilators (LABA or LAMA) and/or ICS, one of which (UPLIFT) was included in the previous systematic review to support the 2016 recommendation.^75,^ ^76,^ ^82^ Overall, the results of these trials and their subgroup analyses are consistent with the previous review’s findings that bronchodilators (LABA or LAMA) with or without ICS can reduce COPD exacerbations and LAMA (i.e., tiotropium) can improve HRQoL (as measured by the SGQR) in adults with fairly symptomatic moderate COPD. In 2016, the USPSTF stated that the evidence in these populations (e.g., mean FEV_1_ 60 percent predicted) was not widely applicable to persons with COPD identified through screening. In this update, one small subgroup analysis (n=357) of UPLIFT demonstrated that tiotropium compared to placebo can reduce exacerbations in patients with minimally symptomatic moderate COPD at 48 months.

Since the previous review, we have also newly included 13 trials evaluating non-pharmacologic interventions in mild to moderate, or minimally symptomatic, COPD.^66–71,^ ^73,^ ^74,^ ^77–80,^ ^86^ Unfortunately, these trials evaluating a range of interventions (i.e., self-management interventions, exercise counseling interventions, supervised exercise and pulmonary rehabilitation interventions, and clinician education interventions) did not demonstrate a consistent benefit across a range of patient outcomes. Only one VA trial (n=114) evaluating a web-based self-management intervention focused on exercise (‘step count’) found a reduction in COPD exacerbations at 65 weeks in persons with moderate COPD (i.e., mean FEV_1_ 63 percent predicted).^78^ However, other trials of self-management interventions, supervised exercise, and pulmonary rehabilitation interventions in person with mild to moderate COPD, or minimal symptoms, did not demonstrate a reduction in exacerbations or other outcomes. It is unclear if and how the small samples sizes in these trials, usual care comparators outside the United States (only two US based studies), and/or poor adherence to interventions contributed to the largely null findings observed in these non-pharmacologic intervention trials.

Similar to the previous review, there was very limited included evidence on the harms from included treatment trials. None of the included trials that reported adverse effects found significant harms. However, these trials generally have a limited ability to detect uncommon harms or longer-term harms. Two large observational studies addressing harms of medications demonstrated that initiation of LAMA or LABA may increase the risk of a serious cardiovascular event in treatment-naïve patients and that ICS may increase the risk of developing diabetes.^81,^ ^82^ External to this review, meta-analyses of treatment trials examining harms have demonstrated that LABAs, but not LAMAs, may increase cardiovascular events (specifically heart failure).^99,^ ^100^ Existing reviews and meta-analyses of treatment trials examining harms of ICS (alone or in combination with LABAs) have demonstrated an increased risk of pneumonia, but these findings may be drug specific.^101,^ ^102^

### Screening for COPD Impact on Uptake of Smoking Cessation, Vaccinations, and Lung Cancer Screening

Smoking cessation, vaccinations, and lung cancer screening in persons who meet criteria are important components of disease management for COPD. However, despite guidelines recommending these preventive services, smoking cessation in active smokers (and recidivism after initial cessation),^103^ as well as uptake of influenza and pneumococcal vaccination,^104^ remain suboptimal. Thus, interventions to increase smoking cessation success and vaccinations in persons with COPD remain an active area of research.^105,^ ^106^ Observational studies suggest that a new diagnosis of COPD is linked to smoking cessation, that smokers with COPD are more likely than those without COPD to be advised to quit smoking and offered smoking cessation support and followup, and that persons with symptomatic COPD (i.e., frequent cough, phlegm, wheeze, shortness of breath, higher symptom score) have greater odds of intention to quit smoking.^107–109^

Three included RCTs evaluating non-pharmacologic interventions reported smoking cessation outcomes and did not demonstrate a benefit for self-management interventions or clinician education/training on these outcomes (Table 14).^69,^ ^77,^ ^80^ We also considered whether identifying undiagnosed COPD might improve the uptake of other recommended preventive services (including but not limited to smoking cessation). In addition to the included trials, six RCTs (n=2,294) designed to evaluate the incremental benefit of receipt of spirometry results or ‘lung age’ (i.e., to approximate the impact of screening or case finding for COPD on smoking cessation) have not consistently shown that receipt of spirometry results or ‘lung age’ increases smoking cessation (Tables 17 and 18).^110–115^ Only one of these trials (n=561), conducted in the UK and included in the prior review, evaluating the incremental value of ‘lung age’ to standardized smoking cessation counseling, reported a statistically significant difference in biochemically confirmed abstinence from smoking at 1 year.

Table 18 Contextual Question: RCTs Evaluating Spirometry or “Lung Age” on Smoking Cessation Outcomes Screening

Study, Year | Country | N Randomized | Population | Treatment Comparison | Followup | Smoking abstinence
Kotz, 2009^110,^ ^128–130^ | Netherlands | 296 | Smokers aged 35-70 years; ≥1 respiratory symptom and mild or moderate COPD | Smoking cessation support with or without discussion of spirometry | 52 weeks | Adjusted OR: 0.88 (95% CI, 0.38 to 2.03)^*^
McClure, 2009^111,^ ^131,^ ^132^ | US | 542 | Smokers aged ≥18 years | Smoking cessation support with spirometry results vs. smoking cessation support and “lung age”^†^ | 52 weeks | 30-day abstinence: OR: 0.77 (95% CI NR); p=0.34^‡^; 7-day abstinence: OR: 0.86 (95% CI NR); p=0.38^‡^
Parkes, 2008^112^ | UK | 561 | Smokers aged ≥35 years | Smoking cessation support with spirometry results vs. smoking cessation support and “lung age”^§^ | 52 weeks | Between group difference: 7.2% (95% CI: 2.2% to 12.1%)^*^
Risser, 1990^113^ | US | 90 | Smokers in VA Demonstration Project | Smoking cessation support with or without discussion of spirometry | 52 weeks | IG: 20.0%, CG 6.7%, p=0.06^*,,ǁ^
Ronaldson, 2018^115^ | UK | 674 | Smokers aged ≥35 years | Lung function testing and COPD case finding vs waitlist control | 24 weeks | Adjusted OR: 1.00 (95% CI, 0.57 to 1.77)^‡^
Sippel, 1999^114^ | US | 205 | Smokers aged ≥18 | Smoking cessation support with or without discussion of spirometry | 39 weeks | Adjusted OR: 0.6 (95% CI, 0.2 to 1.4)^‡^

* Biochemically validated smoking cessation

† Calculated using method Morris and Temple method^133^

‡ Self-reported smoking cessation

§ Men: Lung age= 2.87 × height (in inches) – (31.25 × observed FEV_1_ (liters) - 39.375; Women: Lung age= 3.56 × height (in inches) – (40 × observed FEV_1_ (liters) - 77.28

ǁ Self-reported smoking cessation- IG: 24.4%, CG: 11.1% (p=0.08)

Abbreviations: CI = confidence interval; COPD = chronic obstructive pulmonary disease; N = number; NR = not reported; OR = odds ratio; UK = United Kingdom; US = United States; VA = Veteran’s Affairs; VS = versus.

Unfortunately, comparative studies to address how identifying COPD impacts other recommended preventive services remain quite limited. Only one included RCT evaluating non-pharmacologic interventions reported on uptake of vaccinations.^80^ This cluster RCT by Zwar and colleagues, conducted in Australia, evaluated clinician training on team-based management of COPD. At 52 weeks, 72.8 percent of patients of clinicians in the intervention group, compared to 56.8 percent of patients of clinicians in the control group, were vaccinated for influenza (p=0.035), and 47.9 percent in the intervention group compared to 38.3 percent were vaccinated for pneumococcus; however, results were not statistically significant for pneumococcal vaccination (p=0.15). We found no comparative studies on the incremental benefit of spirometry or diagnosis of COPD on uptake of vaccinations or lung cancer screening.

## Limitations and Future Research Needs

This review was a targeted evidence update aimed at addressing the interval evidence on key evidence gaps identified in the 2016 USPSTF recommendation on Screening for COPD. As such, this review only updated a subset of the key questions previously addressed. This targeted evidence update did not address the screening yield or screening accuracy of various screening or active case-finding approaches. Nonetheless, it is clear from non-comparative and comparative studies that a variety of organized screening approaches in persons at risk for COPD (e.g., risk algorithms, pre-screening questionnaires, handheld devices) can identify yet undiagnosed COPD and more undiagnosed COPD than opportunistic case finding. Likewise, we did not evaluate the screening harms represented by the diagnostic inaccuracy for various screening approaches (i.e., false negatives and false positives). Populations at very high risk for COPD, in whom surveillance for COPD is generally recommended (e.g., persons with alpha-1 antitrypsin deficiency and workers with known occupational exposures) were not included in this review and therefore the findings do not apply to the use of periodic spirometry in occupational settings or specialty care.

Given the absence of direct evidence that screening or active case finding for COPD improves COPD morbidity, mortality, or patient HRQoL, this review focuses on the benefits and harms of treatment in screen-detected populations. Because we found limited intervention trials in these populations, we also included trials that were conducted, or reported subgroup analyses, in persons with mild to moderate COPD or who were minimally symptomatic (based on GOLD criteria). Trials or analyses conducted in populations following an acute COPD exacerbation were also excluded. We acknowledge that persons with more severe airflow obstruction or with greater symptom burden are identified with screening or active case-finding; and that severity of airflow obstruction does not necessarily correlate with symptom burden. This population focus necessarily restricted the number of treatment studies included, which resulted in the lack or under-representation of certain types of therapies (e.g., combination inhaled therapies, anti-inflammatory therapies, pulmonary rehabilitation). Although we included pulmonary rehabilitation trials aimed at persons with mild to moderate COPD or who were minimally symptomatic, the vast majority of trials evaluating pulmonary rehabilitation are not in these populations. Pulmonary rehabilitation, in general, has been demonstrated to improve exercise capacity, dyspnea, and quality of life in persons with COPD.^116,^ ^117^ Furthermore, there is evidence to suggest that pulmonary rehabilitation can result in improvement in these outcomes independent of baseline disease burden, such that persons with mild or moderate COPD may benefit similarly to those with more severe airflow obstruction.^118–120^ This population focus also restricted the number of studies addressing harms, as most of the observational studies addressing harms of pharmacologic therapies did not report disease or symptom severity. We also a priori excluded other intervention types that may have been studied in relevant populations (e.g., acupuncture, neuromuscular electrostimulation, Tai Chi or other active mind-body movement therapies, focused upper limb exercise training).

Our targeted update, as well as the prior review to support the 2016 USPSTF recommendation, focused on the impact of screening and treatment on a priori defined health outcomes. We did not include physiologic changes in FEV_1_ as an outcome. Currently both GOLD and the American Thoracic Society state that there is not conclusive evidence that pharmacotherapy modifies the long-term decline in lung function^10,^ ^121^ However, placebo controlled trials of pharmacologic therapies have demonstrated that LAMA (tiotropium), LABA (salmeterol, vilanterol) and ICS (fluticasone, budesonide) can reduce the decline of FEV_1_ by about 5mL/year in trials reporting follow-up from 40 to 60 months.^122^

Based on this update, we identify a few important evidence gaps and suggestions for future research. First, we acknowledge that early COPD is not synonymous with mild COPD and that true identification of early disease would allow for intervening at a stage which may prevent pulmonary function impairment or decline.^8^ Ongoing research is currently addressing these issues around diagnosis and treatment based on the pathobiological mechanisms (and their biomarkers) to develop and deliver treatment that can modify the natural course of disease, rather than symptom-based treatment.^123^

Second, since airflow obstruction and symptom burden do not necessarily correlate, it is important to characterize populations by both of these dimensions. Many trials report airflow obstruction as a baseline characteristic and subgroup analyses by severity of airflow obstruction. It would be as helpful to have parallel data for symptom burden or by GOLD categories A through D, or using other measures of symptoms. The mMRC is limited to one question on dyspnea and does not capture other symptoms. The 8-item CAT has been shown to be a more effective assessment for symptom severity in COPD patients.^124^

Third, the lack of consistent treatment benefit observed in persons with mild to moderate or minimally symptomatic COPD does not mean that treatment cannot benefit these persons. Included trials, and their subgroup analyses, are limited by small samples and single trials/analyses. In patients with low symptom burden, it may be difficult to demonstrate clinically meaningful improvement using current HRQoL or symptom scales due to already low scores (i.e., floor effect), and demonstrating a benefit on morbidity or mortality from COPD may require longer-term followup (than in current trials) in persons with less severe disease. For many of the non-pharmacologic intervention trials not conducted in the US, the usual care arm may have already been receiving care beyond standard of care in the US, therefore making it more difficult for these trials to show a benefit. Future research should include treatment studies to replicate findings of tiotropium in minimally symptomatic persons using a range of outcomes; trials or (more realistically) well conducted comparative observational studies in persons with minimal symptoms or airflow obstruction evaluating the association of treatment and longer-term COPD morbidity and mortality; and replication of successful non-pharmacologic interventions in US screen-relevant populations. A scan of ongoing studies shows several trials designed to evaluate non-pharmacologic interventions, however, none are in the United States (Appendix E Table 1).

Last, to date there are still no comparative studies evaluating the benefit of screening or active case finding on patient health outcomes. Comparative studies evaluating screening or active case finding on yield of COPD diagnoses should include longer-term followup to determine the impact on quality of life, COPD morbidity and mortality, as well as smoking cessation outcomes, and uptake of recommended vaccinations and lung cancer screening. The CAPTURE trial currently underway will provide direct evidence for the effectiveness of screening for COPD in the United States (Appendix E Table 1).^47^

## Conclusions

The findings of this targeted evidence update are generally consistent with the findings of the previous systematic review that supported the USPSTF’s 2016 recommendation not to routinely screen for COPD. There are still no comparative studies on the effectiveness of screening or active case finding for COPD on patient health outcomes, although one is currently underway. The observed benefits of pharmacologic therapies for COPD are still largely limited to persons with moderate airflow obstruction. There was no consistent benefit of a range of non-pharmacologic interventions in mild to moderate, or minimally symptomatic persons with COPD. In general, harms of pharmacologic and non-pharmacologic interventions are not consistently reported in treatment trials, although large observational studies suggest harms for the initiation of LAMA or LABA and the longer-term use of ICS in persons with COPD.