# Chapter 3 Results

## Literature Search

Results of this search represent literature published since the previous systematic review on this topic. We screened 6387 abstracts and assessed 229 full-text articles for inclusion (Appendix B Figure 1). After screening the full-text articles, no studies were included for KQ1, 16 studies (in 28 articles)^66–80^ were included for KQ2, and eight studies (in 20 articles) for KQ3.^69,^ ^72,^ ^75,^ ^76,^ ^78,^ ^81,^ ^82^ The full list of included studies and their ancillary articles is available in Appendix C. The list of excluded studies with reasons for their exclusion is available in Appendix D.

## KQ1 Does Screening for COPD Improve Health-Related Quality of Life or Reduce Morbidity or Mortality?

### Summary of Results

We found no trials examining the effectiveness of screening or active case finding for COPD on health outcomes. Screening or active case-finding studies to date are limited to describing the yield of COPD cases (Chapter 4: Discussion).

## KQ2 Does Treatment of Screen Detected or Mild to Moderate COPD Improve Health-Related Quality of Life or Reduce Morbidity or Mortality?

### Summary of Results

We included 16 trials evaluating the treatment of mild to moderate, or minimally symptomatic, COPD.^66–80,^ ^82^ Three of these trials (n=20,058) evaluated inhaled bronchodilators (LAMA, LABA) and/or ICS,^72,^ ^75,^ ^76^ and 13 trials (n=3,658).^66–74,^ ^77–80^ evaluated non-pharmacologic interventions (i.e., self-management interventions, exercise counseling interventions, supervised exercise and pulmonary rehabilitation interventions, and clinician education interventions).^66–71,^ ^73,^ ^74,^ ^77–80^

One large RCT (SUMMIT) (n=16,590) demonstrated that LABA, ICS or LABA/ICS could reduce the annual rate of exacerbations in adults with fairly symptomatic (i.e., mean SGRQ score 45-46 or CAT score 18-19) moderate COPD (i.e., mean FEV_1_ 59.7% predicted) with a median followup of 1.8 years.^76,^ ^83^ Subgroup analyses of another RCT (UPLIFT) demonstrated that LAMA could reduce clinically important deterioration (including clinically significant difference in SGRQ and exacerbations) in persons with moderate COPD (i.e., mean FEV_1_ 59% predicted) (n=2603)^84^ and reduce exacerbations in patients with minimal symptoms (i.e., GOLD category A) (n=357) at 48 months.^85^

Although a large variety of non-pharmacologic interventions were studied, overall, there was no consistent benefit observed across a range of outcomes (i.e., exacerbations, HRQoL, dyspnea, exercise or physical performance measures, mental health, smoking cessation) at 26 to 104 weeks. Two RCTs (n=114 and 239) evaluated the same exercise-focused web-based intervention in a VA population.^78,^ ^86^ Only one of these two trials (n=114) demonstrated a reduction in COPD exacerbations at 65 weeks,^78^ the other trial (n=239) found no reduction in a composite outcome of exacerbations and pneumonia at 52 weeks.^86^ Other trials, not conducted in the US, evaluating more intensive self-management interventions, supervised exercise, and pulmonary rehabilitation interventions in persons with mild to moderate COPD, or minimal symptoms, did not demonstrate a reduction in exacerbations or other outcomes. One cluster RCT (n=254 patients) evaluating clinician education/training demonstrated an increase in influenza vaccination, but not pneumococcal vaccination or other outcomes at 52 weeks (Chapter 4: Discussion).^80^ It is unclear if and how small sample sizes, usual care comparators in trials conducted outside the US, and/or poor adherence to the interventions contributed to the largely null findings of these trials.

### Included Studies

#### Pharmacologic Interventions

We found three studies with newly published analyses in mild to moderate COPD, or minimally symptomatic persons (i.e., GOLD category A) since the 2016 recommendation (Tables 3 and 4). Two studies (PINNACLE and SUMMIT) evaluated LABAs, two studies (PINNACLE and UPLIFT) evaluated LAMAs, one study (PINNACLE) evaluated LABA/LAMA, and one study (SUMMIT) evaluated ICS with or without LABA.

Table 3 Key Question 2 Results: Study Characteristics for Included RCTs of Pharmacologic Treatment

Study, Year; Quality | Country | N Randomized | Followup | Inclusion | Exclusion | Treatment Comparison | Concomitant therapies allowed
PINNACLE; Martinez, 2020^72^; Fair | International | 4983 (full population); GOLD category A subset: 729 | 24 weeks | 40-80 years; smoking history of ≥10 pack-years; Post-BD FEV_1_<80% predicted; FEV_1_/FVC≤70% | Significant diseases other than COPD; pregnant/ lactating women; lung volume reduction surgery within last year; hospitalization due to COPD within 3 months or during screening; smoking status change during screening; long-term oxygen therapy required > 12 hours/day | IG1: LAMA/LABA glycopyrrolate/formoterol fumarate (18/9.6 µg/twice a day); IG2: LAMA glycopyrrolate (18 µg/twice a day); IG3: LABA formoterol fumarate (9.6 µg/twice a day); CG: Placebo | Patients receiving stable dose of ICS at screening were permitted to continue
SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^; Good | International | 16,590 | 4 years^*^ | 40-80 years; smoking history of ≥10 pack-years; Post-BD FEV_1_ 50-70% predicted; FEV_1_/FVC≤70%; score of ≥2 on mMRC dyspnea scale; history or increased risk of cardiovascular disease^†^ | Respiratory disorders other than COPD, lung reduction surgery, receiving long-term oxygen, or oral corticosteroid therapy, severe heart failure, life expectancy less than 3 years, and end-stage chronic renal disease | IG1: ICS/LABA fluticasone furoate/vilanterol (100/25 μg/day); IG2: LABA vilanterol (25 μg/day); IG3: ICS fluticasone furoate (100 μg/day); CG: Placebo | All ICS, LABA, and LAMA were discontinued, although other COPD medications such as theophyllines were allowed
UPLIFT; Decramer, 2009^87^,^‡^; Tashkin, 2012^88^,^‡^; Tashkin, 2008^75^,^‡^; Halpin, 2015^85^; Rabe, 2020^84^; Fair | International | 5993 (full population)^75^; Stage II subset: 2739^84,^ ^87^; FEV_1_≥60% subset: 1210^88^; GOLD category A subset: 357^85^ | 4 years | ≥ 40 years; smoking history of ≥10 pack-years; Post-BD FEV_1_<70% predicted; FEV_1_/FVC≤70%^§^ | History of asthma, COPD exacerbation or respiratory infection within 4 weeks before screening, a history of pulmonary resection, long-term oxygen therapy required > 12 hours/day | IG: LAMA tiotropium bromide (18 µg/day); CG: Placebo | All respiratory medications except other SAMA or LAMA

* Maximum followup was 4 years; median study exposure was 1.8 years (IQR 1.2-2.6) and was similar across treatment groups

† Cardiovascular disease was defined as coronary artery disease, peripheral arterial disease, stroke, myocardial infarction, or diabetes mellitus with target organ disease. Increased cardiovascular risk was defined as aged 60 years or older and receiving medication for more than two of the following: hypercholesterolemia, hypertension, diabetes mellitus, or peripheral arterial disease. 182 pts failed to meet cardiovascular entry criteria but were included in analysis.

‡ Included in previous report^127^

§ 23 patients had FEV_1_>70 (protocol violation) but included in the analysis

Abbreviations: CG = control group; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in one second; FVC = Forced vital capacity; GOLD = Global Initiative for Chronic Obstructive Lung Disease; ICS = inhaled corticosteroid; IG = intervention group; LABA = long acting beta agonist; LAMA = long acting muscarinic antagonist; MRC = medical research counsel; mMRC = Modified Medical Research Counsel questionnaire; µg = microgram; N = number of participants; post-BD = post bronchodilator; SUMMIT = study to understand mortality and morbidity in COPD; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium.

Table 4 Key Question 2 Results: Population Characteristics for Included RCTs of Pharmacologic Treatment

Study, Year | N Randomized | Age, years (mean) | Female, % | Smoking status, % | Smoking history, pack-years (mean) | Number of exacerbations in the preceding year | Lung function post-BD FEV_1_ % predicted of normal (mean) | HrQOL symptom score
PINNACLE; Martinez, 2020^72^ | GOLD A subset: 729 | 65.5 | 27.3% | Current: 32.8%; Former: 67.2% | 45.6 | NR | NR | CAT mean score: 6.5
SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Full population: 16,590 | 65 | 25.5% | Current: 46.6%; Former: 53.4% | 41 | 1: 24.4%; 2 or more: 14.8% | 59.7 | SGRQ total score mean: 45-46; CAT mean score: 18-19
UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Halpin, 2015^85^; Rabe, 2020^84^ | Stage II subset: 2,739 | 64.5 | NR | Current: 33.0%; Former: 67.0% | 47.5 | NR | 59 | SGQR total score mean: 41.5
UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Halpin, 2015^85^; Rabe, 2020^84^ | FEV_1_≥60% subset: 1,210 | 64 | 29.9% | Current: 32.3%; Former: 67.7% | 47.6 | NR | 64 | SGQR total score mean: 40
UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Halpin, 2015^85^; Rabe, 2020^84^ | GOLD category A: 357 | 65 | 18.5% | Current: 29.4%; Former: 70.6% | NR | NR | 60.4 | SGQR total score mean: 16.8

Abbreviations: CAT= COPD Assessment Test; FEV_1_ = forced expiratory volume in one second; GOLD = Global Initiative for Chronic Obstructive Lung Disease; µg = microgram; N = number of participants; NR = not reported; postBD = post bronchodilator; RCT = randomized controlled trial; SGRQ = St George’s Respiratory Questionnaire; SUMMIT = study to understand mortality and morbidity in COPD; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium.

The included PINNACLE study was actually a post-hoc analysis of GOLD category A patients (n=729) in three PINNACLE trials (PINNACLE 1, PINNACLE 2, PINNACLE 4) (n=4983).^72^ These trials evaluated glycopyrrolate (LAMA), formoterol fumarate (LABA), and glycopyrrolate/formoterol fumarate (LAMA/LABA) versus placebo. Of note, participants on a stable dose of ICS were allowed to continue this therapy. In this subgroup analysis, the mostly male population had a mean age of 65.5 years, and a mean pack year history of 45.6 years, but a low symptom score (i.e., CAT mean score 6.5) consistent with GOLD category A classification.

The SUMMIT trial (n=16,590) evaluated vilanterol (LABA), fluticasone furoate (ICS), and vilanterol/fluticasone furoate (LABA/ICS) versus placebo.^76,^ ^83^ All background LABA, LAMA, and ICS were discontinued prior to the trial. In this trial, all participants had to have known cardiovascular disease (CVD) or be at increased risk for CVD (as defined by taking medication for more than 2 cardiovascular risk factors). In this trial, the mostly male population had a mean age of 65 years, mean pack year history of 41 years, mean FEV_1_ of about 60 percent predicted, and a fairly high symptom score (i.e., SGRQ 45-56, CAT 18-19).

The UPLIFT trial (n=5993)^75^ was included in the previous systematic review that supported the 2016 recommendation, but had 2 newly published post-hoc subgroup analyses in adults with moderate COPD (Stage II) (n=2603)^84^ and GOLD category A patients (n=357).^85^ UPLIFT evaluated tiotropium (LAMA) versus placebo. Patients were allowed to continue all background medication except for other muscarinic antagonists. In the included subgroup analyses for this trial, the mostly male population had a mean age of 65 years, and a mean pack year history of about 47 years. In the subgroup analysis in adults with moderate COPD, the mean FEV_1_ was 59 percent predicted with a fairly high symptom score (i.e., SGRQ 41.5).^84,^ ^87^ In the GOLD category A subgroup analysis, the mean FEV_1_ was 60.4 percent predicted but the mean symptom score was lower (i.e., SGRQ 16.8).^85^

Although these trials were well conducted multisite RCTs, a few limitations are worth noting. The population studied in SUMMIT is less generalizable to screen-detected populations (i.e., greater degree of airflow obstruction and symptoms), and this trial did not include subgroup analyses of less symptomatic participants as the trial’s inclusion criteria specified a symptom score of greater than or equal to 2 on the mMRC. While both PINNACLE and UPLIFT include subgroup analyses or populations more generalizable to screen-detected persons, all were post hoc analyses and only the subgroup analysis of GOLD category A participants in the UPLIFT trial reported interaction testing and controlled for potential confounders (Table 5).^85^ However, this subgroup analysis of GOLD category A participants only included 357 participants. Last, the PINNACLE trials were limited to 24-week followup.

Table 5 Key Question 2 Results: Subgroup Credibility Ratings for RCTs of Pharmacologic Treatment

Study, year | Subgroup | Timing of analysis | Interaction testing performed? | Groups matched at baseline? | Controlled for confounders?
PINNACLE; Martinez, 2020^72^ | GOLD category A | Post-hoc^*^ | No^†^ | Yes | No^†^
UPLIFT; Decramer, 2009^87^ | COPD Stage II | A-priori | Yes (for exacerbations only) | Yes | No
UPLIFT; Tashkin, 2012^88^ | FEV1≥60% predicted | Post-hoc | No | Only difference is statistically significantly more smokers in CG than IG (36% versus 29% P=0.011) | For HrQOL analysis only
UPLIFT; Halpin, 2015^85^ | GOLD category A | Post-hoc | Yes | Yes | Yes
UPLIFT; Rabe, 2020^84^ | COPD Stage II | Post-hoc | No | NR | NR

* The analyses of lung function by GOLD category were specified in an integrated statistical analysis plan that was developed after the reporting of data from PINNACLE-1 and -2, but prior to the unblinding of PINNACLE-4.

† Performed for lung function outcomes but not for mortality or harms

Abbreviations: CG = control group; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in one second; GOLD = Global Initiative for Chronic Obstructive Lung Disease; HrQOL = health-related quality of life; IG = intervention group; NR = not reported; SUMMIT = study to understand mortality and morbidity in COPD; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium.

#### Non-Pharmacologic Interventions

We found 13 trials evaluating non-pharmacologic interventions used in the management of mild to moderate COPD, or minimally symptomatic persons (i.e., GOLD category A): seven trials of self-management interventions, one trial of exercise-only counseling, three trials of intensive supervised exercise or pulmonary rehabilitation, and two trials of clinician education/training on COPD care (Tables 6 and 7).

Table 6 Key Question 2 Results: Study Characteristics for Included Trials of Non-Pharmacologic Treatments

Intervention type | Author, Year; Study^*^ | Country | Design | N Randomized | Followup | Inclusion | Exclusion
Self-management | Bischoff, 2012^67^ | Netherlands | RCT | 165 | 104 weeks | Aged 35 years and older and FEV_1_/FVC< 0.70 | Post-BD FEV_1_< 30% predicted, treatment by a respiratory physician, severe comorbid conditions with a reduced life expectancy, inability to communicate in the Dutch language
Self-management | Jolly, 2018^69^; PSM COPD | United Kingdom | RCT | 577 | 52 weeks | ≥18 years, on the practice COPD register, mild dyspnea (MRC grades 1 or 2), FEV_1_/FVC <0.7 | Considered to be inappropriate for the study by patients’ physician (e.g., terminal disease or a severe psychiatric disorder)
Self-management | Moy, 2016^86^; Taking Healthy Steps | United States | RCT | 239 | 52 weeks | ≥ 40 year; diagnosis of COPD, emphysema, or chronic bronchitis based on administrative ICD-9 codes; able to walk a minimum of one block; sedentary (defined by < 150 minutes of self-reported physical activity per week); physician clearance; regular email user with internet access | Quadriplegia/paraplegia or wheelchair dependence, dementia, pregnancy-related diagnoses/procedures in past year, involvement in another pedometer walking program
Self-management | Nyberg, 2019^73^ | Sweden | CCT | 83 | 52 weeks | Diagnosis of COPD | Inability to communicate in Swedish
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Netherlands | RCT | 1325 | 26 weeks | Diagnosed with COPD or at moderate/high risk for COPD^†^, aged 40–70, internet access and basic computer skills | Inability to communicate in the Dutch language
Self-management | Wan, 2020^78^; ESC | United States | RCT | 114 | 65 weeks | Aged ≥40 years, ≥10 pack-years of smoking, FEV_1_/FVC <0.70 or emphysema on a CT, able to walk one block, internet access and basic computer skills, >90% accuracy on step counter | COPD exacerbation requiring prednisone or antibiotics in past month, inability to ambulate, unstable CVD or congestive heart failure, pulmonary rehabilitation in previous three months, plans to participate in another exercise study or program in next 3 months, <85% blood oxygen saturation during 6MWT
Self-management | Weldam, 2017^79^; COPD-GRIP | Netherlands | Cluster RCT | 204 | 39 weeks | Diagnosed with COPD, age ≥40, a lung function test in previous year | Life-threatening comorbid condition or if they had a primary diagnosis of asthma, inability to communicate in the Dutch language
Exercise only | Altenburg, 2015^66^; COACH | Netherlands | RCT | 48^‡^ | 65 weeks | Age 40-80, COPD diagnosed based on GOLD guidelines | Comorbidities which severely limit physical activity, exacerbations or respiratory tract infections within prior two months
Supervised exercise or pulmonary rehabilitation | Fastenau, 2020^68^ | Netherlands | RCT | 90 | 26 weeks | Mild to moderate COPD, dyspnea, and physically inactive lifestyle | Pulmonary rehabilitation in the past year, lower respiratory tract infections in past 8 weeks, serious comorbid conditions
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Australia | Cluster RCT | 272 | 52 weeks | ≥40 years, at least two clinic visits in past year, COPD diagnosed based on spirometry and clinical confirmation | NR
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | Spain | RCT | 71 | 52 weeks | 35 to 74 years old, moderate COPD based on GOLD guidelines | Musculoskeletal conditions that prevented exercising and walking test assessments, or terminal illness or other severe disease
Clinician education only | Markun, 2018^71^; CAROL | Switzerland | Cluster RCT | 216 | 52 weeks | ≥45 years, ≥10 pack-years smoking history, FEV_1_/FVC<0.7 | Patients attending for emergency consultations, insufficient German language skills, asthma/hay fever, estimated life expectancy <6 months
Clinician education only | Zwar, 2016^80^; PELICAN | Australia | Cluster RCT | 254 | 52 weeks | Attended the practice at least twice (once in past 12 months); risk factors for COPD (aged 40-85 years and history of smoking); COPD identified via case finding by study nurse based on 2005 ATS/ERS guidelines | Previously recorded diagnosis of COPD, Inability to communicate in English, cognitive impairment

* All studies fair quality.

† Respiratory Health Screening Questionnaire score >19.5

‡ Primary care arm only

Abbreviations: 6MWT = six minute walk test; ATS/ERS = American Thoracic Society and European Respiratory Society (ERS); CAROL = Care in Chronic Obstructive Lung Disease; CCT = Clinical controlled trial; COACH = A Structured Lifestyle Intervention on Daily Physical Activity Level in COPD; COPD = chronic obstructive pulmonary disease; COPD-GRIP = Chronic Obstructive Pulmonary Disease – Guidance, Research on Illness Perception; CVD = Cardiovascular disease; ESC = Every Step Counts; FEV_1_ = forced expiratory volume in one second; FVC = Forced vital capacity; GOLD = Global Initiative for Chronic Obstructive Lung Disease; MRC = Medical Research Counsel questionnaire; NR = not reported; PELICAN = Primary care EarLy Intervention for Copd mANagement; post-BD = post bronchodilator; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; RADICALS = Review of Airway Dysfunction and Interdisciplinary Community-Based Care of Adult Long-Term Smokers; RCT = Randomized controlled trial; VA = Veterans Affairs.

Table 7 Key Question 2 Results: Intervention Characteristics for Included Trials of Non-Pharmacologic Treatments

Intervention type | Author, Year; Study | Country | Intervention description | Delivery | Duration | Comparator | Adherence
Self-management | Bischoff, 2012^67^ | Netherlands | Tailored self-management education/support | 2-4 in person sessions (1 hour) with nurse; 6 follow up phone calls | 52 weeks | Usual care | NR
Self-management | Bischoff, 2012^67^ | Netherlands | Non-tailored self-management education/support^*^ | 1-4 routine monitoring nursing visits | 52 weeks | Usual care | NR
Self-management | Jolly, 2018^69^; PSM COPD | United Kingdom | Telephone health coaching intervention to support self-management | 4 nurse counseling telephone sessions (15-60 minutes) with tailored supportive materials | 26 weeks | 13-page informational leaflet on self-management | 86.4% of scheduled calls were delivered and 75.4% of participants received all four calls
Self-management | Moy, 2016^86^; Taking Healthy Steps | United States | Pedometer plus educational and tracking website with personalized goals | Web/computer based | 17 weeks with 35 week maintenance phase | Received pedometer and access to step count website | Step counts recorded by 77% of intervention group and 64% of control group
Self-management | Nyberg, 2019^73^ | Sweden | COPD self-management website (COPD Web) | Use of pedometer and interactive webpage | 52 weeks | Received pedometer and information on importance of physical activity | 95% of participants created an account and visited the site at least once (77% of participants were considered users)
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Netherlands | Web-based application providing computer-generated tailored feedback | Web/computer based | 26 weeks | Usual care | 36% of participants used application
Self-management | Wan, 2020^78^; ESC | United States | Pedometer plus educational and tracking website with personalized goals | Web/computer based | 13 weeks | Received pedometer and access to step count website | Overall percentage of wear days: 85.8% (average 15.2 hours per day), >4 logins per month
Self-management | Weldam, 2017^79^; COPD-GRIP | Netherlands | Nurse consultations discussing individual patient illness, behavior, and action plan formation | 3 in-persons consultations (30 minutes); 4 hour educational session for nurses | 6 weeks | Usual care | NR
Exercise only | Altenburg, 2015^66^; COACH | Netherlands | Customized lifestyle physical activity counselling program | 5 individual 30-minute in-person counseling sessions by exercise counselors | 12 weeks | Usual care | NR
Supervised exercise or pulmonary rehabilitation | Fastenau, 2020^68^ | Netherlands | Supervised exercise training | 2 supervised group exercise sessions per week for 17 weeks (60-90 minutes) | 17 weeks | Low intensity exercise program (30 minutes/once a week) | NR
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Australia | Interdisciplinary, primary care-based model addressing smoking cessation, medication review and home-based pulmonary rehabilitation | In home pharmacist medication review and smoking cessation support (1.5 hours); 8-week home based pulmonary rehabilitation (one home visit and follow up phone calls) | 8 weeks | Usual care plus informational booklet | Full intervention: 31%; Partial intervention: 26%; No intervention: 43%
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | Spain | Small group pulmonary rehabilitation/education plus weekly maintenance program | 3 (60-minute) sessions a week for 3 months; weekly sessions during months 4-12 | 52 weeks | Usual care | Attended 69.4% of the planned sessions during the first three months, and 58.3% of the planned sessions during the maintenance period
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | Spain | Small group pulmonary rehabilitation/education | 3 (60-minute) sessions a week for 3 months | 2000 minutes over 13 weeks | Usual care | Attended 36.1% of the sessions during the three month period.
Clinician education only | Markun, 2018^71^; CAROL | Switzerland | COPD care bundle and provider education | Half day workshop for care providers, 3-hour refresher workshop after 6 months | provider training only, 26 weeks | Usual care | NR
Clinician education only | Zwar, 2016^80^; PELICAN | Australia | Provider education on team-based management of COPD | 1-day (8 hour) nurse training on case-finding for COPD; 3-hour joint workshop for general practitioners and care team on care organization | provider education only, 1 day | 1-day (8 hour) nurse training on case-finding for COPD; practice mailed a copy of COPD guidelines | 15.3% of participants reported one or more visits to COPD care, 51.4% received one or more visits for any reason.

* Referred to in trial as ‘routine monitoring’.

Abbreviations: CAROL = Care in Chronic Obstructive Lung Disease; COACH = A Structured Lifestyle Intervention on Daily Physical Activity Level in COPD; COPD = chronic obstructive pulmonary disease; COPD-GRIP = Chronic Obstructive Pulmonary Disease – Guidance, Research on Illness Perception; ESC = Every Step Counts; NR = not reported; PELICAN = Primary care EarLy Intervention for Copd mANagement; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; RADICALS = Review of Airway Dysfunction and Interdisciplinary Community-Based Care of Adult Long-Term Smokers.

##### Self-Management Interventions

Three trials (n=165 to 577) evaluated in-person or phone-based (as opposed to web-only) self-management interventions.^67,^ ^69,^ ^79^ Although each of the interventions was different, self-management generally included education on COPD, medications, healthy lifestyle (including but not limited to exercise), tobacco cessation, and an exacerbation management/action plan. These interventions ranged from two to four in-person or phone sessions over several weeks with or without followup calls. The comparator groups received usual care or non-tailored written education materials. These trials included both male and female populations with a mean age ranging from 64.9 to 70.4 years, and 23 to 30 percent of the populations included were active smokers. The trial by Jolly and colleagues (n=577),^69^ conducted in the UK, explicitly recruited minimally symptomatic persons with COPD (MRC score 1 or 2), and the mean FEV_1_ was 71.7 percent predicted, with a mean SGRQ of 28.7. Nonetheless, almost half of the included population had one or more exacerbations in the previous year. In the other two trials, conducted in the Netherlands, the mean FEV_1_s were lower (60.6 and 65.4 percent).^67,^ ^79^

Another four trials (n=83 to 1325) evaluated a web-only self-management intervention.^73,^ ^77,^ ^78,^ ^86^ Two trials evaluated interactive web-based self-management interventions broadly inclusive of topics addressed in the in-person self-management interventions; however, two trials conducted in the VA setting in the United States focused primarily on exercise (‘step count’) although included some information on disease self-management, self-efficacy, and an online community forum for support.^78,^ ^86^ The comparator groups received usual care and/or a pedometer with exercise information. These trials included both male and female populations with a mean age ranging from 57.6 to 68.6 years, and 19 to 37 percent of the populations included were active smokers. One trial by Voncken-Brewster and colleagues (n=1325), conducted in the Netherlands, recruited both person with COPD and at risk for COPD, 67.6 percent of whom had an MRC score of 1 or 2; however, the mean FEV_1_ was not reported.^77^ In the other two trials the mean FEV_1_ was 60.0 to 62.6 percent.^73,^ ^78^

##### Exercise Only Counseling

One trial (n=48 in primary care arm) by Altenburg and colleagues, conducted in the Netherlands, evaluated an in-person counseling intervention in which participants were randomized to receive five 30-minute sessions on improving physical activity or usual care. In this trial, the mostly male population had a median age of 65 years, a median pack year history of 30 years, and median FEV_1_ of 78 percent predicted.^66^

##### Supervised Exercise or Pulmonary Rehabilitation

One trial (n=90) by Fastenau and colleagues, conducted in the Netherlands, evaluated an intensive in-person supervised exercise intervention in which participants were randomized to receive twice weekly sessions (60 to 90 min) for 17 weeks or a low intensity session (30 min) once weekly. In this trial, the population was about half male and had a mean age of 62.5 years; 38 percent were current smokers. The mean FEV_1_ was 74.2 percent predicted.^68^

Two trials evaluated pulmonary rehabilitation programs; one trial (n=272) evaluated a home-based program,^70^ while the other trial (n=71) evaluated an intensive in person program.^74^ The trial by Liang and colleagues, conducted in Australia, evaluated an 8-week home-based pulmonary rehabilitation program involving one home visit and followup calls supplemented by a one-time in home pharmacist medication review and smoking cessation session (90 minutes) versus usual care with non-tailored written educational material. In this mostly male population, the mean age was 64.5 years, 61 percent were current smokers, and the mean FEV_1_ was 70.0 percent predicted.^70^ The other trial by Roman and colleagues, conducted in Spain, evaluated an intensive in-person pulmonary rehabilitation program consisting of three 60 minute sessions a week for 3 months with or without weekly sessions during months 4 through 12, versus usual care. This program also included counseling on medication and smoking cessation. In this mostly male population, the mean age was 64.2 years, and 34 percent were current smokers. This trial recruited only patients with moderate COPD, and the mean FEV_1_ was 60.3 percent predicted.^74^

##### Clinician Education Only Interventions

While some of the included trials implicitly or explicitly provided clinician education as part of the execution of the trial, for most trials, the primary intervention was directed at the patient, and not the clinician. However, two cluster randomized trials (n=216 to 254) conducted outside the United States evaluated clinician education and training for COPD, primarily aimed at general practitioners.^71,^ ^80^ One trial by Zwar and colleagues, conducted in Australia, explicitly included persons with COPD identified via active case finding, and therefore also included training aimed at practice nurses to conduct case finding.^80^ As such, this trial tended to include persons with less severe symptoms (mean SGQR 19.5, CAT 10.2) and airflow obstruction (mean FEV_1_ 74.6 percent predicted). The other trial by Markun and colleagues also included persons with less severe symptoms (69 percent with GOLD category A or B, mean CAT 10.6) and airflow obstruction (mean FEV_1_ 67.3 percent predicted).^71^

All the included trials were fair quality without significant threats to validity. However, many of the trials had characteristics that may limit the ability to detect a true benefit (type II error): 1) small trials with a limited number of participants per intervention arm, 2) usual care (most trials were conducted outside the US) or control groups receiving more care than may typically be delivered in the US, and 3) poor adherence to or uptake of the intervention itself.

### Detailed Results

#### Pharmacologic Interventions

Two of the three included trials demonstrated that LABA, ICS or LABA/ICS could reduce exacerbations in persons with fairly symptomatic moderate COPD and that LAMA could reduce exacerbations in patients with minimal symptoms (i.e., GOLD category A) (Table 9).

Table 8 Key Question 2 Results: Population Characteristics for Included Trials of Non-Pharmacologic Treatments

Intervention type | Author, Year; Study | Age, years (mean) | Female, % | Smoking status, % | Smoking history, pack-years (mean) | Number of exacerbations in preceding year | Lung function post-BD FEV_1_ % predicted of normal (mean) | COPD Stage | HrQOL symptom score
Self-management | Bischoff, 2012^67^ | 64.9 | 35 | Current: 30 | NR | Median: 0.5 to 1 | 65.4 | NR | NR
Self-management | Jolly, 2018^69^; PSM COPD | 70.4 | 37 | Current: 23 | NR | 1 or more: 47% | 71.7 | 1: 33%; 2: 54%; 3: 12%; 4: <1% | SGRQ mean score: 28.7
Self-management | Moy, 2016^86^ | 66.8 | 6 | Current: 24 | NR | NR | NR | mMRC 0-1: 69%; mMRC 2-4: 31% | SGRQ mean score: 46
Self-management | Nyberg, 2019^73^ | 68.0 | 43 | Current: 19; Former: 71 | 30 | NR | 60.0 | A: 53%; B: 20%; C: 8%; D: 18% | EQ-5D mean score: 0.90
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | 57.6 | 52 | Current: 34 | NR | NR | NR^*^ | NR | CCQ mean score: 1.0; MRC score:; 0: 27.5%,; 1: 40.1%,; 2: 24.4%,; 3>: 8%
Self-management | Wan, 2020^78^; ESC | 68.6 | 2 | Current: 37; Former: 63 | 61.5 | Mean in previous year: 0.35 | 62.6 | NR | SGRQ mean score: 33.5
Self-management | Weldam, 2017^79^; COPD-GRIP | 67.0 | 55 | Current: 30 | NR | NR | 60.6 | 1: 9%; 2: 62%; 3: 21%; 4: 7%^†^ | MRC mean score: 2.1
Exercise only | Altenburg, 2015^66^; COACH | 65^‡^ | 33 | NR | 30^‡^ | NR | 78^‡^ | 1: 46%; 2: 48%; 3: 6%; 4: 0% | CRQ total mean: 117; CCQ total mean: 0.75
Supervised exercise or pulmonary rehabilitation | Fastenau, 2020^68^ | 62.5 | 51 | Current: 38; Former: 54 | NR | NR | 74.2 | 1: 27%; 2: 73% | CCQ total score mean: 1.7
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | 64.5 | 39 | Current: 61 | NR | NR | 70.0 | Mild: 70%; Moderate: 21%; Severe: 9% | NR
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | 64.2 | 18 | Current: 34; Former: 62 | | 39%^§^ | 60.3 | 2: 100% | NR
Clinician education only | Markun, 2018^71^; CAROL | 67.5 | 41 | Current: 56; Former: 44 | 44.5 | 1 or more: 34% | 67.3 | A: 59%; B: 10%; C: 19%; D: 12% | CAT mean score: 10.6
Clinician education only | Zwar, 2016^80^; PELICAN | 66.0 | 40 | Current: 31; Former: 69 | NR | NR | 74.6 | 1: 21%; 2: 42%; 3: 6%; 4: <1%^ǁ^ | SGQR mean score: 19.5; CAT: 10.2

* Diagnosed with COPD: 21.7%, increased risk for COPD 78.3%

† 78 patients (31%) that a clinician assigned a diagnosis of COPD were found to not meet criteria for COPD (FEV_1_/FVC not <0.7) upon further assessment

‡ Median

§ 39 % with physician visit for exacerbation and 18% with hospitalization

ǁ 78 patients (31%) that a clinician assigned a diagnosis of COPD were found to not meet criteria for COPD (FEV_1_/FVC not <0.7) upon further assessment

Abbreviations: CAT= COPD Assessment Test; CAROL = Care in Chronic Obstructive Lung Disease; CCQ = Clinical COPD Questionnaire; COACH = A Structured Lifestyle Intervention on Daily Physical Activity Level in COPD; COPD = chronic obstructive pulmonary disease; COPD-GRIP = Chronic Obstructive Pulmonary Disease – Guidance, Research on Illness Perception; CRQ = Chronic Respiratory Disease Questionnaire; EQ-5D = EuroQOL-5 Dimension Questionnaire; ESC = Every Step Counts; FEV_1_ = forced expiratory volume in one second; HRQoL = Health Related Quality of Life; MRC = Medical Research Counsel questionnaire; NR = not reported; PELICAN = Primary care EarLy Intervention for Copd mANagement; post-BD = post bronchodilator; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; RADICALS = Review of Airway Dysfunction and Interdisciplinary Community-Based Care of Adult Long-Term Smokers; SGRQ = St George’s Respiratory Questionnaire

Table 9 Key Question 2 Results: Outcomes for Included RCTs of Pharmacologic Treatment

Drug Class | Study, year | Treatment Comparison | Followup | Outcome | N analyzed | IG Events^*^ | CG Events^*^ | IG vs. CG
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (Median) | All-cause mortality | 8246 | 251/4135 (6.1%) | 275/4111 (6.7%) | HR: 0.91 (95% CI, 0.77 to 1.08)
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (Median) | Annual rate of moderate/severe exacerbations | 8246 | 0.31 | 0.35 | Percent reduction: 12% (95% CI, 4% to 19%)
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (Median) | Annual rate of hospitalized exacerbation | 8246 | 0.06 | 0.07 | Percent reduction: 18% (95% CI, 3% to 31%)
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (Median) | Composite CVD endpoint^†^ | 8246 | 161/4135 (3.9%) | 173/4111 (4.2%) | HR: 0.90 (95% CI, 0.73 to 1.11)
LABA | PINNACLE; Martinez, 2020^72^ | Formoterol fumarate vs. placebo | 24 weeks | All-cause mortality | GOLD A: 318 | 1/205 (0.5%) | 0/113 (0%) | NR
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (Median) | All-cause mortality | 8229 | 265/4118 (6.4%) | 275/4111 (6.7%) | HR: 0.96 (95% CI, 0.81 to 1.14)
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (Median) | Annual rate of moderate/severe exacerbations | 8229 | 0.31 | 0.35 | Percent reduction: 10% (95% CI, 2% to 18%)
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (Median) | Annual rate of hospitalized exacerbation | 8229 | 0.06 | 0.07 | Percent reduction: 20% (95% CI, 5% to 32%)
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (Median) | Composite CVD endpoint^†^ | 8229 | 180/4118 (4.4%) | 173/4111 (4.2%) | HR: 0.99 (95% CI, 0.80 to 1.22)
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (Median) | All-cause mortality | 8232 | 246/4121 (6.0%) | 275/4111 (6.7%) | HR: 0.88 (95% CI, 0.74 to 1.04)
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (Median) | Annual rate of moderate/severe exacerbations | 8232 | 0.25 | 0.35 | Percent reduction: 29% (95% CI, 22% to 35%)
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (Median) | Annual rate of hospitalized exacerbation | 8232 | 0.05 | 0.07 | Percent reduction: 27% (95% CI, 13% to 39%)
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (Median) | Composite CVD endpoint^†^ | 8232 | 174/4121 (4.2%) | 173/4111 (4.2%) | HR: 0.93 (95% CI, 0.75 to 1.14)
LAMA | UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Clinically important deterioration^‡^ | Stage II: 2,603 | 1053/1310 (80.4%) | 1122/1293 (86.8%) | HR: 0.70 (95% CI, 0.65, 0.77)
LAMA | UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Exacerbations^§^ | Stage II: 2,739 | 824/1384 (59.5%) | 882/1355 (65.1%) | HR: 0.82 (95% CI, 0.75 to 0.90)
LAMA | UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Exacerbations^§^ | FEV_1_≥60%: NR (1210 randomized) | NR (56%) | NR (62%) | HR: 0.83 (95% CI, 0.71 to 0.96)
LAMA | UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Exacerbations^§^ | GOLD category A: 357 | 91/188 (48.4%) | 92/169 (54.4%) | RR: 0.64 (95% CI, 0.47 to 0.89); HR: 0.77 (95% CI, 0.58 to 1.03)^ǁ^
LAMA | UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Clinically meaningful deterioration in SGRQ^¶^ | Stage II: 2,603 | 487/1310 (37.2%) | 594/1293 (45.9%) | HR: 0.71 (0.63, 0.80)
LAMA | UPLIFT; Decramer, 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Clinically meaningful deterioration in SGRQ^¶^ | FEV_1_≥60%: NR (1210 randomized) | NR (52%) | NR (44%) | P<0.05
LAMA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate vs. placebo | 24 weeks | All-cause mortality | GOLD A: 308 | 0/195 (0%) | 0/113 (0%) | NR
LAMA/LABA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate/formoterol fumarate vs. placebo | 24 weeks | All-cause mortality | GOLD A: 330 | 0/217 (0%) | 0/113 (0%) | NR

* Number of events or event rate

† Includes MI, unstable angina, stroke, TIA, sudden death, procedural death, other cardiovascular death

‡ SGRQ increase ≥4 units, trough FEV_1_ decline ≥100mL, moderate/severe exacerbation

§ Increase/new onset >1 respiratory symptom for ≥ 3 days requiring antibiotic and/or systemic steroid

ǁ Time to first exacerbation

¶ SGRQ increase ≥4 units

Abbreviations: CG = control group; CI = confidence interval; CVD = cardiovascular disease; FEV_1_= forced expiratory volume in 1 second; GOLD = Global Initiative for Chronic Obstructive Lung Disease; ICS = inhaled corticosteroid; HR = hazard ratio; IG = intervention group; LABA = long acting beta agonist; LAMA = long acting muscarinic antagonist; µg = microgram; N = number; NR = not reported; SUMMIT = study to understand mortality and morbidity in COPD; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium; Vs = versus

The analysis from the PINNACLE trials evaluating glycopyrrolate (LAMA), formoterol fumarate (LABA), and glycopyrrolate/formoterol fumarate (LAMA/LABA) versus placebo in GOLD category A patients (n=729) only reported mortality outcomes and adverse outcomes at 24 weeks. This pooled analysis found no difference in mortality outcomes.^72^ Harms are discussed in Key Question 3.

The SUMMIT trial (n=16,590) in persons with mild to moderate COPD (mean FEV_1_ 59.7 percent, SGRQ 45-46) found that vilanterol (LABA), fluticasone furoate (ICS), and vilanterol/fluticasone furoate (LABA/ICS) all reduced moderate to severe COPD exacerbations and hospitalizations for exacerbations compared to placebo at a median followup of 1.8 years.^76,^ ^83^ In this population, 39.2 percent of persons had a least one exacerbation in the year prior to trial recruitment. The percent reduction in the annual rate of moderate to severe exacerbations was higher for LABA/ICS (29 percent [95% CI, 22 to 35%]) than for LABA (10 percent [95 % CI, 2 to 18 %) or ICS (12 percent [95% CI, 4 to 19%) alone. This trial also found that LABA alone reduced pneumonias compared placebo at a median of 1.8 years, discussed in Key Question 3.

The UPLIFT trial subgroup analysis in moderate (stage II) COPD (n=2603) found that tiotropium (LAMA) reduced clinically important deterioration at 48 months compared to placebo (deterioration was a composite outcome of a decrease in trough FEV_1_ of ≥100 mL, increase in SGRQ total score from baseline ≥4 units [clinically meaningful difference], or moderate/severe exacerbation).^84^ Of note, these results are consistent with prior subgroup analyses by stage and FEV_1_ included in the previous review and do not add any new understanding of the benefits of tiotropium over placebo in this population.^87,^ ^88^ Another subgroup analysis in GOLD category A patients (n=357) did demonstrate that LAMA reduced the proportion of persons with exacerbations compared to placebo at 48 months, which decreased to 48.4 percent compared to 54.4 percent (RR 0.64 [95% CI, 0.47 to 0.89]).^85^ The overall symptom score in these patients was low (i.e., SGRQ 16.8), although the severity of airflow obstruction (FEV_1_ 60.4 percent) was similar to those in the moderate (stage II) COPD subgroup analyses.

#### Non-Pharmacologic Interventions

##### Self-Management Interventions

Overall, there were no consistent and significant benefits in outcomes across the four trials evaluating in person or phone-based self-management interventions. However, intervention intensity, outcomes reported, and duration of followup varied across the trials. Neither of the two trials evaluating exacerbation outcomes found a statistically significant difference in exacerbations or hospitalizations at 52 or 104 weeks ^67,^ ^69^ (Table 10). All three trials reported disease specific or general HRQoL outcomes using different instruments (i.e., CRQ, SGRQ, CCQ, and EQ-5D); nonetheless, no trial demonstrated a clinically meaningful or statistically significant benefit in HRQoL at 26, 39 or 104 weeks (Table 11). And all three trials reported dyspnea outcomes using either the CRQ (dyspnea domain) or MRC instrument (Table 12). Across the trials there were no statistically significant improvements in dyspnea at 26, 39 or 52 weeks; however, in the trial by Bischoff and colleagues (n analyzed=110), the dyspnea outcome improved in the intervention group that received a non-tailored self-management support at 104 weeks (mean difference 0.40 [95% CI, 0.041 to 0.78]).^67^ The clinical significance of this finding is unclear, given the small change on a continuous measure and in the setting of no impact on the overall CRQ instrument. In addition, the trial by Jolly and colleagues reported other mental health, exercise, and smoking cessation outcomes, finding no statistically significant improvements in anxiety/depression (data not shown), objective measures of exercise, or smoking cessation at 26 or 52 weeks (Tables 13 and 14).^69^

Table 10 Key Question 2 Results: Exacerbation and Hospitalization Outcomes for Included Non-Pharmacologic Trials

Intervention type | Author, Year; Study | Treatment comparison | Outcome | Followup | N analyzed | IG Events | CG Events | IG vs. CG
Self-management | Bischoff, 2012^67^ | Tailored self-management intervention vs. usual care | Exacerbation^*^ | 52 weeks | 101 | Rate per patient: 2.83 | Rate per patient: 2.73 | RR: 1.10 (95% CI, 0.86 to 1.40)
Self-management | Bischoff, 2012^67^ | Tailored self-management intervention vs. usual care | Exacerbation^*^ | Weeks 52-104 | 101 | Rate per patient: 2.45 | Rate per patient: 2.17 | RR: 1.16 (95% CI, 0.81 to 1.67)
Self-management | Bischoff, 2012^67^ | Non-tailored self-management intervention vs. usual care | Exacerbation^*^ | 52 weeks | 103 | Rate per patient: 3.25 | Rate per patient: 2.73 | RR: 1.25 (95% CI, 0.98 to 1.58)
Self-management | Bischoff, 2012^67^ | Non-tailored self-management intervention vs. usual care | Exacerbation^*^ | Weeks 52-104 | 103 | Rate per patient: 2.38 | Rate per patient: 2.17 | RR: 1.15 (95% CI, 0.80 to 1.65)
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | Hospital admissions | 26 weeks^†^ | 531 | Mean (SD): 0.07 (0.3) | Mean (SD): 0.06 (0.3) | IRR: 0.86 (95% CI, 0.45 to 1.62), p=0.64
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | Hospital admissions | 52 weeks^‡^ | 516 | Mean (SD): 0.06 (0.3) | Mean (SD): 0.06 (0.3) | IRR: 0.90 (95% CI, 0.39 to 2.09), p=0.81
Self-management | Moy, 2016^86^; Taking Healthy Steps | Web-based exercise intervention vs. pedometer only | Exacerbation or pneumonia | 52 weeks | 328 | 35/154 (22.7%) | 15/84 (18%) | OR: 1.4 (95% CI, 0.7 to 2.8), p=0.33
Self-management | Moy, 2016^86^; Taking Healthy Steps | Web-based exercise intervention vs. pedometer only | Hospitalization | 52 weeks | 328 | 36/154 (23.4%) | 14/84 (17%) | OR: 1.6 (95% CI, 0.8 to 3.2), p=0.19
Self-management | Moy, 2016^86^; Taking Healthy Steps | Web-based exercise intervention vs. pedometer only | Emergency room visit | 52 weeks | 328 | 46/154 (29.9%) | 20/84 (24%) | OR: 1.4 (95% CI, 0.8 to 2.6), p=0.27
Self-management | Wan, 2020^78^; ESC | Web-based exercise intervention vs. pedometer only | Acute exacerbation^§^ | 65 weeks | 109 | NR | NR | RR: 0.51 (0.31 to 0.85)^¶^
Supervised-exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR with maintenance program vs. usual care | Hospitalized for exacerbation | 52 weeks | 43 | 3/24 (12.5%) | 3/19 (15.8%) | NS
Supervised-exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR with maintenance program vs. usual care | Primary care visit for exacerbation | 52 weeks | 43 | 7/24 (30.3%) | 9/19 (42.8%) | NS
Supervised-exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR vs. usual care | Hospitalized for exacerbation | 52 weeks | 41 | 5/22 (22.7%) | 3/19 (15.8%) | NS
Supervised-exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR vs. usual care | Primary care visit for exacerbation | 52 weeks | 41 | 7/22 (35.0%) | 9/19 (42.8%) | NS

* Change for at least two consecutive days in either two or more major symptoms (dyspnea, sputum purulence, sputum amount) or any one major symptom plus at least one minor symptom (colds, wheeze, sore throat, cough)

† While overall admissions were not significant, intervention participants reported lower doctor and pharmacist consultations, but higher all cause emergency department visits

‡ No differences across any utilization measure

§ New or increased respiratory symptoms with ≥2 the following criteria: increased cough, sputum, wheezing, dyspnea, or chest tightness for ≥3 days requiring antibiotics or new/increased systemic steroid use

¶ Favors intervention group

Abbreviations: CG = control group; CI = confidence interval; ESC = Every Step Counts; IG = intervention group; IRR = incidence rate ratio; N = number; NR = not reported; NS = not significant; OR = odds ratio; PR = pulmonary rehabilitation; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; RR = rate ratio; SD = standard deviation; Vs = versus

Table 11 Key Question 2 Results: Quality of Life Outcomes for Included Trials of Non-Pharmacologic Treatment

Intervention type | Author, Year; Study | Treatment comparison | Followup | Outcome measure | N analyzed | IG: % with MCID | CG: % with MCID | Effect estimate^*^
Self-management | Bischoff, 2012^67^ | Tailored self-management intervention vs. usual care | 104 weeks | CRQ | 110 | NR | NR | −0.22 (95% CI, −0.49 to 0.042)
Self-management | Bischoff, 2012^67^ | Non-tailored self-management intervention vs. usual care | 104 weeks | CRQ | 110 | 13/46 (28%) | 8/44 (18%) | OR (MCID): 1.44 (95% CI, 0.61 to 3.38); Difference in change: 0.16 (95% CI, −0.11 to 0.42)
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 26 weeks | EQ-5D | 516 | NR | NR | 0.01 (95% CI, −0.01 to 0.03), p=0.30
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 26 weeks | SGRQ | 459 | NR | NR | −0.3 (95% CI, −2.3 to 1.7), p=0.76
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 52 weeks | EQ-5D | 505 | NR | NR | 0.01 (95% CI, −0.01 to 0.03), p=0.38
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 52 weeks | SGRQ | 473 | NR | NR | −1.3 (95% CI, −3.6 to 0.9), p=0.23
Self-management | Moy, 2016^86^; Taking Healthy Steps | Web-based exercise intervention vs. pedometer only | 52 weeks | SGRQ | 238 | NR | NR | 1.1 (95% CI, −2.2 to 4.5), p=0.50
Self-management | Nyberg, 2019^73^ | Web-based self-management intervention vs. pedometer | 52 weeks | CAT | 83 | NR | NR | Beta-coefficient: −1.1 (95% CI, −2.2 to 4.3), p=0.521
Self-management | Nyberg, 2019^73^ | Web-based self-management intervention vs. pedometer | 52 weeks | EQ-5D | 83 | NR | NR | Beta-coefficient: 0.02 (95% CI, −0.03 to 0.07), p=0.980
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | CCQ | 1307 | NR | NR | Beta-coefficient: −0.03 (95% CI, −0.07 to 0.01), p=0.134
Self-management | Wan, 2020^78^; ESC | Web-based exercise intervention vs. pedometer only | 52 weeks | SGRQ | 109 | NR | NR | NS
Self-management | Weldam, 2017; COPD-GRIP | In-person self-management intervention vs usual care | 39 weeks | CCQ | 199 | 16/100 (15.7%) | 13/99 (12.9%) | OR (MCID): NS; Difference in change: 0.04 (95% CI, −0.09 to 0.17), p=0.197
Exercise only | Altenburg, 2015^66^; COACH | Lifestyle/exercise counseling vs usual care | 65 weeks | CCQ | 38 | NR | NR | p=0.536
Exercise only | Altenburg, 2015^66^; COACH | Lifestyle/exercise counseling vs usual care | 65 weeks | CRQ | 38 | NR | NR | p=0.278
Supervised exercise or pulmonary rehabilitation | Fastenau, 2020^68^ | Supervised exercise vs. low intensity exercise | 26 weeks | CCQ | 67 | NR | NR | −0.09 (95% CI, −0.4 to 0.2), p=0.549
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Lifestyle counseling plus home PR vs. usual care | 26 weeks | CAT | 208 | NR | NR | 0.66 (95% CI, −1.98 to 3.30) p=0.61
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Lifestyle counseling plus home PR vs. usual care | 26 weeks | SGRQ | 204 | NR | NR | 2.45 (95% CI, −0.89 to 5.79), p=0.15
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Lifestyle counseling plus home PR vs. usual care | 52 weeks | CAT | 189 | NR | NR | 0.86 (95% CI, −2.02 to 3.74) p=0.55
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Lifestyle counseling plus home PR vs. usual care | 52 weeks | SGRQ | 185 | 47/105 (44.8%) | 38/90 (42.2%) | 2.21 (95% CI, −2.86 to 7.28), p=0.38
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR with maintenance program vs. usual care | 52 weeks | CRQ | 36 | NR | NR | NS for any subscale (total score NR)
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR vs. usual care | 52 weeks | CRQ | 31 | NR | NR | NS for any subscale (total score NR)
Clinician education only | Markun, 2018^71^; CAROL | Clinician training vs. usual care | 52 weeks | CAT | 216 | NR | NR | −1.1 (95% CI, −3.3 to 1.1), p=0.32
Clinician education only | Zwar, 2016^80^; PELICAN | Clinician training vs. written information | 52 weeks | CAT | 222 | NR | NR | LSM change: −0.20 (95% CI, −1.53 to 1.12), 0.73
Clinician education only | Zwar, 2016^80^; PELICAN | Clinician training vs. written information | 52 weeks | SGRQ | 222 | NR | NR | LSM change: −0.21 (95% CI, −2.55 to 2.14), 0.86

* Mean difference unless otherwise noted

Abbreviations: CAROL = Care in Chronic Obstructive Lung Disease; CAT= COPD Assessment Test; CCQ = Clinical COPD Questionnaire; CG = control group; CI = confidence interval; COACH = A Structured Lifestyle Intervention on Daily Physical Activity Level in COPD; CRQ = Chronic Respiratory Disease Questionnaire; EQ-5D = EuroQOL-5 Dimension Questionnaire; IG = intervention group; LSM = least squares mean; MCID = minimal clinically important difference; mMRC = modified Medical Research Counsel questionnaire; MRC = Medical Research Counsel questionnaire N = number; NR = not reported; NS = not significant; OR = odds ratio; PELICAN = Primary care EarLy Intervention for Copd mANagement; PR = pulmonary rehabilitation; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; RADICALS = Review of Airway Dysfunction and Interdisciplinary Community-Based Care of Adult Long-Term Smokers; SGRQ = St George’s Respiratory Questionnaire

Table 12 Key Question 2 Results: Dyspnea Outcomes for Included Trials of Non-Pharmacologic Treatment

Intervention type | Author, Year; Study | Treatment comparison | Followup | Outcome measure | N analyzed | IG: % with MCID | CG: % with MCID | Effect estimate^*^
Self-management | Bischoff, 2012^67^ | Tailored self-management education/support vs. usual care | 26 weeks | CRQ-Dyspnea domain | 110 | NR | NR | −0.098 (95% CI: −0.47 to 0.28)
Self-management | Bischoff, 2012^67^ | Tailored self-management education/support vs. usual care | 104 weeks | CRQ-Dyspnea domain | 110 | NR | NR | −0.16 (95% CI: −0.54 to 2.1)
Self-management | Bischoff, 2012^67^ | Non-tailored self-management education/support vs. usual care | 26 weeks | CRQ-Dyspnea domain | 110 | NR | NR | 0.12 (95% CI: −0.26 to 0.49)
Self-management | Bischoff, 2012^67^ | Non-tailored self-management education/support vs. usual care | 104 weeks | CRQ-Dyspnea domain | 110 | NR | NR | 0.40 (95% CI: 0.041 to 0.78); p=0.042
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 26 weeks | MRC | 495 | NR | NR | OR: 0.8 (95% CI: 0.6 to 1.2); p=0.39
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 52 weeks | MRC | 495 | NR | NR | OR: 1.1 (95% CI: 0.7 to 1.5); p=0.79
Self-management | Nyberg, 2019^73^ | Web-based self-management intervention vs. pedometer | 52 weeks | mMRC | 83 | NR | NR | Beta coefficient: −0.1 (95% CI: −0.4 to 0.3); p=0.709
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | MRC | 1,307 | NR | NR | OR: 1.28 (95% CI: 0.92 to 1.79); p=0.149
Self-management | Weldam, 2017^79^; COPD-GRIP | In-person self-management intervention vs usual care | 39 weeks | CRQ- Dyspnea domain | 163 | NR | NR | 0.16 (95% CI: −0.13 to 0.04); p=0.162
Supervised exercise or pulmonary rehabilitation | Fastenau, 2020^68^ | Supervised exercise vs. low intensity exercise | 26 weeks | MRC | 67 | NR | NR | −0.03 (95% CI: −0.3 to 0.3); p=0.867
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Lifestyle counseling plus home PR vs. usual care | 26 weeks | mMRC | 208 | NR | NR | Any improvement from baseline: IG 23.7%, CG: 17.0%, p=0.31
Supervised exercise or pulmonary rehabilitation | Liang, 2019^70^; RADICALS | Lifestyle counseling plus home PR vs. usual care | 52 weeks | mMRC | 190 | NR | NR | Any improvement from baseline: IG 21.2%, CG: 18.2%, p=0.74
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR with maintenance program vs. usual care | 52 weeks | CRQ-Dyspnea domain | 49 | NR | NR | Mean difference in change: 0.1 (95% CI: −0.5 to 0.8)
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR vs. usual care | 52 weeks | CRQ-Dyspnea domain | 31 | NR | NR | Mean difference in change: 0.5 (95% CI: −0.2 to 1.1)

* mean difference unless otherwise noted

Abbreviations: CG = control group; CI = confidence interval; CRQ = Chronic Respiratory Disease Questionnaire; IG = intervention group; MCID = minimal clinically important difference; mMRC = Modified Medical Research Counsel questionnaire; MRC = Medical Research Counsel questionnaire; N = number; NR = not reported; OR = odds ratio; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; PR= pulmonary rehabilitation; RADICALS = Review of Airway Dysfunction and Interdisciplinary Community-Based Care of Adult Long-Term Smokers

Table 13 Key Question 2 Results: Exercise and Physical Functioning Outcomes for Included Trials of Non-Pharmacologic Treatment

Intervention type | Author, Year; Study | Treatment comparison | Followup | Outcome measure | N analyzed | IG vs. CG
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 26 weeks | MET minutes a week (IPAQ) | 506 | Total self-reported physical activity, walking, moderate, and vigorous intensity activity were all significantly higher in the intervention arm at 6 months
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 52 weeks | MET minutes a week (IPAQ) | 482 | NS
Self-management | Moy, 2016^86^; Taking Healthy Steps | Web-based exercise intervention vs. pedometer only | 52 weeks | Average daily step count | 328 | NS
Self-management | Nyberg, 2019^73^ | Web-based self-management intervention vs. pedometer | 52 weeks | Physical activity (self-reported) | 83 | NS
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | MET minutes a week (IPAQ-SF) | 1,307 | NS
Self-management | Wan, 2020^78^,^‡^; ESC | Web-based exercise intervention vs. pedometer only | 26 weeks | Average daily step count | 87 | NS
Self-management | Wan, 2020^78^,^‡^; ESC | Web-based exercise intervention vs. pedometer only | 52 weeks | Average daily step count | 75 | NS
Exercise only | Altenburg, 2015^66^,^§^; COACH | Lifestyle/exercise counseling vs usual care | 65 weeks | 6MWD | 38 | Mean difference: NR, p=0.313^*^
Supervised exercise or pulmonary rehabilitation | Fastenau, 2020^68^ | Supervised exercise vs. low intensity exercise | 26 weeks | 6MWD | 67 | Mean difference: 20.1 (95% CI: −6.5 to 46.7)^†^
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR with maintenance program vs. usual care | 52 weeks | 6MWD | 36 | Mean difference in change: −13.5 (95%: −55.5 to 28.5)
Supervised exercise or pulmonary rehabilitation | Roman, 2013^74^ | PR vs. usual care | 52 weeks | 6MWD | 31 | Mean difference in change: −12.9 (95%: −56.7 to 30.7)

* Daily steps/daily physical activity (measured via pedometer) were also not significantly different between groups

† Reports other physical activity outcomes, none were significant other than handgrip strength.

‡ Reports Ex-SRES: Exercise self-efficacy (NS) and step counts (NS)

§ Also reports daily steps/daily physical activity (measured via pedometer) were also not significantly different between groups

Abbreviations: 6MWD= 6 minute walking distance during the 6 minute walk test (6MWT); CI = confidence interval; ESC = Every step counts; COACH = A Structured Lifestyle Intervention on Daily Physical Activity Level in COPD; IG = intervention group; IPAQ = International Physical Activity Questionnaire; IPAQ-SF = International Physical Activity Questionnaire short form; MET = metabolic equivalent of task; N = number; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; vs = versus

Table 14 Key Question 2 Results: Smoking Cessation and Vaccination Outcomes for Included Trials of Non-Pharmacologic Treatment

Intervention type | Author, Year; Study | Intervention comparison | Followup | Outcome | N analyzed | IG | CG | IG vs. CG
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 26 weeks | Smoking cessation | 114 | 14/64 (22%) | 9/50 (18%) | P=0.60
Self-management | Jolly, 2018^69^; PSM COPD | Phone-based self-management intervention vs. printed information | 52 weeks | Smoking cessation | 106 | 7/54 (13%) | 13/52 (25%) | P=0.11
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | 7-day point prevalence abstinence | 341 | NR | NR | OR=1.06 (95% CI: 0.43 to 2.66)
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | 24-hour point prevalence of abstinence | 341 | NR | NR | OR=0.72 (95% CI: 0.33 to 1.59)
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | Continued abstinence^*^ | 341 | NR | NR | OR=0.98 (95% CI: 0.37 to 2.63)
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | Prolonged abstinence^†^ | 341 | NR | NR | OR=0.86 (95% CI: 0.33 to 2.25)
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | Tobacco consumption | 341 | NR | NR | Beta-coefficient =0.11 (95% CI: −1.61 to 1.84)
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | Intention to quit smoking | 341 | NR | NR | Beta-coefficient =−0.03 (95% CI: −0.32 to 0.26)
Self-management | Voncken-Brewster, 2015^77^; MasterYourBreath | Web-based self-management intervention vs. usual care | 26 weeks | Number of quit attempts | 341 | NR | NR | Beta-coefficient=−0.38 (95% CI: −1.11 to 0.36)
Clinician education only | Zwar, 2016^80^; PELICAN | Clinician training vs. written information | 52 weeks | Number of current smokers | 222 | 28/126 (22%) | 25/96 (26%) | OR: 0.92 (95% CI: 0.44 to 1.91)
Clinician education only | Zwar, 2016^80^; PELICAN | Clinician training vs. written information | 52 weeks | Vaccinated for influenza | 222 | 91/126 (73%) | 54/96 (57%) | OR: 2.31 (95% CI: 1.06 to 5.03)
Clinician education only | Zwar, 2016^80^; PELICAN | Clinician training vs. written information | 52 weeks | Vaccinated for pneumococcus | 222 | 53/126 (48%) | 36/96 (38%) | OR: 1.54 (95% CI: 0.86 to 2.71)

* Not smoked at all since last quit date

† Not smoked in two weeks since last quit date)

Abbreviations: CG control group; CI = confidence interval; IG = intervention group; N = number; NR = not reported; OR = odds ratio; PELICAN = Primary care EarLy Intervention for Copd mANagement; PSM COPD = Patient self-management for chronic obstructive pulmonary disease; vs. = versus.

Overall, there were no consistent benefits seen in outcomes across the four RCTs evaluating web-based self-management interventions. Only one exercise-focused web-based intervention did demonstrate a reduction in exacerbations (Table 10). Two trials evaluated the same web-based self-management intervention which focused primarily on exercise (‘step count’).^78,^ ^86^ The initial trial by Moy and colleagues (n analyzed=238) found no difference in exacerbations or pneumonia at 52 weeks;^86^ whereas the second trial by Wan and colleagues (n analyzed=109)^78^ reported a reduction in exacerbations at 65 weeks in participants randomized to the web-based intervention versus the pedometer only group (relative risk [RR] 0.51 [95% CI, 0.31 to 0.85]).^78^ The absolute reduction in exacerbations is not reported, but at baseline, the mean (standard deviation) rate of COPD exacerbations in the prior year was 0.42 (0.98) in the intervention group and 0.27 (0.63) in the pedometer only group. All four trials reported disease-specific or general HRQoL outcomes using different instruments (i.e., CAT, CCQ, SGRQ, and EQ-5D); nonetheless, no trial demonstrated a clinically meaningful or statistically significant benefit in HRQoL at 26 or 52 weeks (Table 11).^73,^ ^77,^ ^78,^ ^86^ Two trials reporting dyspnea outcomes using either the MRC or modified version of the instrument found no statistically significant benefit at 26 or 52 weeks (Table 12).^73,^ ^77^ All four trials reported objective measures of exercise and found no improvement in exercise outcomes at 26 or 52 weeks, including both trials evaluating the exercise-focused web-based intervention (Table 13).^73,^ ^77,^ ^78,^ ^86^ In addition, one trial found no benefit in smoking cessation at 26 weeks, using a variety of measures (Table 14).^77^

##### Exercise Only Counseling

One trial by Altenburg and colleagues found no statistically significant benefit on HRQoL (using the CCQ, CRQ), or on objective measures of global physical performance (using the 6MWT) at 65 weeks for an in-person exercise counseling intervention (Tables 11 and 13). This study did not report any exacerbation or dyspnea outcomes.^66^

##### Supervised Exercise or Pulmonary Rehabilitation

Overall, there were no benefits in reported outcomes across the three trials evaluating supervised exercise or pulmonary rehabilitation interventions. Only one of these trials reported on exacerbations and found no reduction in exacerbations at 52 weeks (Table 10).^74^ All three trials reported disease specific HRQoL outcomes using different instruments (i.e., CAT, CCQ, SGRQ); none of the trials demonstrated a clinically meaningful or statistically significant benefit in HRQoL at 26 or 52 weeks (Table 11).^68,^ ^70,^ ^74^ None of the three trials reporting dyspnea outcomes using the CRQ (dyspnea domain), MRC or modified MRC instrument found a statistically significant benefit at 26 or 52 weeks (Table 12).^68,^ ^70,^ ^74^ One trial by Liang and colleagues reporting mental health outcomes found no improvement in depression and anxiety scores at 26 and 52 weeks (data not shown).^70^ Two trials reporting objective measures of physical performance found no improvement in the 6MWD at 26 and 52 weeks (Table 13).^68,^ ^74^

##### Clinician Education Only Interventions

Overall, there were no benefits in reported outcomes in the two cluster RCTs evaluating clinician education and training interventions; however, one trial by Zwar and colleagues (n analyzed= 222) did demonstrate a statistically significant increase in influenza but not pneumococcal vaccinations or smoking cessation at 52 weeks (Chapter 4: Discussion).^80^ Reporting of patient level outcomes was more limited for these trials as compared to the other included intervention trials. Neither trial found a benefit on disease specific HRQoL outcomes as measured by the CAT at 52 weeks (Table 11).

## KQ3 What Are the Adverse Effects of COPD Treatments in This Population?

### Summary of Results

Overall, there was very limited included evidence on the harms of pharmacologic and non-pharmacologic interventions in the treatment of mild to moderate, or minimally symptomatic COPD. None of the included trials (i.e., LAMA, LABA, LABA/LAMA or ICS with or without LABA, self-management intervention) that reported adverse effects (six trials) found significant harms. However, the small number of included participants and limited length of followup in the included trials (or their relevant subgroup analyses) limits the ability to detect uncommon harms or longer-term harms. Given this update’s focus on screen-relevant populations, only two large observational studies addressing harms of pharmacologic treatment met our inclusion criteria. These studies demonstrated that initiation of LAMA or LABA may increase the risk of a serious cardiovascular event in treatment naïve patients and that ICS may increase the risk of developing diabetes. However, these observational studies are a subset of a much larger body of evidence on serious harms of bronchodilators and ICS in COPD (Chapter 4: Discussion).

### Included Studies

#### Pharmacologic Interventions

The three included trials from Key Question 2 also report adverse effects (Tables 3 and 4).^72,^ ^76,^ ^83–85,^ ^87,^ ^88^ Two trials (PINNACLE and SUMMIT) evaluated LABAs, two trials (PINNACLE and UPLIFT) evaluated LAMAs, one trial (PINNACLE) evaluated LABA/LAMA, and one trial (SUMMIT) evaluated ICS with or without LABA. For a description of these trials, see Key Question 2: Included studies section.

In addition to these three trials, we also found two observational studies evaluating the harms of LABA, LAMA, or ICS in screen-relevant populations (Table 16). One nested case-control study in Taiwan by Wang and colleagues examined the cardiovascular risk for the initiation of LABA and LAMA in treatment naïve COPD patients.^82^ The other study was a matched cohort study in the UK by Price and colleagues which examined the risk of diabetes and osteoporosis from ICS use in populations in whom the majority of patients were stage I or II and GOLD category A or B.^81^ The mean age in the observational studies was slightly older than the trial populations. The mean FEV_1_ or symptom score was not reported, nonetheless the studies provided some indication of severity of COPD. The study by Price and colleagues conducted subgroup analysis for GOLD categories A and B patients.^81^ The vast majority of studies evaluating harms of pharmacologic treatment were excluded because no description was reported regarding the severity or symptoms of included populations. Both of these studies used large nationally representative databases and tried to adjust for known confounders.

Table 15 Key Question 3 Results: Adverse Events for Included RCTs of Pharmacologic Treatment

Drug Class | Study, year | Treatment Comparison | Followup | Outcome | N analyzed | IG Events | CG Events | IG vs. CG
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (median) | Adverse events | 8288 | 2820/4157 (68%) | 2782/4131 (67%) | NR
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (median) | Serious adverse events | 8288 | 929/4157 (22%) | 918/4131 (22%) | NR
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (median) | Fatal adverse events | 8288 | 183/4157 (4%) | 192/4131 (5%) | NR
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (median) | Medication discontinuation due to adverse event | 8288 | 367/4157 (9%) | 397/4131 (10%) | NR
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (median) | Pneumonia | 8288 | 228/4157 (5.5%) | 214/4131 (5.2%) | HR: 1.035 (95% CI, 0.859 to 1.247), p=0.716
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (median) | Severe pneumonia | 8288 | 146/4157 (3.5%) | 127/4131 (3.1%) | HR: 1.17 (95% CI, 0.880 to 1.416), p=0.364
ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate vs. placebo | 1.8 years (median) | Fatal pneumonia | 8288 | 10/4157 (0.2%) | 9/4131 (0/2%) | HR: 1.079 (95% CI, 0.438 to 2.657), p=0.868
LABA | PINNACLE; Martinez, 2020^72^ | Formoterol fumarate vs. placebo | 24 weeks | Serious adverse events | 318 | 15/205 (7.3%) | 7/113 (6.2%) | NR
LABA | PINNACLE; Martinez, 2020^72^ | Formoterol fumarate vs. placebo | 24 weeks | Serious adverse events related to study treatment^*^ | 318 | 0/205 (0%) | 1/113 (0.9%) | NR
LABA | PINNACLE; Martinez, 2020^72^ | Formoterol fumarate vs. placebo | 24 weeks | Treatment related adverse events leading to early discontinuation | 318 | 7/205 (3.4%) | 8/113 (7.1%) | NR
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (median) | Adverse events | 8271 | 2809/4140 (68%) | 2782/4131 (67%) | NR
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (median) | Serious adverse events | 8271 | 972/4140 (23%) | 918/4131 (22%) | NR
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (median) | Fatal adverse events | 8271 | 198/4140 (4%) | 192/4131 (5%) | NR
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (median) | Medication discontinuation due to adverse event | 8271 | 370/4140 (9%) | 397/4131 (10%) | NR
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (median) | Pneumonia | 8271 | 163/4140 (3.9%) | 214/4131 (5.2%) | HR: 0.722 (95% CI, 0.589 to 0.886), p=0.002
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (median) | Severe pneumonia | 8271 | 104/4140 (2.5%) | 127/4131 (3.1%) | HR: 0.778 (95% CI, 0.600 to 1.008), p=0.057
LABA | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Vilanterol vs. placebo | 1.8 years (median) | Fatal pneumonia | 8271 | 6/4140 (0.1%) | 9/4131 (0/2%) | HR: 0.632 (95% CI, 0.225 to 1.777), p=0.384
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (median) | Adverse events | 8271 | 2780/4140 (67%) | 2782/4131 (67%) | NR
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (median) | Serious adverse events | 8271 | 961/4140 (23%) | 918/4131 (22%) | NR
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (median) | Fatal adverse events | 8271 | 182/4140 (4%) | 192/4131 (5%) | NR
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (median) | Medication discontinuation due to adverse event | 8271 | 342/4140 (8%) | 397/4131 (10%) | NR
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (median) | Pneumonia | 8271 | 237/4140 (5.7%) | 214/4131 (5.2%) | HR: 1.038 (95% CI, 0.863 to 1.249), p=0.693
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (median) | Severe pneumonia | 8271 | 140/4140 (3.4%) | 127/4131 (3.1%) | HR: 1.022 (95% CI, 0.804 to 1.300), p=0.858
LABA/ICS | SUMMIT; Vestbo, 2016^76^; Crim, 2017^83^ | Fluticasone furoate/vilanterol vs. placebo | 1.8 years (median) | Fatal pneumonia | 8271 | 13/4140 (0.3%) | 9/4131 (0.2%) | HR: 1.330 (95% CI, 0.567 to 3.117), p=0.512
LAMA | UPLIFT; Decramer 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Adverse events leading to discontinuation | Stage II subset: 2,739 | 235/1384 (17.0%) | 241/1355 (17.8%) | NR
LAMA | UPLIFT; Decramer 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Adverse events leading to discontinuation | FEV_1_≥60% subset: 1210 | 98/632 (15.5%) | 88/578 (15.2%) | NR
LAMA | UPLIFT; Decramer 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Fatal Adverse event | Category A: 357 | 13/188 (6.9%) | 11/169 (6.5%) | RR: 1.03 (95% CI, 0.46 to 2.29)
LAMA | UPLIFT; Decramer 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Fatal major cardiac events | Category A: 357 | 4/188 (2.1%) | 12/169 (7.1%) | RR: 0.79 (95% CI, 0.35 to 1.78)
LAMA | UPLIFT; Decramer 2009^87^; Tashkin, 2012^88^; Tashkin, 2008^75^; Rabe, 2020^84^; Halpin, 2015^85^ | Tiotropium bromide vs. placebo | 48 months | Major adverse cardiac event | Category A: 357 | 11/188 (5.9%) | 3/169 (1.8%) | RR: 1.16 (95% CI, 0.26 to 5.18)
LAMA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate vs. placebo | 24 weeks | Serious adverse events | 308 | 7/195 (3.6%) | 7/113 (6.2%) | NR
LAMA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate vs. placebo | 24 weeks | Serious adverse events related to study treatment | 308 | 3/195 (1.5%) | 1/113 (0.9%) | NR
LAMA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate vs. placebo | 24 weeks | Treatment related adverse events leading to early discontinuation | 308 | 9/195 (4.6%) | 8/113 (7.1%) | NR
LAMA/LABA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate/formoterol fumarate vs. placebo | 24 weeks | Serious adverse events | 330 | 16/217 (7.4%) | 7/113 (6.2%) | NR
LAMA/LABA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate/formoterol fumarate vs. placebo | 24 weeks | Serious adverse events related to study treatment | 330 | 4/217 (1.8%) | 1/113 (0.9%) | NR
LAMA/LABA | PINNACLE; Martinez, 2020^72^ | Glycopyrrolate/formoterol fumarate vs. placebo | 24 weeks | Treatment related adverse events leading to early discontinuation | 330 | 12/217 (5.5%) | 8/113 (7.1%) | NR

* Adjudicated by investigator prior to unblinding

Abbreviations: CG = control group; CI = confidence interval; HR = hazard ratio; ICS = inhaled corticosteroids; IG = intervention group; LABA = long acting beta agonist; LAMA = long acting muscarinic antagonist; µg = microgram; N = number of participants; NR = not reported; RR = relative risk; SUMMIT = study to understand mortality and morbidity in COPD; UPLIFT = Understanding Potential Long-term Impacts on Function with Tiotropium; vs = versus.

Table 16 Key Question 3 Results: Adverse Events for Included Observational Studies of Pharmacologic Treatment

Drug Class | Study, year; Quality | Study design; Country, years | Population description | Outcome | N analyzed; Follow-up | IG vs. CG
LABA or LAMA | Wang, 2018^82^; Fair | Nested case-control; Taiwan, 2007-2011 | LABA-LAMA naïve patients; 71.4 years (mean); 31.1% female; mean FEV_1_ NR | Risk of cardiovascular disease | N=37,719 cases; N=146,139 controls; Mean 2.0 years | LABA new use; N=520 (1.4%) cases; N=1186 (0.8%) controls; Adjusted OR= 1.50 (95% CI: 1.35 to 1.67); LABA prevalent use; N=962 (2.6%) cases; N=3795 (2.6%) controls; Adjusted OR=0.91 (95% CI: 0.85 to 0.98); LAMA new use; N=190 (0.5%) cases; N=463 (0.3%) controls; Adjusted OR= 1.52 (95% CI: 1.28 to 1.80); LAMA prevalent use; N=458 (1.2%) cases; N=1977 (1.4) controls; Adjusted OR= 0.88 (95% CI: 0.79 to 0.98)
ICS | Price, 2019^81^; Fair | Cohort; UK, 1990-2015 | Mean age 68-71 years; 38-41% female; 55-74% stage 1/2; 63-66% GOLD class A/B | Diabetes onset; (ICS vs. LABA initiation) | N = 17,970 (Category A/B subset: N = 9,923); Median 3.7-5.6 years | All patients; HR=1.27 (95% CI, 1.07 to 1.50); Gold A/B; HR=1.32(95% CI, 1.06 to 1.64)
ICS | Price, 2019^81^; Fair | Cohort; UK, 1990-2015 | Mean age 68-71 years; 38-41% female; 55-74% stage 1/2; 63-66% GOLD class A/B | Diabetes progression; (ICS vs. LABA initiation) | N = 804 (Category A/B subset: N = 492); Median 3.7-5.6 years | All patients; HR=1.04 (95% CI, 0.87 to 1.25); GOLD A/B; HR=1.01 (95% CI, 0.80 to 1.28)
ICS | Price, 2019^81^; Fair | Cohort; UK, 1990-2015 | Mean age 68-71 years; 38-41% female; 55-74% stage 1/2; 63-66% GOLD class A/B | Osteoporosis onset; (ICS vs. LABA initiation) | N = 19,898 (Category A/B subset: N = 11,057); Median 3.7-5.6 years | All patients; HR=1.13 (95% CI, 0.93 to 1.39); GOLD A/B; HR=1.06 (95% CI, 0.82 to 1.37)

Abbreviations: CG = control group; CI = confidence interval; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in one second; GOLD = Global Initiative for Chronic Obstructive Lung Disease; HR = hazard ratio; ICS = inhaled corticosteroid; IG = intervention group; LABA = long-acting beta agonist; LAMA = long acting muscarinic antagonist; N = number; NR = not reported; OR = odds ratio; vs = versus.

#### Non-Pharmacologic Interventions

Only three of the included non-pharmacologic intervention trials from Key Question 2 also reported on harms.^69,^ ^78,^ ^86^ We found no additional studies that specifically evaluated the harms of non-pharmacologic interventions in a screen-relevant population. All three trials evaluated self-management interventions. One trial by Jolly and colleagues (n=577) conducted in the UK, explicitly recruited minimally symptomatic persons with COPD (MRC score 1 or 2) and evaluated a phone-based intervention. The other two trials by Moy and colleagues (n=238) and by Wan and colleagues (n=114) were conducted in VA settings and included more symptomatic persons and evaluated an exercise-focused web-based intervention. For additional details of these trials, see Key Question 2: Included studies section.

### Detailed Results

#### Pharmacologic Interventions

Overall, none of the included trials found significant harms for LAMA, LABA, LABA/LAMA, or ICS with or without LABA (Table 15). However, the subgroup analyses from PINNACLE and UPLIFT included a limited number of participants and therefore are quite limited in their ability to detect less common harms, and both PINNACLE and SUMMIT have limited length of followup and therefore are limited in their ability to detect longer term harms.

The analysis from the PINNACLE trials evaluating glycopyrrolate (LAMA), formoterol fumarate (LABA), and glycopyrrolate/formoterol fumarate (LAMA/LABA) versus placebo in GOLD category A patients (n=729) reported adverse outcomes at 24 weeks.^72^ This pooled analysis across three trials did not report any statistically significant harms. There is a signal of increased serious adverse events related to study treatment for LABA/LAMA compared to placebo (1.8 percent versus 0.9 percent), but this was based on a total of 5 adverse events across both arms.

The SUMMIT trial (n=16,590) in persons with mild to moderate COPD (mean FEV_1_ 59.7 percent, SGRQ 45-46) found that vilanterol (LABA), fluticasone furoate (ICS), and vilanterol/fluticasone furoate (LABA/ICS) did not increase adverse events compared to placebo at a median followup of 1.8 years.^76,^ ^83^ This trial did not find an increase in pneumonias from ICS with or without LABA. In fact, this study demonstrated that LABA alone reduced pneumonias compared to placebo at a median of 1.8 years, 3.9 versus 5.2 percent (HR 0.72 [95% CI, 0.59 to 0.89]).

The subgroup analyses from the UPLIFT trial did not report any increase in adverse events from tiotropium (LAMA) versus placebo at 48 months.^84,^ ^85,^ ^87,^ ^88^ However, in the subgroup analysis of GOLD category A patients (n=357), there is a signal of increased major adverse cardiac events from LAMA compared to placebo (5.9 percent versus 1.8 percent), but this was based on a total of 14 adverse events across both arms.^85^

The nested case-control study by Wang and colleagues (n=37,719 cases and 146,139 controls) observed that the initiation of both LABA and LAMA was associated with an increase in cardiovascular events within 30 days of its initiation (OR 1.50 [95% CI, 1.35 to 1.67 and adj OR 1.52 [95% CI, 1.28 to 1.80], respectively). However, notably this risk association was absent, or even reduced, with prevalent use. Risk of cardiovascular events did not seem to vary by different LABA or LAMA drugs, concomitant COPD medications, history of CVD, or history of prior COPD exacerbations (Table 16).^82^

The matched cohort study by Price and colleagues (n= 17,970 for diabetes onset and n= 19,898 for osteoporosis onset) observed that long-term ICS use, compared with long-acting bronchodilator use, was associated with an increased risk of developing diabetes (HR 1.27 [95% CI, 1.07 to 1.50]). The subgroup analysis conducted in GOLD categories A and B patients combined had similar findings (Table 16). The study also noted a dose–response relationships at mean ICS exposures of 500 µg/day or greater versus less than 250 µg/day, fluticasone propionate–equivalent.^81^ The association with an increased risk of developing osteoporosis was not statistically significant and not observed in the subgroup analysis in GOLD categories A and B patients.

#### Non-Pharmacologic Interventions

The RCT by Jolly and colleagues (n=577) reported no difference in self-reported adverse events at 52 weeks between the phone-based intervention compared to the usual care group (24 versus 20 events, p value NR).^69^ The RCT by Moy and colleagues (n=238) reported no difference in pulmonary or cardiac adverse events between the web-based intervention and pedometer only groups; however, more minor musculoskeletal adverse events occurred in the intervention group (27.9%) than the pedometer group (10%).^86^ The RCT by Wan and colleagues (n=114) reported no statistically significant difference in adverse events at 13 weeks between the group receiving the web-based intervention compared to the pedometer only group (14 versus 10 events, p=0.54 respectively).^78^ In all of the trials, none of the serious adverse events were determined to be related to the study intervention.