# Appendix E Ongoing Studies

Appendix E Table 1 Ongoing COPD Screening, Active Case-Finding, and Treatment Trials

Study reference/ trial identifier; Primary Investigator | Study name | Location | Estimated N | Intervention Description | Relevant Outcomes | Status^*^; Estimated Completion
Screening or active case-finding
NCT03583099; Fernando J Martinez; MeiLan Han | The CAPTURE Study: Validating a Unique COPD Case Finding Tool in Primary Care (Aim 3) (CAPTURE) | United States | 5000 | Physician education and use of CAPTURE tool (screening questionnaire and PEF measurement) | COPD symptoms scores, exacerbations, hospitalization, mortality | Ongoing; Estimated completion: December 1, 2021
Treatment
NCT03654092; Anja Frei | Home-based Exercise Training for COPD Patients (HOMEX-2) | Switzerland | 120 | Home-based exercise program | COPD symptoms, HRQoL, exacerbations | Recruiting; Estimated completion: October 2020
ACTRN12618001091291; Ian Yang | Mobile Health for Chronic Obstructive Pulmonary Disease (COPD) | Australia | 100 | COPD mobile health app (education, action plan, monitoring symptoms, modification of risk factors) | COPD symptoms, QoL, lifestyle changes, exacerbations, hospital admissions | Ongoing; Estimated completion: 2021
NCT03746873; Karin Wadell | Increase Level of Physical Activity and Decrease Use of Health Care for People With COPD (COPD) | Sweden | 144 | COPD Web: interactive web based tool to increase physical activity and appropriate self-management strategies | Pedometer with written information about physical activity | Recruiting; Estimated completion: March 15, 2022
NCT04139200; Thierry Troosters | Long-term Activity Coaching in Patients With COPD | Belgium | 150 | Long-term Activity Coaching in Patients With COPD | Health status, HRQoL, anxiety and depression | Ongoing; Estimated completion: November 2021

* As of December 2021