# Appendix D Excluded Studies List

Exclusion Code | Definition
E1 | Study relevance
E2 | Setting
E2a | Not Very High Human Development Index
E3 | Population (general)
E3a | Not screen relevant population
E4 | Study quality
E5 | Study design
E6 | Wrong intervention
E7 | Wrong comparator
E8 | No relevant outcomes
E9 | Non-English publication
E10 | Publication Type (i.e., conference abstract)

1 Aljaafareh, A, Valle, JR, . Risk of cardiovascular events after initiation of long-acting bronchodilators in patients with chronic obstructive lung disease: A population-based study. SAGE Open Medicine. 4. 2050312116671337. 2016. KQ1E1, KQ2E1, KQ3E3a27757229
2 Anzueto, A, Jenkins, CR, . Efficacy of an inhaled corticosteroid/long-acting beta2-agonist combination in symptomatic COPD patients in GOLD groups B and D. Eur Respir J. 46(1): 255–8. 2015. KQ1E1, KQ2E7, KQ3E826022947
3 Anzueto, AR, Kostikas, K, . Indacaterol/glycopyrronium versus salmeterol/fluticasone in the prevention of clinically important deterioration in COPD: results from the FLAME study. Respir Res. 19(1): 121. 2018. KQ1E1, KQ2E7, KQ3E829925383
4 Arora, S, Delacruz, L, . 24-Hour Lung Function Following the Novel LAMA/LABA Co-Suspension Technology of Glycopyrrolate/Formoterol Fixed-Dose Combination MDI, in Patients with Moderate-to-Very-Severe COPD. Am J Respir Crit Care Med. 193(Meeting Abstracts): A6792. 2016. KQ1E1, KQ2E5, KQ3E8
5 Barakat, S, Michele, G, . Outpatient pulmonary rehabilitation in patients with chronic obstructive pulmonary disease. Int J Chron Obstruct Pulmon Dis. 3(1): 155–62. 2008. KQ1E1, KQ2E5, KQ3E818488439
6 Bateman, ED, Chapman, KR, . Aclidinium bromide and formoterol fumarate as a fixed-dose combination in COPD: pooled analysis of symptoms and exacerbations from two six-month, multicentre, randomised studies (ACLIFORM and AUGMENT). Respir Res. 16. 92. 2015. KQ1E1, KQ2E3a, KQ3E826233481
7 Beeh, KM, Westerman, J, . The 24-h lung-function profile of once-daily tiotropium and olodaterol fixed-dose combination in chronic obstructive pulmonary disease. Pulm Pharmacol Ther. 32. 53–9. 2015. KQ1E1, KQ2E5, KQ3E825956072
8 Behnke, M, Taube, C, . Home-based exercise is capable of preserving hospital-based improvements in severe chronic obstructive pulmonary disease. Respir Med. 94(12): 1184–91. 2000. KQ1E1, KQ2E3a, KQ3E811192954
9 Bender, Bg, Make, Bj, . Enhancing physical activity in patients with chronic obstructive pulmonary disease (COPD) through a program of patient selected goals. Am J Respir Crit Care Med. 191(Meeting Abstracts): A2458. 2015. KQ1E1, KQ2E5, KQ3E8
10 Bendstrup, KE, Ingemann Jensen, J, . Out-patient rehabilitation improves activities of daily living, quality of life and exercise tolerance in chronic obstructive pulmonary disease. Eur Respir J. 10(12): 2801–6. 1997. KQ1E1, KQ2E3a, KQ3E89493664
11 Berry, MJ, Rejeski, WJ, . A lifestyle activity intervention in patients with chronic obstructive pulmonary disease. Respir Med. 104(6): 829–39. 2010. KQ1E1, KQ2E3a, KQ3E820347286
12 Bestall, JC, Paul, EA, . Longitudinal trends in exercise capacity and health status after pulmonary rehabilitation in patients with COPD. Respir Med. 97(2): 173–80. 2003. KQ1E1, KQ2E3a, KQ3E812587969
13 Blumenthal, JA, Emery, CF, . The effects of a telehealth coping skills intervention on outcomes in chronic obstructive pulmonary disease: primary results from the INSPIRE-II study. Psychosom Med. 76(8): 581–92. 2014. KQ1E1, KQ2E5, KQ3E825251888
14 Boeselt, T, Nell, C, . Benefits of High-Intensity Exercise Training to Patients with Chronic Obstructive Pulmonary Disease: A Controlled Study. Respiration. 93(5): 301–310. 2017. KQ1E1, KQ2E5, KQ3E828329753
15 Boland, Mr, Tsiachristas, A, . Copd Performance Indicators In An Integrated Care Program And Its Impact On Health Outcomes: the Recode Cluster Randomized Trial. Value in health. 18(7): A505. 2015. KQ1E1, KQ2E5, KQ3E8
16 Bourbeau, J, Julien, M, . Reduction of hospital utilization in patients with chronic obstructive pulmonary disease: a disease-specific self-management intervention. Arch Intern Med. 163(5): 585–91. 2003. KQ1E1, KQ2E3a, KQ3E3a12622605
17 Boxall, AM, Barclay, L, . Managing chronic obstructive pulmonary disease in the community. A randomized controlled trial of home-based pulmonary rehabilitation for elderly housebound patients. J Cardiopulm Rehabil. 25(6): 378–85. 2005. KQ1E1, KQ2E3a, KQ3E816327534
18 Breyer, MK, Breyer-Kohansal, R, . Nordic walking improves daily physical activities in COPD: a randomised controlled trial. Respir Res. 11. 112. 2010. KQ1E1, KQ2E3a, KQ3E820727209
19 Bringsvor, HB, Langeland, E, . Effects of a COPD self-management support intervention: a randomized controlled trial. International Journal of Copd. 13. 3677–3688. 2018. KQ1E1, KQ2E3a, KQ3E830510410
20 Brooks, D, Krip, B, . The effect of postrehabilitation programmes among individuals with chronic obstructive pulmonary disease. Eur Respir J. 20(1): 20–9. 2002. KQ1E1, KQ2E3a, KQ3E812166571
21 Bucknall, CE, Miller, G, . Glasgow supported self-management trial (GSuST) for patients with moderate to severe COPD: randomised controlled trial. BMJ. 344. e1060. 2012. KQ1E1, KQ2E3a, KQ3E822395923
22 Buhl, R, Magder, S, . Long-term general and cardiovascular safety of tiotropium/olodaterol in patients with moderate to very severe chronic obstructive pulmonary disease. Respir Med. 122. 58–66. 2017. KQ1E1, KQ2E7, KQ3E827993292
23 Buhl, R, Maltais, F, . Tiotropium and olodaterol fixed-dose combination versus mono-components in COPD (GOLD 2-4). Eur Respir J. 45(4): 969–79. 2015. KQ1E1, KQ2E7, KQ3E825573406
24 Callejas Gonzalez, FJ, Genoves Crespo, M, . UPLIFT study - understanding potential long-term impacts on function with tiotropium - and sub-analyses. Bibliographic resume of the obtained results. Expert Rev Respir Med. 10(9): 1023–33. 2016. KQ1E1, KQ2E5, KQ3E827176208
25 Calverley, PM, Page, C, . Effect of Erdosteine on COPD Exacerbations in COPD Patients with Moderate Airflow Limitation. International Journal of Copd. 14. 2733–2744. 2019. KQ1E1, KQ2E3a, KQ3E3a31819405
26 Casas, A, Troosters, T, . Integrated care prevents hospitalisations for exacerbations in COPD patients. Eur Respir J. 28(1): 123–30. 2006. KQ1E1, KQ2E3a, KQ3E816611656
27 Cascini, S, Kirchmayer, U, . Inhaled Corticosteroid Use in Chronic Obstructive Pulmonary Disease and Risk of Pneumonia: A Nested Case-Control Population-based Study in Lazio (Italy)-The OUTPUL Study. Copd: Journal of Chronic Obstructive Pulmonary Disease. 14(3): 311–317. 2017. KQ1E1, KQ2E1, KQ3E3a28406337
28 Celli, Br, Decramer, M, . Defining a COPD composite safety endpoint for demonstrating efficacy in clinical trials: results from the randomized, placebo-controlled UPLIFT trial. Respir Res. 17(1). 2016. KQ1E1, KQ2E3a, KQ3E8
29 Chan, AW, Lee, A, . Effectiveness of a Tai chi Qigong program in promoting health-related quality of life and perceived social support in chronic obstructive pulmonary disease clients. Qual Life Res. 19(5): 653–64. 2010. KQ1E1, KQ2E5, KQ3E820229333
30 Chapron, A, Pele, F, . Targeted screening of COPD in primary care: feasibility and effectiveness. Rev Mal Respir. 2019. KQ1E9, KQ2E9, KQ3E9
31 Charususin, N, Gosselink, R, . Randomised controlled trial of adjunctive inspiratory muscle training for patients with COPD. Thorax. 73(10): 942–950. 2018. KQ1E1, KQ2E5, KQ3E829914940
32 Chen, W, Sadatsafavi, M, . Effects of beta2-Adrenergic Agonists on Risk of Parkinson’s Disease in COPD: A Population-Based Study. Pharmacotherapy:The Journal of Human Pharmacology & Drug Therapy. 40(5): 408–415. 2020. KQ1E1, KQ2E1, KQ3E3a
33 Chien, C-L, Liu, Y-F, . Impact of Multidisciplinary Self-Management Education Program in Patients with Chronic Obstructive Pulmonary Disease: self-Efficacy, Exercise Tolerance, and Quality of Life. Am J Respir Crit Care Med. 193(Meeting Abstracts): A7863. 2016. KQ1E1, KQ2E5, KQ3E8
34 Chiu, KL, Lee, CC, . Evaluating the association of osteoporosis with inhaled corticosteroid use in chronic obstructive pulmonary disease in Taiwan. Sci Rep. 11(1): 724. 2021. 10.1038/s41598-020-80815-y KQ1E1, KQ2E1, KQ3E3a33436973
35 Cockcroft, A, Bagnall, P, . Controlled trial of respiratory health worker visiting patients with chronic respiratory disability. Br Med J (Clin Res Ed). 294(6566): 225–8. 1987. KQ1E1, KQ2E5, KQ3E8
36 Coultas, D, Frederick, J, . A randomized trial of two types of nurse-assisted home care for patients with COPD. Chest. 128(4): 2017–24. 2005. KQ1E1, KQ2E3a, KQ3E3a16236850
37 Coultas, D, Jackson, B, . A lifestyle physical activity intervention is associated with fewer self-reported COPD-related hospitalizations. Eur Respir J. 48(Suppl 60): Pa2060. 2016. KQ1E10, KQ2E10, KQ3E10
38 Coultas, DB, Jackson, BE, . A Lifestyle Physical Activity Intervention for Patients with Chronic Obstructive Pulmonary Disease. A Randomized Controlled Trial. Ann Am Thorac Soc. 13(5): 617–26. 2016. KQ1E1, KQ2E3a, KQ3E3a26785249
39 Coultas, DB, Jackson, BE, . Home-based Physical Activity Coaching, Physical Activity, and Health Care Utilization in Chronic Obstructive Pulmonary Disease. Chronic Obstructive Pulmonary Disease Self-Management Activation Research Trial Secondary Outcomes. Ann Am Thorac Soc. 15(4): 470–478. 2018. KQ1E1, KQ2E3a, KQ3E3a29283670
40 Coventry, PA, Blakemore, A, . The Push and Pull of Self-Managing Mild COPD: An Evaluation of Participant Experiences of a Nurse-Led Telephone Health Coaching Intervention. Qual Health Res. 29(5): 658–671. 2019. KQ1E1, KQ2E5, KQ3E830501475
41 Cruz, J, Brooks, D, . Walk2Bactive: A randomised controlled trial of a physical activity-focused behavioural intervention beyond pulmonary rehabilitation in chronic obstructive pulmonary disease. Chron Respir Dis. 13(1): 57–66. 2016. KQ1E1, KQ2E5, KQ3E126703921
42 de Roos, P, Lucas, C, . Effectiveness of a combined exercise training and home-based walking programme on physical activity compared with standard medical care in moderate COPD: a randomised controlled trial. Physiotherapy. 104(1): 116–121. 2018. KQ1E1, KQ2E5, KQ3E828802772
43 Dheda, K, Crawford, A, . Implementation of British Thoracic Society guidelines for acute exacerbation of chronic obstructive pulmonary disease: impact on quality of life. Postgrad Med J. 80(941): 169–71. 2004. KQ1E1, KQ2E3a, KQ3E815016940
44 Does Adherence to GOLD Recommendations Regarding Inhaler Therapy Lead to Better Patient Outcomes?: insights from the LOTT Trial. Chest. 158(2): 437–439. 2020. 10.1016/j.chest.2020.04.031 KQ1E1, KQ2E5, KQ3E832768056
45 Donohue, Jf, Bollu, V, . Improvements in health status for individuals with COPD treated with nebulized arformoterol tartrate: results from a 52-week trial. Am J Respir Crit Care Med. 191(Meeting Abstracts): A3983. 2015. KQ1E1, KQ2E3a, KQ3E8
46 Donohue, JF, Bollu, VK, . Long-term health-related quality-of-life and symptom response profiles with arformoterol in COPD: results from a 52-week trial. International Journal of Copd. 13. 499–508. 2018. KQ1E1, KQ2E3a, KQ3E829440887
47 Donohue, JF, Ganapathy, V, . Health Status of Patients with Moderate to Severe COPD after Treatment with Nebulized Arformoterol Tartrate or Placebo for 1 Year. Clin Ther. 39(1): 66–74. 2017. KQ1E1, KQ2E3a, KQ3E828011247
48 Donohue, JF, Kerwin, E, . Maintained therapeutic effect of revefenacin over 52 weeks in moderate to very severe Chronic Obstructive Pulmonary Disease (COPD). Respir Res. 20(1): 241. 2019. KQ1E1, KQ2E7, KQ3E831666076
49 Donohue, JF, Kerwin, E, . Revefenacin, a once-daily, lung-selective, long-acting muscarinic antagonist for nebulized therapy: Safety and tolerability results of a 52-week phase 3 trial in moderate to very severe chronic obstructive pulmonary disease. Respir Med. 153. 38–43. 2019. KQ1E1, KQ2E7, KQ3E831150963
50 du Moulin, M, Taube, K, . Home-based exercise training as maintenance after outpatient pulmonary rehabilitation. Respiration. 77(2): 139–45. 2009. KQ1E1, KQ2E6, KQ3E618667807
51 Duruturk, N, Arikan, H, . A comparison of calisthenic and cycle exercise training in chronic obstructive pulmonary disease patients: a randomized controlled trial. Expert Rev Respir Med. 10(1): 99–108. 2016. KQ1E1, KQ2E5, KQ3E826616764
52 D’Urzo, A, Rennard, S, . A randomised double-blind, placebo-controlled, long-term extension study of the efficacy, safety and tolerability of fixed-dose combinations of aclidinium/formoterol or monotherapy in the treatment of chronic obstructive pulmonary disease. Respir Med. 125. 39–48. 2017. KQ1E1, KQ2E3a, KQ3E828340861
53 Eaton, T, Young, P, . Does early pulmonary rehabilitation reduce acute health-care utilization in COPD patients admitted with an exacerbation? A randomized controlled study. Respirology. 14(2): 230–8. 2009. KQ1E1, KQ2E5, KQ3E819272084
54 Effects of low impact aerobic exercise in COPD. Biomedical and pharmacology journal. 13(1): 237–243. 2020. 10.13005/bpj/1881 KQ1E1, KQ2E5, KQ3E8
55 Efraimsson, EO, Hillervik, C, . Effects of COPD self-care management education at a nurse-led primary health care clinic. Scand J Caring Sci. 22(2): 178–85. 2008. KQ1E1, KQ2E5, KQ3E818489687
56 Elci, A, Borekci, S, . The efficacy and applicability of a pulmonary rehabilitation programme for patients with COPD in a secondary-care community hospital. Respirology. 13(5): 703–7. 2008. KQ1E1, KQ2E5, KQ3E818713091
57 Engstrom, CP, Persson, LO, . Long-term effects of a pulmonary rehabilitation programme in outpatients with chronic obstructive pulmonary disease: a randomized controlled study. Scand J Rehabil Med. 31(4): 207–13. 1999. KQ1E1, KQ2E3a, KQ3E810599897
58 Ernst, P, Coulombe, J, . The Risk of Sepsis with Inhaled and Oral Corticosteroids in Patients with COPD. Copd: Journal of Chronic Obstructive Pulmonary Disease. 14(2): 137–142. 2017. KQ1E1, KQ2E1, KQ3E3a28010132
59 Farmer, A, Williams, V, . Self-Management Support Using a Digital Health System Compared With Usual Care for Chronic Obstructive Pulmonary Disease: Randomized Controlled Trial. J Med Internet Res. 19(5): e144. 2017. KQ1E1, KQ2E3a, KQ3E3a28468749
60 Farmer, A, Williams, V, . Self-management support using an Internet-linked tablet computer based intervention in chronic obstructive pulmonary disease (EDGE): randomised controlled trial. Npj primary care respiratory medicine. 26(16022): 10-cr024. 2016. KQ1E10, KQ2E10, KQ3E10
61 Ferguson, GT, Flezar, M, . Efficacy of Tiotropium + Olodaterol in Patients with Chronic Obstructive Pulmonary Disease by Initial Disease Severity and Treatment Intensity: A Post Hoc Analysis. Adv Ther. 32(6): 523–36. 2015. KQ1E1, KQ2E7, KQ3E826112656
62 Ferguson, GT, Kerwin, EM, . Health-Related Quality of Life Improvements in Moderate to Very Severe Chronic Obstructive Pulmonary Disease Patients on Nebulized Glycopyrrolate: Evidence from the GOLDEN Studies. Chronic Obstructive Pulmonary Diseases. 5(3): 193–207. 2018. KQ1E1, KQ2E5, KQ3E830584583
63 Ferguson, GT, Papi, A, . Budesonide/formoterol MDI with co-suspension delivery technology in COPD: the TELOS study. Eur Respir J. 52(3): 09. 2018. KQ1E1, KQ2E7, KQ3E8
64 Finnerty, JP, Keeping, I, . The effectiveness of outpatient pulmonary rehabilitation in chronic lung disease: a randomized controlled trial. Chest. 119(6): 1705–10. 2001. KQ1E1, KQ2E3a, KQ3E811399694
65 Freund, T, Peters-Klimm, F, . Medical Assistant-Based Care Management for High-Risk Patients in Small Primary Care Practices: A Cluster Randomized Clinical Trial. Ann Intern Med. 164(5): 323–30. 2016. KQ1E1, KQ2E3a, KQ3E3a26833209
66 Gallefoss, F, Bakke, PS, . Quality of life assessment after patient education in a randomized controlled study on asthma and chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 159(3): 812–7. 1999. KQ1E1, KQ2E3a, KQ3E810051255
67 Gallo-Silva, B, Cerezer-Silva, V, . Effects of Water-Based Aerobic Interval Training in Patients With COPD: A RANDOMIZED CONTROLLED TRIAL. J Cardiopulm Rehabil Prev. 39(2): 105–111. 2019. KQ1E1, KQ2E5, KQ3E830720640
68 Gayle, A, Dickinson, S, . Incidence of type II diabetes in chronic obstructive pulmonary disease: a nested case-control study. NPJ Primary Care Respiratory Medicine. 29(1): 28. 2019. KQ1E1, KQ2E1, KQ3E3a
69 Gon, Y, Nishi, K, . Efficacy and safety of glycopyrrolate/formoterol fumarate metered dose inhaler delivered using co-suspension delivery technology in Japanese patients with moderate-to-very severe chronic obstructive pulmonary disease. Respir Investig. 59(1): 135–144. 2021. 10.1016/j.resinv.2020.06.007 KQ1E1, KQ2E3a, KQ3E8
70 Gonzalez, Ic, Espinosa, Ra, . A self-treatment programme in patients with COPD: effectiveness for the reduction of severe exacerbations. Eur Respir J. 46. 2015. KQ1E10, KQ2E10, KQ3E10
71 Gonzalez, AV, Coulombe, J, . Long-term Use of Inhaled Corticosteroids in COPD and the Risk of Fracture. Chest. 153(2): 321–328. 2018. KQ1E1, KQ2E1, KQ3E3a28716642
72 Gottlieb, V, Lyngso, AM, . Pulmonary rehabilitation for moderate COPD (GOLD 2)--does it have an effect?. COPD. 8(5): 380–6. 2011. KQ1E1, KQ2E4, KQ3E421936683
73 Hakim, A, Khan, Y, . Low-Dose Budesonide/Formoterol Counteracts Airway Inflammation and Improves Lung Function in Chronic Obstructive Pulmonary Disease. Am J Respir Crit Care Med. 199(5): 662–664. 2019. KQ1E1, KQ2E5, KQ3E830540486
74 Hanania, NA, Papi, A, . Efficacy and safety of two doses of budesonide/formoterol fumarate metered dose inhaler in COPD. Erj Open Research. 6(2). 2020. KQ1E1, KQ2E7, KQ3E8
75 Hanania, NA, Sethi, S, . Long-term safety and efficacy of formoterol fumarate inhalation solution in patients with moderate-to-severe COPD. International Journal of Copd. 14. 117–127. 2019. KQ1E1, KQ2E3a, KQ3E830643398
76 He, GX, Li, N, . Benefits of different intensities of pulmonary rehabilitation for patients with moderate-to-severe COPD according to the GOLD stage: a prospective, multicenter, single-blinded, randomized, controlled trial. International Journal of Copd. 14. 2291–2304. 2019. KQ1E2a, KQ2E2a, KQ3E2a31631999
77 Hermiz, O, Comino, E, . Randomised controlled trial of home based care of patients with chronic obstructive pulmonary disease. BMJ. 325(7370): 938. 2002. KQ1E1, KQ2E5, KQ3E812399344
78 Hernandez, C, Casas, A, . Home hospitalisation of exacerbated chronic obstructive pulmonary disease patients. Eur Respir J. 21(1): 58–67. 2003. KQ1E1, KQ2E5, KQ3E812570110
79 Hernandez, M, Zambom-Ferraresi, F, . Short and long term effects of a physical activity programa in COPD patients. Eur Respir J. 2015. KQ1E10, KQ2E10, KQ3E10
80 Hernandez, MT, Rubio, TM, . Results of a home-based training program for patients with COPD. Chest. 118(1): 106–14. 2000. KQ1E1, KQ2E5, KQ3E810893367
81 Holland, AE, Mahal, A, . Home-based rehabilitation for COPD using minimal resources: a randomised, controlled equivalence trial. Thorax. 72(1): 57–65. 2017. KQ1E1, KQ2E3a, KQ3E827672116
82 Hoogendoorn, M, van Wetering, CR, . Self-report versus care provider registration of healthcare utilization: impact on cost and cost-utility. Int J Technol Assess Health Care. 25(4): 588–95. 2009. KQ1E1, KQ2E5, KQ3E819845991
83 Horne, BD, Hegewald, MJ, . The Summit Score Stratifies Mortality and Morbidity in Chronic Obstructive Pulmonary Disease. International Journal of Copd. 15. 1741–1750. 2020. 10.2147/COPD.S254437 KQ1E1, KQ2E5, KQ3E832764918
84 Hospes, G, Bossenbroek, L, . Enhancement of daily physical activity increases physical fitness of outclinic COPD patients: results of an exercise counseling program. Patient Educ Couns. 75(2): 274–8. 2009. KQ1E1, KQ2E5, KQ3E819036552
85 Howard, C, Dupont, S. ‘The COPD breathlessness manual’: a randomised controlled trial to test a cognitive-behavioural manual versus information booklets on health service use, mood and health status, in patients with chronic obstructive pulmonary disease. NPJ Prim Care Respir Med. 24. 14076. 2014. KQ1E1, KQ2E3a, KQ3E825322078
86 Huang, TM, Kuo, KC, . Risk of active tuberculosis among COPD patients treated with fixed combinations of long-acting beta2 agonists and inhaled corticosteroids. BMC Infect Dis. 20(1): 706. 2020. 10.1186/s12879-020-05440-6 KQ1E1, KQ2E1, KQ3E3a32977747
87 Hynninen, MJ, Bjerke, N, . A randomized controlled trial of cognitive behavioral therapy for anxiety and depression in COPD. Respir Med. 104(7): 986–94. 2010. KQ1E1, KQ2E3a, KQ3E820346640
88 Jackson, Be, Coultas, D, . Benefits of a lifestyle physical activity intervention for COPD are limited to patients with moderate impairment. Am J Respir Crit Care Med. 191(Meeting Abstracts): A4448. 2015. KQ1E10, KQ2E10, KQ3E10
89 Janson, C, Lisspers, K, . Osteoporosis and fracture risk associated with ICS use among Swedish COPD patients: the ARCTIC study. Eur Respir J. 24. 24. 2020. 10.1183/13993003.00515-2020 KQ1E1, KQ2E1, KQ3E8
90 Jarab, AS, Alqudah, SG, . Impact of pharmaceutical care on health outcomes in patients with COPD. Int J Clin Pharm. 34(1): 53–62. 2012. KQ1E1, KQ2E3a, KQ3E822101426
91 Jonsdottir, H, Amundadottir, OR, . Effectiveness of a partnership-based self-management programme for patients with mild and moderate chronic obstructive pulmonary disease: a pragmatic randomized controlled trial. J Adv Nurs. 71(11): 2634–49. 2015. KQ1E1, KQ2E3a, KQ3E826193907
92 Jordan, RE, Adab, P, . Targeted case finding for chronic obstructive pulmonary disease versus routine practice in primary care (TargetCOPD): a cluster-randomised controlled trial. Lancet Respir Med. 4(9): 720–730. 2016. KQ1E8, KQ2E1, KQ3E127444687
93 Kalter-Leibovici, O, Benderly, M, . Disease Management plus Recommended Care versus Recommended Care Alone for Ambulatory Patients with Chronic Obstructive Pulmonary Disease. Am J Respir Crit Care Med. 197(12): 1565–1574. 2018. KQ1E1, KQ2E3a, KQ3E829494211
94 Karapolat, H, Atasever, A, . Do the benefits gained using a short-term pulmonary rehabilitation program remain in COPD patients after participation?. Lung. 185(4): 221–5. 2007. KQ1E1, KQ2E5, KQ3E817487535
95 Kawamatsu, S, Jin, R, . Scores of Health-Related Quality of Life Questionnaire Worsen Consistently in Patients of COPD: Estimating Disease Progression over 30 Years by SReFT with Individual Data Collected in SUMMIT Trial. J Clin Med. 9(8): 18. 2020. 10.3390/jcm9082676 KQ1E1, KQ2E5, KQ3E8
96 Kayahan, B, Karapolat, H, . Psychological outcomes of an outpatient pulmonary rehabilitation program in patients with chronic obstructive pulmonary disease. Respir Med. 100(6): 1050–7. 2006. KQ1E1, KQ2E5, KQ3E816253496
97 Kerwin, EM, Kalberg, CJ, . Umeclidinium/vilanterol as step-up therapy from tiotropium in patients with moderate COPD: a randomized, parallel-group, 12-week study. International Journal of Copd. 12. 745–755. 2017. KQ1E1, KQ2E5, KQ3E828280319
98 Kerwin, EM, Murray, L, . Clinically Important Deterioration Among Patients with Chronic Obstructive Pulmonary Disease (COPD) Treated with Nebulized Glycopyrrolate: A Post Hoc Analysis of Pooled Data from Two Randomized, Double-Blind, Placebo-Controlled Studies. International Journal of Copd. 15. 2309–2318. 2020. 10.2147/COPD.S267249 KQ1E1, KQ2E5, KQ3E833061349
99 Khdour, MR, Kidney, JC, . Clinical pharmacy-led disease and medicine management programme for patients with COPD. Br J Clin Pharmacol. 68(4): 588–98. 2009. KQ1E1, KQ2E3a, KQ3E819843062
100 Ko, FW, Dai, DL, . Effect of early pulmonary rehabilitation on health care utilization and health status in patients hospitalized with acute exacerbations of COPD. Respirology. 16(4): 617–24. 2011. KQ1E1, KQ2E3a, KQ3E821199163
101 Koff, PB, Jones, RH, . Proactive integrated care improves quality of life in patients with COPD. Eur Respir J. 33(5): 1031–8. 2009. KQ1E1, KQ2E5, KQ3E819129289
102 LaForce, C, Derom, E, . Long-term safety of tiotropium/olodaterol Respimat R in patients with moderate-to-very severe COPD and renal impairment in the TONADO R studies. International Journal of Copd. 13. 1819–1831. 2018. KQ1E1, KQ2E7, KQ3E829910611
103 Lamers, F, Jonkers, CC, . Improving quality of life in depressed COPD patients: effectiveness of a minimal psychological intervention. COPD. 7(5): 315–22. 2010. KQ1E1, KQ2E6, KQ3E620854045
104 Larson, JL, Covey, MK, . Self-efficacy enhancing intervention increases light physical activity in people with chronic obstructive pulmonary disease. Int J Chron Obstruct Pulmon Dis. 9. 1081–90. 2014. KQ1E1, KQ2E3a, KQ3E825336939
105 Lazaar, AL, Miller, BE, . CXCR2 antagonist for patients with chronic obstructive pulmonary disease with chronic mucus hypersecretion: a phase 2b trial. Respir Res. 21(1): 149. 2020. KQ1E1, KQ2E3a, KQ3E3a32532258
106 Lazaar, AL, Miller, BE, . Effect of the CXCR2 antagonist danirixin on symptoms and health status in COPD. Eur Respir J. 52(4): 10. 2018. KQ1E1, KQ2E3a, KQ3E3a
107 Lee, JH, Park, YH, . Risk of Pneumonia Associated with Inhaled Corticosteroid in Patients with Chronic Obstructive Pulmonary Disease: A Korean Population-Based Study. International Journal of Copd. 15. 3397–3406. 2020. 10.2147/COPD.S286149 KQ1E1, KQ2E1, KQ3E3a33402820
108 Lee, SH, Lee, J, . Efficacy and safety of aclidinium bromide in patients with COPD: A phase 3 randomized clinical trial in a Korean population. Respirology. 20(8): 1222–8. 2015. KQ1E1, KQ2E5, KQ3E826370136
109 Lee, YM, Kim, SJ, . Inhaled corticosteroids in COPD and the risk of lung cancer. Int J Cancer. 143(9): 2311–2318. 2018. KQ1E1, KQ2E1, KQ3E3a29943812
110 Lei, S, Li, M, . The long-term outcomes of tobacco control strategies based on the cognitive intervention for smoking cessation in COPD patients. Respir Med. 172. 106155. 2020. 10.1016/j.rmed.2020.106155 KQ1E1, KQ2E3a, KQ3E832949957
111 Licskai, C, Ferrone, M, . COPD collaborative self-management in primary care: a randomized controlled trial. Eur Respir J. 48(Suppl 60): Oa1994. 2016. KQ1E1, KQ2E3a, KQ3E8
112 Lin, F, Yeh, M, . Two-month breathing-based walking improves anxiety, depression, dyspnoea and quality of life in chronic obstructive pulmonary disease: a randomised controlled study. Journal of clinical nursing (john wiley & sons, inc.). 28(19/20): 3632–3640. 2019. KQ1E1, KQ2E5, KQ3E8
113 Lin, HW, Chung, CL, . Inhaled Pharmacotherapy and Stroke Risk in Patients with Chronic Obstructive Pulmonary Disease: A Nationwide Population Based Study Using Two-Stage Approach. PLoS ONE [Electronic Resource]. 10(7): e0130102. 2015. KQ1E1, KQ2E1, KQ3E3a26158649
114 Lin, HW, Lin, LF, . Chronic obstructive pulmonary disease with short-acting inhaled pharmacotherapy increases the risk of prostate cancer: A two-stage database approach. PLoS ONE [Electronic Resource]. 13(9): e0203377. 2018. KQ1E1, KQ2E1, KQ3E3a30188953
115 Liou, JT, Lin, CW, . Risk of Severe Cardiovascular Events From Add-On Tiotropium in Chronic Obstructive Pulmonary Disease. Mayo Clin Proc. 93(10): 1462–1473. 2018. KQ1E1, KQ2E1, KQ3E3a30104044
116 Lipworth, BJ, Collier, DJ, . Improved lung function and patient-reported outcomes with co-suspension delivery technology glycopyrrolate/formoterol fumarate metered dose inhaler in COPD: a randomized Phase III study conducted in Asia, Europe, and the USA. International Journal of Copd. 13. 2969–2984. 2018. KQ1E1, KQ2E3a, KQ3E830310273
117 Liu, Xiao-Dan, Jin, Hong-Zhu, . Therapeutic Effects of Qigong in Patients with COPD: A Randomized Controlled Trial. Hong Kong Journal of Occupational Therapy. 22(1): 38–46. 2012. KQ1E1, KQ2E6, KQ3E6
118 Loeckx, M, Louvaris, Z, . Compliance with a three month telecoaching program to enhance physical activity in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 191(Meeting Abstracts): A2007. 2015. KQ1E1, KQ2E5, KQ3E8
119 Loeckx, M, Rabinovich, Ra, . Smartphone-based physical activity telecoaching in chronic obstructive pulmonary disease: mixed-methods study on patient experiences and lessons for implementation. JMIR mhealth uhealth. 6(12): e200. 2018. 10.2196/mhealth.9774 KQ1E1, KQ2E5, KQ3E830578215
120 Lord, VM, Cave, P, . Singing teaching as a therapy for chronic respiratory disease--a randomised controlled trial and qualitative evaluation. BMC Pulm Med. 10. 41. 2010. KQ1E1, KQ2E5, KQ3E820682030
121 Louvaris, Z, Spetsioti, S, . Interval training induces clinically meaningful effects in daily activity levels in COPD. Eur Respir J. 48(2): 567–570. 2016. KQ1E1, KQ2E5, KQ3E827338191
122 Magnussen, H, Arzt, M, . Aclidinium bromide improves symptoms and sleep quality in COPD: a pilot study. Eur Respir J. 49(6): 06. 2017. KQ1E1, KQ2E5, KQ3E8
123 Magnussen, H, Arzt, M, . The Effect of Aclidinium Bromide 400 µg on Lung Function, Sleep Quality and Physical Activity in Patients with Chronic Obstructive Pulmonary Disease: results of a Phase IV Pilot Study. Am J Respir Crit Care Med. 193(Meeting Abstracts): A6820. 2016. KQ1E1, KQ2E5, KQ3E8
124 Man, WD, Polkey, MI, . Community pulmonary rehabilitation after hospitalisation for acute exacerbations of chronic obstructive pulmonary disease: randomised controlled study. BMJ. 329(7476): 1209. 2004. KQ1E1, KQ2E5, KQ3E815504763
125 Martin, IR, McNamara, D, . Care plans for acutely deteriorating COPD: a randomized controlled trial. Chron Respir Dis. 1(4): 191–5. 2004. KQ1E1, KQ2E3a, KQ3E816281645
126 Martinez, Fj, Anderson, J, . Impact of Vilanterol, Fluticasone Furoate, or Their Combination on Exacerbations in COPD Patients with Moderate Airflow Obstruction: the SUMMIT Trial. Am J Respir Crit Care Med. 193(Meeting Abstracts): A6786. 2016. KQ1E10, KQ2E10, KQ3E10
127 Martinez, FJ, Lipworth, BJ, . Benefits of glycopyrrolate/formoterol fumarate metered dose inhaler (GFF MDI) in improving lung function and reducing exacerbations in patients with moderate-to-very severe COPD: a pooled analysis of the PINNACLE studies. Respir Res. 21(1): 128. 2020. KQ1E1, KQ2E3a, KQ3E832450869
128 Martinez, FJ, Rabe, KF, . Efficacy and Safety of Glycopyrrolate/Formoterol Metered Dose Inhaler Formulated Using Co-Suspension Delivery Technology in Patients With COPD. Chest. 151(2): 340–357. 2017. KQ1E1, KQ2E3a, KQ3E3a27916620
129 Martinsen, U, Bentzen, H, . The effect of occupational therapy in patients with chronic obstructive pulmonary disease: a randomized controlled trial. Scand J Occup Ther. 24(2): 89–97. 2017. KQ1E1, KQ2E3a, KQ3E826982627
130 McGeoch, GR, Willsman, KJ, . Self-management plans in the primary care of patients with chronic obstructive pulmonary disease. Respirology. 11(5): 611–8. 2006. KQ1E1, KQ2E3a, KQ3E816916335
131 Mitchell, KE, Johnson-Warrington, V, . A self-management programme for COPD: a randomised controlled trial. Eur Respir J. 44(6): 1538–47. 2014. KQ1E1, KQ2E3a, KQ3E825186259
132 Monninkhof, E, van der Valk, P, . Effects of a comprehensive self-management programme in patients with chronic obstructive pulmonary disease. Eur Respir J. 22(5): 815–20. 2003. KQ1E1, KQ2E3a, KQ3E814621090
133 Naya, I, Tombs, L, . Impact of prior and concurrent medication on exacerbation risk with long-acting bronchodilators in chronic obstructive pulmonary disease: a post hoc analysis. Respir Res. 20(1): 60. 2019. KQ1E1, KQ2E3a, KQ3E830914064
134 Ninot, G, Moullec, G, . Cost-saving effect of supervised exercise associated to COPD self-management education program. Respir Med. 105(3): 377–85. 2011. KQ1E1, KQ2E3a, KQ3E821036024
135 Nolan, Cm, Maddocks, M, . Pedometer Step Count Targets during Pulmonary Rehabilitation in Chronic Obstructive Pulmonary Disease. A Randomized Controlled Trial. Am J Respir Crit Care Med. 195(10): 1344–1352. 2017. KQ1E1, KQ2E3a, KQ3E827911566
136 Ohar, J, Tosiello, R, . Efficacy and safety of a novel, nebulized glycopyrrolate for the treatment of COPD: effect of baseline disease severity and age; pooled analysis of GOLDEN 3 and GOLDEN 4. International Journal of Copd. 14. 27–37. 2019. KQ1E1, KQ2E5, KQ3E830587959
137 Orme, MW, Weedon, AE, . Findings of the Chronic Obstructive Pulmonary Disease-Sitting and Exacerbations Trial (COPD-SEAT) in Reducing Sedentary Time Using Wearable and Mobile Technologies With Educational Support: Randomized Controlled Feasibility Trial. JMIR Mhealth Uhealth. 6(4): e84. 2018. KQ1E1, KQ2E5, KQ3E829643055
138 Petersen, AM, Mittendorfer, B, . Physical activity counteracts increased whole-body protein breakdown in chronic obstructive pulmonary disease patients. Scand J Med Sci Sports. 18(5): 557–64. 2008. KQ1E1, KQ2E5, KQ3E818067517
139 Polkey, MI, Qiu, ZH, . Tai Chi and Pulmonary Rehabilitation Compared for Treatment-Naive Patients With COPD: A Randomized Controlled Trial. Chest. 153(5): 1116–1124. 2018. KQ1E1, KQ2E5, KQ3E829625777
140 Pradella, CO, Belmonte, GM, . Home-Based Pulmonary Rehabilitation for Subjects With COPD: A Randomized Study. Respir Care. 60(4): 526–32. 2015. KQ1E1, KQ2E5, KQ3E825269680
141 Rabe, KF, Watz, H, . Anti-inflammatory effects of roflumilast in chronic obstructive pulmonary disease (ROBERT): a 16-week, randomised, placebo-controlled trial. The Lancet Respiratory Medicine. 6(11): 827–836. 2018. KQ1E1, KQ2E5, KQ3E830224319
142 Raymakers, AJN, Sadatsafavi, M, . Inhaled corticosteroids and the risk of lung cancer in COPD: a population-based cohort study. Eur Respir J. 53(6). 2019. KQ1E1, KQ2E1, KQ3E3a
143 Rea, H, McAuley, S, . A chronic disease management programme can reduce days in hospital for patients with chronic obstructive pulmonary disease. Intern Med J. 34(11): 608–14. 2004. KQ1E1, KQ2E3a, KQ3E815546454
144 Rehman, A, Ganai, J, . Effect of Passive Stretching of Respiratory Muscles on Chest Expansion and 6-Minute Walk Distance in COPD Patients. International Journal of Environmental Research & Public Health [Electronic Resource]. 17(18): 06. 2020. 10.3390/ijerph17186480 KQ1E1, KQ2E5, KQ3E8
145 Reisner, C, Gottschlich, G, . 24-Hour Lung Function Profile of Novel Co-Suspension Technology Glycopyrrolate/Formoterol Metered Dose Inhaler Versus Placebo and Spiriva Respimat, in Patients with Moderate-To-Very-Severe Chronic Obstructive Pulmonary Disease. Am J Respir Crit Care Med. 193(Meeting Abstracts): A6823. 2016. KQ1E1, KQ2E5, KQ3E8
146 Rice, KL, Dewan, N, . Disease management program for chronic obstructive pulmonary disease: a randomized controlled trial. Am J Respir Crit Care Med. 182(7): 890–6. 2010. KQ1E1, KQ2E3a, KQ3E820075385
147 Ringbaek, TJ, Broendum, E, . Rehabilitation of patients with chronic obstructive pulmonary disease. Exercise twice a week is not sufficient!. Respir Med. 94(2): 150–4. 2000. KQ1E1, KQ2E5, KQ3E810714421
148 Rixon, L, Hirani, SP, . A RCT of telehealth for COPD patient’s quality of life: the whole system demonstrator evaluation. Clin Respir J. 11(4): 459–469. 2017. KQ1E1, KQ2E3a, KQ3E3a26260325
149 Robinson, SA, Shimada, SL, . A web-based physical activity intervention benefits persons with low self-efficacy in COPD: results from a randomized controlled trial. J Behav Med. 42(6): 1082–1090. 2019. KQ1E1, KQ2E5, KQ3E830980223
150 Robinson, SA, Wan, ES, . Age and Attitudes Towards an Internet-Mediated, Pedometer-Based Physical Activity Intervention for Chronic Obstructive Pulmonary Disease: Secondary Analysis. 24058297. 3(2): e19527. 2020. 10.2196/19527 KQ1E1, KQ2E5, KQ3E8
151 Rutkowski, S, Rutkowska, A, . Virtual reality rehabilitation in patients with chronic obstructive pulmonary disease: a randomized controlled trial. International journal of COPD. 15. 117–124. 2020. KQ1E1, KQ2E5, KQ3E832021150
152 Saeed, MI, Eklof, J, . Use of inhaled corticosteroids and the risk of developing type 2 diabetes in patients with chronic obstructive pulmonary disease. Diabetes Obes Metab. 22(8): 1348–1356. 2020. KQ1E1, KQ2E1, KQ3E3a32239604
153 Samp, JC, Joo, MJ, . Risk of Cardiovascular and Cerebrovascular Events in COPD Patients Treated With Long-Acting beta2-Agonist Combined With a Long-Acting Muscarinic or Inhaled Corticosteroid. Annals of Pharmacotherapy. 51(11): 945–953. 2017. KQ1E1, KQ2E1, KQ3E3a28677404
154 Santos, C, Rodrigues, F, . Pulmonary Rehabilitation in COPD: Effect of 2 Aerobic Exercise Intensities on Subject-Centered Outcomes--A Randomized Controlled Trial. Respir Care. 60(11): 1603–9. 2015. KQ1E1, KQ2E5, KQ3E826221044
155 Sethi, S, Donohue, JF, . Efficacy and safety of revefenacin for nebulization in patients with chronic obstructive pulmonary disease taking concomitant ICS/LABA or LABA: subgroup analysis from phase III trials. Ther Adv Respir Dis. 14. 1753466620905278. 2020. KQ1E1, KQ2E5, KQ3E832106777
156 Siler, TM, Donald, AC, . A randomized, parallel-group study to evaluate the efficacy of umeclidinium/vilanterol 62.5/25 mug on health-related quality of life in patients with COPD. International Journal of Copd. 11. 971–9. 2016. KQ1E1, KQ2E5, KQ3E827274218
157 Siler, Tm, Donald, Ac, . Arandomized, parallel-group study to evaluate the efficacy of umeclidinium/vilanterol 62.5/25 mug on health-related quality of life in patients with COPD. International journal of COPD. 11(1): 971–979. 2016. KQ1E1, KQ2E5, KQ3E827274218
158 Siler, TM, Nagai, A, . A randomised, phase III trial of once-daily fluticasone furoate/vilanterol 100/25 mug versus once-daily vilanterol 25 mug to evaluate the contribution on lung function of fluticasone furoate in the combination in patients with COPD. Respir Med. 123. 8–17. 2017. KQ1E1, KQ2E7, KQ3E828137501
159 Silva, Cmdse, Gomes Neto, M, . Effects of upper limb resistance exercise on aerobic capacity, muscle strength, and quality of life in COPD patients: a randomized controlled trial. Clin Rehabil. 32(12): 1636–1644. 2018. KQ1E1, KQ2E5, KQ3E830012033
160 Singh, D, Fuhr, R, . A Randomized Trial of Dual-Acting Bronchodilator AZD8871 for Chronic Obstructive Pulmonary Disease. Am J Respir Crit Care Med. 199(10): 1282–1284. 2019. KQ1E1, KQ2E5, KQ3E830768909
161 Singh, D, Emirova, A, . Efficacy and safety of CHF6001, a novel inhaled PDE4 inhibitor in COPD: the PIONEER study. Respir Res. 21(1): 246. 2020. 10.1186/s12931-020-01512-y KQ1E1, KQ2E3a, KQ3E832962709
162 Slok, AH, Kotz, D, . Effectiveness of the Assessment of Burden of COPD (ABC) tool on health-related quality of life in patients with COPD: a cluster randomised controlled trial in primary and hospital care. BMJ Open. 6(7): e011519. 2016. KQ1E1, KQ2E3a, KQ3E3a
163 Smith, JA, McGarvey, L, . The Effect of Aclidinium on Symptoms Including Cough in Chronic Obstructive Pulmonary Disease: A Phase 4, Double-Blind, Placebo-controlled, Parallel-Group Study. Am J Respir Crit Care Med. 200(5): 642–645. 2019. KQ1E1, KQ2E5, KQ3E830951372
164 Smith, JA. The Effect of Aclidinium on Symptoms Including Cough in COPD: a Phase IV, DoubleBlind, Placebo-Controlled, Parallel-Group Study. Am J Respir Crit Care Med. 2019. KQ1E1, KQ2E5, KQ3E8
165 Snoeck-Stroband, JB, Lapperre, TS, . Prediction of Long-Term Benefits of Inhaled Steroids by Phenotypic Markers in Moderate-to-Severe COPD: A Randomized Controlled Trial. PLoS ONE [Electronic Resource]. 10(12): e0143793. 2015. KQ1E1, KQ2E8, KQ3E826659582
166 Stamenova, V, Liang, K, . Technology-Enabled Self-Management of Chronic Obstructive Pulmonary Disease With or Without Asynchronous Remote Monitoring: Randomized Controlled Trial. J Med Internet Res. 22(7): e18598. 2020. 10.2196/18598 KQ1E1, KQ2E3a, KQ3E832729843
167 Suissa, S, Dell’Aniello, S, . Concurrent use of long-acting bronchodilators in COPD and the risk of adverse cardiovascular events. Eur Respir J. 49(5): 05. 2017. KQ1E1, KQ2E1, KQ3E3a
168 Suissa, S, Dell’Aniello, S, . Inhaled corticosteroid use and the incidence of lung cancer in COPD. Eur Respir J. 55(2): 02. 2020. KQ1E1, KQ2E1, KQ3E3a
169 Suissa, S, Dell’Aniello, S, . Long-Acting Bronchodilator Initiation in COPD and the Risk of Adverse Cardiopulmonary Events: A Population-Based Comparative Safety Study. Chest. 151(1): 60–67. 2017. KQ1E1, KQ2E1, KQ3E3a27554300
170 Sutanto, YS, Makhabah, DN, . Videogame assisted exercise training in patients with chronic obstructive pulmonary disease: A preliminary study. Pulmonology. 25(5): 275–282. 2019. KQ1E1, KQ2E5, KQ3E831076287
171 Tabak, M, Brusse-Keizer, M, . A telehealth program for self-management of COPD exacerbations and promotion of an active lifestyle: a pilot randomized controlled trial. Int J Chron Obstruct Pulmon Dis. 9. 935–44. 2014. KQ1E1, KQ2E3a, KQ3E825246781
172 Tabak, M, Vollenbroek-Hutten, MM, . A telerehabilitation intervention for patients with Chronic Obstructive Pulmonary Disease: a randomized controlled pilot trial. Clin Rehabil. 28(6): 582–91. 2014. KQ1E1, KQ2E5, KQ3E824293120
173 Tashkin, DP, Leimer, I, . Cardiac safety of tiotropium in patients with cardiac events: a retrospective analysis of the UPLIFT R trial. Respir Res. 16. 65. 2015. KQ1E1, KQ2E3a, KQ3E826031308
174 Tashkin, DP, Miravitlles, M, . Concomitant inhaled corticosteroid use and the risk of pneumonia in COPD: a matched-subgroup post hoc analysis of the UPLIFT R trial. Respir Res. 19(1): 196. 2018. KQ1E1, KQ2E3a, KQ3E830290801
175 Taylor, SJ, Sohanpal, R, . Self-management support for moderate-to-severe chronic obstructive pulmonary disease: a pilot randomised controlled trial. Br J Gen Pract. 62(603): e687–95. 2012. KQ1E1, KQ2E3a, KQ3E823265228
176 Theander, K, Jakobsson, P, . Effects of pulmonary rehabilitation on fatigue, functional status and health perceptions in patients with chronic obstructive pulmonary disease: a randomized controlled trial. Clin Rehabil. 23(2): 125–36. 2009. KQ1E1, KQ2E5, KQ3E819164400
177 Thom, DH, Willard-Grace, R, . Randomized Controlled Trial of Health Coaching for Vulnerable Patients with Chronic Obstructive Pulmonary Disease. Ann Am Thorac Soc. 15(10): 1159–1168. 2018. KQ1E1, KQ2E3a, KQ3E3a30130430
178 van Wetering, CR, Hoogendoorn, M, . Short- and long-term efficacy of a community-based COPD management programme in less advanced COPD: a randomised controlled trial. Thorax. 65(1): 7–13. 2010. KQ1E1, KQ2E3a, KQ3E819703824
179 Varas, AB, Cordoba, S, . Effectiveness of a community-based exercise training programme to increase physical activity level in patients with chronic obstructive pulmonary disease: A randomized controlled trial. Physiotherapy Research International. 23(4): e1740. 2018. KQ1E1, KQ2E3a, KQ3E830168228
180 Vestbo, J, Fabbri, L, . Inhaled corticosteroid containing combinations and mortality in COPD. Eur Respir J. 52(6): 12. 2018. KQ1E1, KQ2E5, KQ3E8
181 Vestbo, J, Leather, D, . Effectiveness of Fluticasone Furoate-Vilanterol for COPD in Clinical Practice. N Engl J Med. 375(13): 1253–60. 2016. KQ1E1, KQ2E3a, KQ3E3a27593504
182 Wakabayashi, R, Motegi, T, . Efficient integrated education for older patients with chronic obstructive pulmonary disease using the Lung Information Needs Questionnaire. Geriatr Gerontol Int. 11(4): 422–30. 2011. KQ1E1, KQ2E7, KQ3E821447136
183 Walters, J, Cameron-Tucker, H, . Effects of telephone health mentoring in community-recruited chronic obstructive pulmonary disease on self-management capacity, quality of life and psychological morbidity: a randomised controlled trial. BMJ Open. 3(9): e003097. 2013. KQ1E1, KQ2E3a, KQ3E8
184 Wang, CY, Lai, CC, . The association between inhaled corticosteroid and pneumonia in COPD patients: the improvement of patients’ life quality with COPD in Taiwan (IMPACT) study. International Journal of Copd. 11. 2775–2783. 2016. KQ1E1, KQ2E1, KQ3E3a27877031
185 Wang, L, Wu, K, . The Effects of Tai Chi on Lung Function, Exercise Capacity and Health Related Quality of Life for Patients With Chronic Obstructive Pulmonary Disease: A Pilot Study. Heart Lung Circ. 28(8): 1206–1212. 2019. KQ1E1, KQ2E5, KQ3E830166260
186 Watz, H, Troosters, T, . ACTIVATE: the effect of aclidinium/formoterol on hyperinflation, exercise capacity, and physical activity in patients with COPD. International Journal of Copd. 12. 2545–2558. 2017. KQ1E1, KQ2E5, KQ3E828883722
187 Welch, L, Orlando, R, . Findings from a pilot randomised trial of a social network self-management intervention in COPD. BMC Pulm Med. 20(1): 162. 2020. KQ1E1, KQ2E5, KQ3E832513163
188 Wise, RA, Chapman, KR, . Effect of Aclidinium Bromide on Major Cardiovascular Events and Exacerbations in High-Risk Patients With Chronic Obstructive Pulmonary Disease: The ASCENT-COPD Randomized Clinical Trial. JAMA. 321(17): 1693–1701. 2019. KQ1E1, KQ2E3a, KQ3E3a31063575
189 Wise, RA, Anderson, JA, . Adjudication of cardiovascular events in patients with chronic obstructive pulmonary disease: SUMMIT trial. Clinical Trials. 17(4): 430–436. 2020. 10.1177/1740774520920897 KQ1E1, KQ2E5, KQ3E832441114
190 Wood-Baker, R, McGlone, S, . Written action plans in chronic obstructive pulmonary disease increase appropriate treatment for acute exacerbations. Respirology. 11(5): 619–26. 2006. KQ1E1, KQ2E3a, KQ3E816916336
191 Wu, M, Zhou, LQ, . Efficacy of patients’ preferred exercise modalities in chronic obstructive pulmonary disease: A parallel-group, randomized, clinical trial. Clin Respir J. 12(4): 1581–1590. 2018. KQ1E1, KQ2E3a, KQ3E828925009
192 Yudhawati, R, Rasjid Hs, M. Effect of yoga on FEV1, 6-minute walk distance (6-MWD) and quality of life in patients with COPD group B. Advances in Respiratory Medicine. 87(5): 261–268. 2019. KQ1E1, KQ2E5, KQ3E831680225
193 Zhang, Ym. Salmeterol and fluticasone treatment for chronic obstructive pulmonary disease. J Trop Med. 17. 56–58. 2017. KQ1E9, KQ2E9, KQ3E9
194 Zheng, J, de Guia, T, . Efficacy and safety of fluticasone furoate/vilanterol (50/25 mcg; 100/25 mcg; 200/25 mcg) in Asian patients with chronic obstructive pulmonary disease: a randomized placebo-controlled trial. Curr Med Res Opin. 31(6): 1191–200. 2015. KQ1E1, KQ2E3a, KQ3E3a25830381
195 Zheng, J, Xu, JF, . Glycopyrrolate/formoterol fumarate metered dose inhaler for maintenance-naive patients with chronic obstructive pulmonary disease: a post-hoc analysis of the randomized PINNACLE trials. Respir Res. 21(1): 69. 2020. KQ1E1, KQ2E3a, KQ3E3a32164675
196 Zheng, J, Zhong, N, . Efficacy and safety of once-daily inhaled umeclidinium/vilanterol in Asian patients with COPD: results from a randomized, placebo-controlled study. International Journal of Copd. 10. 1753–67. 2015. KQ1E1, KQ2E3a, KQ3E3a26366068
197 Zhong, N, Zheng, J, . Efficacy and Safety of Once-Daily Inhaled Umeclidinium in Asian Patients with COPD: Results from a Randomized, Placebo-Controlled Study. International Journal of Copd. 15. 809–819. 2020. KQ1E1, KQ2E3a, KQ3E832368027
198 Zhu, S, Shi, K, . A modified 6-form Tai Chi for patients with COPD. Complement Ther Med. 39. 36–42. 2018. KQ1E1, KQ2E5, KQ3E830012390
199 Zwar, NA, Hermiz, O, . Care of patients with a diagnosis of chronic obstructive pulmonary disease: a cluster randomised controlled trial. Med J Aust. 197(7): 394–8. 2012. KQ1E1, KQ2E3a, KQ3E3a23025736