# Appendix C Included Studies List

## Included trials by author (ancillary publication(s) indented under primary article)

- Altenburg, WA, ten Hacken, NH, . Short- and long-term effects of a physical activity counselling programme in COPD: a randomized controlled trial. Respir Med. 109(1): 112–21. 2015.25499548
- Bischoff, EW, Akkermans, R, . Comprehensive self management and routine monitoring in chronic obstructive pulmonary disease patients in general practice: randomised controlled trial. BMJ. 345: e7642. 2012.23190905
- Fastenau, A, van Schayck, OC, . Effectiveness of an exercise training programme COPD in primary care: A randomized controlled trial. Respir Med. 165: 105943. 2020.32308200
- Jolly, K, Sidhu, MS, . Self management of patients with mild COPD in primary care: randomised controlled trial. BMJ. 361: k2241. 2018.29899047
  - Jolly, K, Sidhu, M, . Improving recruitment to a study of telehealth management for COPD: a cluster randomised controlled ‘study within a trial’ (SWAT) of a multimedia information resource. Trials [Electronic Resource]. 20(1): 453. 2019.31340853
- Sidhu, MS, Daley, A, . Patient self-management in primary care patients with mild COPD - protocol of a randomised controlled trial of telephone health coaching. BMC Pulm Med. 15: 16. 2015.25880414
- Liang, J, Abramson, MJ, . Interdisciplinary COPD intervention in primary care: a cluster randomised controlled trial. Eur Respir J. 53(4). 2019.
- Markun, S, Rosemann, T, . Care in Chronic Obstructive Lung Disease (CAROL): a randomised trial in general practice. Eur Respir J. 51(5): 05. 2018.
- Martinez, FJ, Rabe, KF, . Glycopyrrolate/Formoterol Fumarate Metered Dose Inhaler Improves Lung Function versus Monotherapies in GOLD Category A Patients with COPD: Pooled Data from the Phase III PINNACLE Studies. International Journal of Copd. 15: 99–106. 2020.32021148
- Moy, ML, Martinez, CH, . Long-Term Effects of an Internet-Mediated Pedometer-Based Walking Program for Chronic Obstructive Pulmonary Disease: Randomized Controlled Trial. J Med Internet Res. 18(8): e215. 2016.27502583
  - Moy, ML, Collins, RJ, . An Internet-Mediated Pedometer-Based Program Improves Health-Related Quality-of-Life Domains and Daily Step Counts in COPD: A Randomized Controlled Trial. Chest. 148(1): 128–137. 2015.25811395
- Nyberg, A, Tistad, M, . Can the COPD web be used to promote self-management in patients with COPD in swedish primary care: a controlled pragmatic pilot trial with 3 month- and 12 month follow-up. Scand J Prim Health Care. 37(1): 69–82. 2019.30700230
- Price, DB, Voorham, J, . Inhaled corticosteroids in COPD and onset of type 2 diabetes and osteoporosis: matched cohort study. NPJ Primary Care Respiratory Medicine. 29(1): 38. 2019.
- Roman, M, Larraz, C, . Efficacy of pulmonary rehabilitation in patients with moderate chronic obstructive pulmonary disease: a randomized controlled trial. BMC Fam Pract. 14: 21. 2013.23399113
- Tashkin, DP, Celli, B, . A 4-year trial of tiotropium in chronic obstructive pulmonary disease. N Engl J Med. 359(15): 1543–54. 2008.18836213
  - Decramer, M, Celli, B, . Effect of tiotropium on outcomes in patients with moderate chronic obstructive pulmonary disease (UPLIFT): a prespecified subgroup analysis of a randomised controlled trial. Lancet. 374(9696): 1171–8. 2009.19716598
  - Halpin, DMG, Tashkin, DP, . Effect of Tiotropium on Outcomes in Patients With COPD, Categorized Using the New GOLD Grading System: Results of the UPLIFT R Randomized Controlled Trial. Chronic Obstructive Pulmonary Diseases. 2(3): 236–251. 2015.28848846
  - Rabe, KF, Halpin, DMG, . Composite endpoints in COPD: clinically important deterioration in the UPLIFT trial. Respir Res. 21(1): 177. 2020.32646424
  - Tashkin, DP, Celli, BR, . Efficacy of tiotropium in COPD patients with FEV1 >/= 60% participating in the UPLIFT(R) trial. COPD. 9(3): 289–96. 2012.22432932
- Vestbo, Jørgen, Anderson, JulieA, . Fluticasone furoate and vilanterol and survival in chronic obstructive pulmonary disease with heightened cardiovascular risk (SUMMIT): a double-blind randomised controlled trial. Lancet. 387(10030): 1817–1826. 2016.27203508
  - Brook, RD, Anderson, JA, . Cardiovascular outcomes with an inhaled beta2-agonist/corticosteroid in patients with COPD at high cardiovascular risk. Heart. 103(19): 1536–1542. 2017.28416587
  - Calverley, PMA, Anderson, JA, . Fluticasone Furoate, Vilanterol, and Lung Function Decline in Patients with Moderate Chronic Obstructive Pulmonary Disease and Heightened Cardiovascular Risk. Am J Respir Crit Care Med. 197(1): 47–55. 2018.28737971
  - Celli, B, Anderson, JA, . Long-Acting beta-Agonist/Inhaled Corticosteroid in Patients with Chronic Obstructive Pulmonary Disease with Cardiovascular Disease or Risk: A Factorial Analysis of the SUMMIT Clinical Trial. Am J Respir Crit Care Med. 197(12): 1641–1644. 2018.29412688
  - Crim, C, Calverley, PMA, . Pneumonia risk with inhaled fluticasone furoate and vilanterol in COPD patients with moderate airflow limitation: The SUMMIT trial. Respir Med. 131: 27–34. 2017.28947039
- Voncken-Brewster, V, Tange, H, . A randomized controlled trial evaluating the effectiveness of a web-based, computer-tailored self-management intervention for people with or at risk for COPD. International Journal of Copd. 10: 1061–73. 2015.26089656
- Wan, ES, Kantorowski, A, . Long-term effects of web-based pedometer-mediated intervention on COPD exacerbations. Respir Med. 162: 105878. 2020.32056676
  - Wan, E. S., Kantorowski, A., Homsy, D., Teylan, M., Kadri, R., Richardson, C. R., Gagnon, D. R., Garshick, E., Moy, M. L. Promoting physical activity in COPD: Insights from a randomized trial of a web-based intervention and pedometer use. Respiratory Medicine. 2017; 130:102–110.29206627
- Wang, MT, Liou, JT, . Association of Cardiovascular Risk With Inhaled Long-Acting Bronchodilators in Patients With Chronic Obstructive Pulmonary Disease: A Nested Case-Control Study. JAMA Intern Med. [Epub ahead of print]. 2018.
- Weldam, SWM, Schuurmans, MJ, . The effectiveness of a nurse-led illness perception intervention in COPD patients: a cluster randomised trial in primary care. Erj Open Research. 3(4): 2017.
- Zwar, NA, Bunker, JM, . Early intervention for chronic obstructive pulmonary disease by practice nurse and GP teams: a cluster randomized trial. Fam Pract. 33(6): 663–670. 2016.27535327