# Appendix B Literature Flow

Appendix B Figure 1 Literature Flow Diagram

*Articles may appear under more than one Key Question

This figure is a flow chart that summarizes the search and selection of articles in this review. There were 19354 citations identified through literature databases and an additional 69 citations were identified from outside sources. After duplicates were removed, 6387 unique citations were screened at the title/abstract stage. The full-text of 229 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=0), Key question 2 (k=16), and Key Question 3 (k=8). Reasons for excluding the other articles are available in Appendix D.