# Appendix A Detailed Methods

## Literature search strategy

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- AG = age
- TX = all text

### MEDLINE

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R) <1946 to July 22, 2020>

Search Strategy:

------------------------------------------------------------

1. Pulmonary Disease, Chronic Obstructive/
2. Bronchitis, Chronic/
3. Lung Diseases, Obstructive/
4. asthma-chronic obstructive pulmonary disease overlap syndrome/
5. (chronic obstruct$ or chronic airflow limitation$ or obstructive lung or chronic bronchitis or COPD or COAD).ti.
6. (chronic obstruct$ or chronic airflow limitation$ or obstructive lung or chronic bronchitis or COPD or COAD).ti,ab.
7. limit 6 to (“in data review” or in process or publisher or “pubmed not medline”)
8. or/1-5,7
9. Mass screening/
10. Spirometry/
11. Bronchospirometry/
12. Respiratory Function Tests/
13. screen$.ti,ab.
14. spiromet$.ti,ab.
15. bronchospiromet$.ti,ab.
16. ((respiratory or lung) adj2 function test$).ti,ab.
17. or/9-16
18. 8 and 17
19. Pulmonary Disease, Chronic Obstructive/di [Diagnosis]
20. Bronchitis, Chronic/di
21. Lung Diseases, Obstructive/di
22. or/18-21
23. (clinical trial or adaptive clinical trial or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or randomized controlled trial or equivalence trial or pragmatic clinical trial or Meta-Analysis).pt.
24. clinical trials as topic/ or adaptive clinical trials as topic/ or clinical trials, phase iii as topic/ or clinical trials, phase iv as topic/ or controlled clinical trials as topic/ or non-randomized controlled trials as topic/ or randomized controlled trials as topic/ or equivalence trials as topic/ or intention to treat analysis/ or pragmatic clinical trials as topic/ or meta-analysis as topic/
25. control groups/ or double-blind method/ or single-blind method/ or random allocation/ or placebos/
26. (randomized or randomised or placebo or randomly or phase iii or phase 3).ti,ab.
27. (RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$).ti,ab.
28. ((control$ or clinical) adj3 (study or studies or trial$ or group$)).ti,ab.
29. (Nonrandom$ or non random$ or non-random$ or quasi-random$ or quasirandom$).ti,ab.
30. ((open label or open-label) adj5 (study or studies or trial$)).ti,ab.
31. ((equivalence or superiority or non-inferiority or noninferiority) adj3 (study or studies or trial$)).ti,ab.
32. (pragmatic study or pragmatic studies).ti,ab.
33. ((pragmatic or practical) adj3 trial$).ti,ab.
34. ((quasiexperimental or quasi-experimental) adj3 (study or studies or trial$)).ti,ab.
35. (metaanaly$ or meta analy$).ti,ab.
36. or/23-35
37. 22 and 36
38. limit 37 to (english language and yr=“2015 -Current”)
39. remove duplicates from 38
40. Bronchodilator Agents/ [start of tx]
41. Cholinergic Antagonists/
42. Adrenergic beta-Agonists/
43. Adrenergic beta-2 Receptor Agonists/
44. “Nebulizers and Vaporizers”/
45. Expectorants/
46. Muscarinic Antagonists/
47. Adrenal Cortex Hormones/
48. Albuterol/
49. Fenoterol/
50. Ipratropium/
51. Terbutaline/
52. Bronchodilat$.ti,ab.
53. (anticholinergic$ or anti-cholinergic$).ti,ab.
54. (beta$ adj3 (agonist$ or adrenergic or adrenoceptor)).ti,ab.
55. (SABA$ or LABA$).ti,ab.
56. Albuterol.ti,ab.
57. Salbutamol.ti,ab.
58. Fenoterol.ti,ab.
59. Levalbuterol.ti,ab.
60. Xopenex HFA.ti,ab.
61. Pirbuterol.ti,ab.
62. Maxair Autohaler.ti,ab.
63. Terbutaline.ti,ab.
64. Spiriva.ti,ab.
65. Arformoterol.ti,ab.
66. Brovana.ti,ab.
67. Formoterol.ti,ab.
68. Foradil.ti,ab.
69. Indacaterol.ti,ab.
70. breezhaler.ti,ab.
71. Arcapta.ti,ab.
72. Salmeterol.ti,ab.
73. Serevent diskus.ti,ab.
74. Olodaterol.ti,ab.
75. Vilanterol.ti,ab.
76. Umeclidinium.ti,ab.
77. muscarin$ antagonist$.ti,ab.
78. antimuscarin$.ti,ab.
79. anti muscarin$.ti,ab.
80. (SAMA$ or LAMA$).ti,ab.
81. Ipratropium.ti,ab.
82. Aclidinium.ti,ab.
83. Tudorza Pressair.ti,ab.
84. (Glycopyrronium or glycopyrrolate).ti,ab.
85. Seebri.ti,ab.
86. Tiotropium.ti,ab.
87. Respimat.ti,ab.
88. HandiHaler.ti,ab.
89. Revefenacin.ti,ab.
90. glucocorticoid$.ti,ab.
91. (inhal$ and (corticosteroid$ or steroid$)).ti,ab.
92. Beclomethasone.ti,ab.
93. Qvar.ti,ab.
94. Betamethasone.ti,ab.
95. Budesonide.ti,ab.
96. Pulmicort flexhaler.ti,ab.
97. Ciclesonide.ti,ab.
98. Alvesco.ti,ab.
99. Symbicort.ti,ab.
100. Flunisolide.ti,ab.
101. Aerobid.ti,ab.
102. Fluticasone.ti,ab.
103. Flovent.ti,ab.
104. Mometasone.ti,ab.
105. Asmanex.ti,ab.
106. Triamcinolone.ti,ab.
107. Dry powder$ inhaler$.ti,ab.
108. Metered dose inhaler$.ti,ab.
109. Breath actuated inhaler$.ti,ab.
110. Accuhaler.ti,ab.
111. Turbohaler.ti,ab.
112. Diskhaler.ti,ab.
113. Nebuli?er$.ti,ab.
114. Receptors, Interleukin-8B/
115. ((CXCR2 or interleukin 8B or IL8B or IL-8B) adj3 (antagonis$ or receptor$)).ti,ab.
116. CXC chemokine receptor 2.ti,ab.
117. (AZD5069 or AZD-5069).ti,ab.
118. (MK-7123 or MK7123 or Navarixin or SCH-527123).ti,ab.
119. (Danirixin or GSK1325756 or GSK-1325756).ti,ab.
120. (Elubrixin or SB-656933 or SB656933).ti,ab.
121. (SX-682 or SX682).ti,ab.
122. nonpharmacologic intervention$.ti,ab.
123. non pharmacologic intervention$.ti,ab.
124. Case Management/
125. “Delivery of Health Care, Integrated”/
126. Patient Care Management/
127. (Case management or Integrated care or Care coordination or coordinated care).ti,ab.
128. Counseling/
129. Directive Counseling/
130. Health Promotion/
131. Self-Management/
132. Risk Reduction Behavior/
133. health behavior/
134. Health Education/
135. Health Promotion/
136. Patient Education as Topic/
137. Healthy lifestyle/
138. counsel$.ti,ab.
139. (advice or advise or consultation$).ti,ab.
140. (behavio$ adj2 (therap$ or chang$ or modification$ or improv$)).ti,ab.
141. (monitoring adj1 (patient$ or activity or health)).ti,ab.
142. (set$ adj2 goal$).ti,ab.
143. action plan$.ti,ab.
144. (assessment adj5 feedback).ti,ab.
145. support planning.ti,ab.
146. risk factor management.ti,ab.
147. (life style or lifestyle).ti,ab.
148. motivation$.ti,ab.
149. health coach$.ti,ab.
150. health behavio$.ti,ab.
151. health education.ti,ab.
152. education$ program$.ti,ab.
153. patient education.ti,ab.
154. self manag$.ti,ab.
155. (self adj (model or plan)).ti,ab.
156. (promot$ adj3 (health or exercise$ or physical activit$ or weight loss)).ti,ab.
157. Smoking cessation/
158. “Tobacco Use Cessation”/
159. Smoking Prevention/
160. ((smok$ or cigarette$) adj10 (cessation or quit$ or stop$ or abstain$ or abstinence)).ti,ab.
161. Diet, Reducing/ or nutrition therapy/ or nutritional support/
162. Feeding behavior/
163. Healthy diet/
164. Weight Reduction Programs/
165. (diet or diets or dietary or nutrition).ti.
166. Exercise/
167. Exercise Therapy/ or Exercise Movement Techniques/
168. (exercis$ or physical activit$).ti.
169. or/40-168
170. 8 and 169
171. Pulmonary Disease, Chronic Obstructive/dt
172. Bronchitis, Chronic/dt
173. Lung Diseases, Obstructive/dt
174. or/170-173
175. 36 and 174
176. limit 175 to (english language and yr=“2015 -Current”)
177. Mortality/ [start of tx harms]
178. Morbidity/
179. Death/
180. “Drug-Related Side Effects and Adverse Reactions”/
181. safety.ti,ab.
182. harm$.ti,ab.
183. mortality.ti,ab.
184. toxicity.ti,ab.
185. complication$.ti,ab.
186. (death or deaths).ti,ab.
187. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab.
188. side effect$.ti,ab.
189. adverse effects.fs.
190. toxicity.fs.
191. mortality.fs.
192. Dizziness/
193. Headache/
194. Xerostomia/
195. Constipation/
196. Urinary Retention/
197. Urinary Tract Infections/
198. Muscle Cramp/
199. Hematoma/
200. Candidiasis, Oral/
201. Bone Density/de [Drug Effects]
202. Fractures, Bone/
203. Cataract/
204. Glaucoma/
205. Glaucoma, open-angle/
206. Cough/
207. Bronchial Spasm/
208. Arrhythmias, Cardiac/
209. Tachycardia/
210. Heart Failure/
211. Heart Arrest/
212. Heart Rate/de [Drug Effects]
213. Myocardial Infarction/
214. Cardiomyopathies/
215. xerostomia$.ti,ab.
216. dry mouth.ti,ab.
217. headache$.ti,ab.
218. tremor$.ti,ab.
219. constipat$.ti,ab.
220. urinary retention.ti,ab.
221. urinary tract infection$.ti,ab.
222. muscle cramp$.ti,ab.
223. (bruise$ or bruising).ti,ab.
224. h?ematoma$.ti,ab.
225. (((oral or oropharyngeal) adj candidiasis) or moniliasis).ti,ab.
226. ((low or decrease$) adj3 (bone mass density or BMD)).ti,ab.
227. fracture$.ti,ab.
228. cataract$.ti,ab.
229. glaucoma.ti,ab.
230. paradoxical bronchospasm$.ti,ab.
231. bronchial spasm$.ti,ab.
232. respiratory death$.ti,ab.
233. cardiovascular event$.ti,ab.
234. arrhythmi$.ti,ab.
235. tachycardi$.ti,ab.
236. palpitation$.ti,ab.
237. ((rapid or increase$ or elevat$) adj3 (heart rate or heartbeat)).ti,ab.
238. myocardial infarction$.ti,ab.
239. cardiomyopath$.ti,ab.
240. (heart adj (failure$ or attack$)).ti,ab.
241. cardiac death$.ti,ab.
242. (respiratory infection$ or respiratory tract infection$ or throat irritation or pharyngitis or sinusitis or rhinitis).ti,ab.
243. (myalgia or pain or back problem$ or headache).ti,ab.
244. (dyspepsia or constipation or vomiting or gastroenteritis or gastrointestinal discomfort or stomach ache or diarrhea or nausea).ti,ab.
245. (voice alteration or dysphonia or otitis media or conjunctivitis or nasal congestion or nasal discharge or epistaxis).ti,ab.
246. (fever or pyrexia or edema or rash or dysmenorrhea or dizziness).ti,ab.
247. (infection or flu syndrome or pneumonia).ti,ab.
248. or/177-247
249. 174 and 248
250. limit 249 to (english language and yr=“2015 -Current”)
251. 39 or 176 or 250
252. 251 not (animals/ not humans/)
253. 252 not ((exp infant/ or child/ or adolescence/) not (exp adult/ or exp aged/ or middle aged/))
254. remove duplicates from 253

#### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

- ID Search Hits
#1 “chronic obstructive pulmonary” next disease*:ti,ab,kw
#2 “chronic obstructive airway” next disease*:ti,ab,kw
#3 “chronic airflow” next limitation*:ti,ab,kw
#4 “chronic obstructive respiratory” next disease*:ti,ab,kw
#5 “obstructive lung” next disease*:ti,ab,kw
#6 “chronic bronchitis”:ti,ab,kw
#7 COPD:ti,ab,kw or COAD:ti,ab,kw
#8 #1 or #2 or #3 or #4 or #5 or #6 or #7 21043
#9 (prescreen* or pre-screen* or screen*):ti,ab,kw
#10 (early or earlier):ti,ab,kw near/3 (identif* or test* or detect*):ti,ab,kw
#11 (spiromet* or bronchospiromet*):ti,ab,kw
#12 (respiratory or lung):ti,ab,kw near/3 test*:ti,ab,kw
#13 (“peak flow” or “peak expiratory flow”):ti,ab,kw
#14 (famil* near/3 histor*):ti,ab,kw
#15 #9 or #10 or #11 or #12 or #13 or #14
#16 #8 and #15 with Publication Year from 2015 to 2020, in Trials
#17 (treat* or therap*):ti
#18 bronchodilat*:ti,ab,kw
#19 (anticholinergic* or anti-cholinergic*):ti,ab,kw
#20 beta*:ti,ab,kw near/3 (agonist* or adrenergic or adrenoceptor):ti,ab,kw
#21 (SABA or LABA):ti,ab,kw
#22 Albuterol:ti,ab,kw
#23 Salbutamol:ti,ab,kw
#24 Fenoterol:ti,ab,kw
#25 Levalbuterol:ti,ab,kw
#26 Xopenex HFA:ti,ab,kw
#27 Pirbuterol:ti,ab,kw
#28 Maxair Autohaler:ti,ab,kw
#29 Terbutaline:ti,ab,kw
#30 Spiriva:ti,ab,kw
#31 Arformoterol:ti,ab,kw
#32 Brovana:ti,ab,kw
#33 Formoterol:ti,ab,kw
#34 Foradil:ti,ab,kw
#35 Indacaterol:ti,ab,kw
#36 breezhaler:ti,ab,kw
#37 Arcapta:ti,ab,kw
#38 Salmeterol:ti,ab,kw
#39 Serevent diskus:ti,ab,kw
#40 Olodaterol:ti,ab,kw
#41 Vilanterol:ti,ab,kw
#42 (muscarin* next antagonist*):ti,ab,kw
#43 antimuscarin*:ti,ab,kw
#44 (anti next muscarin*):ti,ab,kw
#45 (SAMA or LAMA):ti,ab,kw
#46 Ipratropium:ti,ab,kw
#47 Aclidinium:ti,ab,kw
#48 Tudorza Pressair:ti,ab,kw
#49 Glycopyrronium bromide:ti,ab,kw
#50 Seebri,ab,kw
#51 Tiotropium:ti,ab,kw
#52 Respimat:ti,ab,kw
#53 HandiHaler:ti,ab,kw
#54 glucocorticoid*:ti,ab,kw
#55 corticosteroid*:ti,ab,kw
#56 inhaled next steroid*:ti,ab,kw
#57 Beclomethasone:ti,ab,kw
#58 Qvar:ti,ab,kw
#59 Betamethasone:ti,ab,kw
#60 Budesonide:ti,ab,kw
#61 Pulmicort flexhaler:ti,ab,kw
#62 Ciclesonide:ti,ab,kw
#63 Alvesco:ti,ab,kw
#64 Symbicort:ti,ab,kw
#65 Flunisolide:ti,ab,kw
#66 Aerobid:ti,ab,kw
#67 Fluticasone:ti,ab,kw
#68 Flovent:ti,ab,kw
#69 Mometasone:ti,ab,kw
#70 Asmanex:ti,ab,kw
#71 Triamcinolone:ti,ab,kw
#72 (dry next powder* next inhaler*):ti,ab,kw
#73 (metered next dose* next inhaler*):ti,ab,kw
#74 (breath next actuated* next inhaler*):ti,ab,kw
#75 Accuhaler:ti,ab,kw
#76 Turbohaler:ti,ab,kw
#77 Diskhaler:ti,ab,kw
#78 (nebulizer* or nebuliser*):ti,ab,kw
#79 ((CXCR2 or interleukin 8B or IL8B or IL-8B) NEAR/3 (antagonis* or receptor*)):ti,ab,kw
#80 “CXC chemokine receptor 2”:ti,ab,kw
#81 (AZD5069 or AZD-5069):ti,ab,kw
#82 (MK-7123 or MK7123 or Navarixin or SCH-527123):ti,ab,kw
#83 (Danirixin or GSK1325756 or GSK-1325756):ti,ab,kw
#84 (Elubrixin or SB-656933 or SB656933):ti,ab,kw
#85 (SX-682 or SX682):ti,ab,kw
#86 (nonpharmacologic or “non pharmacologic”):ti,ab,kw
#87 (“case management” or “integrated care” or “care coordination” or “coordinated care”):ti,ab,kw
#88 (counsel* or advice or advise or consultation*):ti,ab,kw
#89 (behavio* NEAR/2 (therap* or chang* or modification* or improv*)):ti,ab,kw
#90 (monitoring NEAR/1 (patient* or activity or health)):ti,ab,kw
#91 (set* NEAR/2 goal*):ti,ab,kw
#92 Action NEXT plan*:ti,ab,kw
#93 (assessment NEAR/5 feedback):ti,ab,kw
#94 “support planning“:ti,ab,kw
#95 “risk factor management”:ti,ab,kw
#96 (“life style” or lifestyle):ti,ab,kw
#97 motivation*:ti,ab,kw
#98 health NEXT coach*:ti,ab,kw
#99 health NEXT behavio*:ti,ab,kw
#100 “health education”:ti,ab,kw
#101 education* NEXT program*:ti,ab,kw
#102 “patient education”:ti,ab,kw
#103 self NEXT manag*:ti,ab,kw
#104 (promot* NEAR/3 (health or exercise* or physical NEXT activit* or weight NEXT loss)):ti,ab,kw
#105 ((smok* or cigarette*) NEAR/10 (cessation or quit* or stop* or abstain* or abstinence)):ti,ab,kw
#106 (diet or diets or dietary or nutrition):ti
#107 (exercis* or physical NEXT activit*):ti
#108 {or #17-#107}
#109 #8 and #108 with Publication Year from 2015 to 2020, in Trials
#110 #16 or #109
#111 #110 NOT conference:pt

Appendix A Table 1 Inclusion and Exclusion Criteria

| Inclusion | Exclusion
Populations | KQ 1: adults aged 40 and over, asymptomatic adults, adults who have physical symptoms that are undetected by the patient or the clinician (e.g., have mild dyspnea that goes unnoticed); or those who have nonspecific symptoms (e.g., sporadic sputum production or cough) that have gone unrecognized as being related to COPD. | KQ 1: Patients with diagnosed COPD or other respiratory conditions; patients with identified alpha-1 antitrypsin deficiency; pregnant women
Populations | KQs 2, 3: adults^*^ aged 40 and over with screen-detected fixed airway obstruction; screen-relevant adults, e.g., patients with mild (forced expiratory volume in one second [FEV1] ≥ 80% predicted) to moderate (FEV1 50-79%) COPD^*^ or mean population FEV1 ≥ 60% predicted | KQs 2, 3: Patients with severe or very severe COPD; pregnant women; patients with identified alpha-1 antitrypsin deficiency
Setting | All KQs: Primary or specialty care or community-based settings; developed countries, as defined by Human Development Index (HDI) in “very high human development” category (>0.8) | All KQs: Inpatient settings
Interventions | KQ 1: Any screening method including pre-bronchodilator screening spirometry, questionnaires or risk assessment tools; peak flow meter; confirmatory post-bronchodilator spirometry | KQ 1: Testing used for disease monitoring or management, pulmonary imaging
Interventions | KQs 2, 3: Pharmacotherapy (including short and long acting beta-agonists, anticholinergics, inhaled corticosteroids, CXCR2 antagonists, or combinations of these treatments); Nonpharmacologic therapy (including case management, behavioral counseling, exercise therapy) | KQs 2, 3: Oxygen therapy; surgical therapies; lung transplant; treatment of acute exacerbations; systemic corticosteroids; phosphodiesterase-4 inhibitors; mucolytic agents; antibiotics^†^; acupuncture, herbal or over the counter supplements; whole body vibration therapy
Comparisons | All KQs: Usual care; placebo; no screening/treatment | All KQs: Active comparator
Outcomes | KQs 1, 2: All-cause mortality, disease specific mortality, COPD-related morbidity; HRQoL at ≥6 months followup | KQs 1, 2: Change in FEV1
Outcomes | KQ 3: Serious adverse events requiring unexpected or unwanted medical attention and/or resulting in death (e.g., requiring hospitalization)
Study Designs | KQs 1, 2: RCT | KQs 1, 2: Nonrandomized studies including cohort studies, case-control studies, case series
Study Designs | KQ 3: RCTs included for KQ2, large registry studies of drug safety
Study Quality | All KQs: Good- & fair-quality | All KQs: Poor-quality
Language | All KQs: English | All KQs: Non-English studies

* Based on the GOLD criteria COPD classifications

† Patients with severe disease would constitute a very small minority of those identified by asymptomatic screening spirometry and thus the treatment modalities recommended for these patients will not be considered in this evidence review (i.e. oxygen therapy, surgical treatment to reduce lung volume, and lung transplantation).

Abbreviations: COPD = chronic obstructive pulmonary disease; CXCR2 = CXC chemokine receptor 2; FEV_1_ = forced expiratory volume in one second; GOLD = Global Initiative for Chronic Obstructive Lung Disease; HRQol = health related quality of life; RCT = randomized controlled trial

Appendix A Table 2 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Randomized and non-randomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^3^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - Controlled Clinical Trial only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Registry studies, adapted from the Newcastle-Ottawa Scale^60^ | - Does the cohort appear to be valid?; - Is the cohort representative of the average-risk patient?; - Did the study adjust for prognostic variables?; - Can we be confident in the assessment of the presence or absence of prognostic factors?; - Can we be confident in the assessment of outcomes?

* Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent review.